# Appendix C Excluded Studies

Reasons for exclusion

E1. Wrong aim or irrelevant
E2. Wrong setting; a. Non-HDI country
E3. Wrong comparator; a. Comparative effectiveness (e.g., liquid-based cytology vs. conventional cytology alone); b. No comparator
E4. No relevant outcomes; a. Observational study reporting outcomes represented in RCTs
E5. Wrong population; a. Ages 18–21 years; b. Studies conducted in women with abnormal screening results (e.g., cytology with HPV triage, HPV positive women only); c. Cohort defined by testing results (e.g., lab-based study)
E6. Wrong intervention (not an HPV primary screening strategy)
E7. Wrong study design; a. Observational study, n<10,000 participants; b. Single group cohort study with one round of screening; exceptions to the rule include addressing a subpopulation of interest
E8. Non-English
E9. Poor quality; a. High or differential attrition; b. Other quality issues
E10. Unable to locate

Abbreviations: HDI = Human Development Index; HPV = human papillomavirus; RCT = randomized controlled trial

1 Human papillomavirus testing for triage of women with cytologic evidence of low-grade squamous intraepithelial lesions: baseline data from a randomized trial. The Atypical Squamous Cells of Undetermined Significance/Low-Grade Squamous Intraepithelial Lesions Triage Study (ALTS) Group. J Natl Cancer Inst. 2000;92(5):397–402. PMID: 10700419. http://dx.doi.org/10.1093/jnci/92.5.397 KQ1E5b, KQ2E5b.10700419
2 Long-term follow-up of ARTISTIC cervical screening trial cohort. http://www.nets.nihr.ac.uk/projects/hta/9804501. Accessed PMID: None. KQ1E4, KQ2E4.
3 Agorastos T, Chatzistamatiou K, Katsamagkas T, Primary screening for cervical cancer based on high-risk human papillomavirus (HPV) detection and HPV 16 and HPV 18 genotyping, in comparison to cytology. PLoS One. 2015;10(3). PMID: 25793281. http://dx.doi.org/10.1371/journal.pone.0119755 KQ1E7a, KQ2E7a.25793281
4 Amarosa EJ, Winer RL, Hong KJ, Impact of Possibly Oncogenic High-Risk Human Papillomavirus (HPV) Types in Triage for ASC-US Cervical Cytology Results. J Low Genit Tract Dis. 2015;19(4):307–10. PMID: 26125096. http://dx.doi.org/10.1097/LGT.0000000000000132 KQ1E5, KQ2E5.26125096
5 Andersson S, Dillner L, Elfgren K, A comparison of the human papillomavirus test and Papanicolaou smear as a second screening method for women with minor cytological abnormalities. Acta Obstet Gynecol Scand. 2005;84(10):996–1000. PMID: 16167918. http://dx.doi.org/10.1111/j.0001-6349.2005.00702.x KQ1E5b, KQ2E5b.16167918
6 Anonymous. HPV testing on self collected cervicovaginal lavage specimens as screening method for women who do not attend cervical screening: cohort study. BMJ. 2016;353:i2823. PMID: 27193898. http://dx.doi.org/10.1136/bmj.i2823 KQ1E1, KQ2E1.27193898
7 Anonymous. Safety of extending screening intervals beyond five years in cervical screening programmes with testing for high risk human papillomavirus: 14 year follow-up of population based randomised cohort in the Netherlands. BMJ. 2016;355:i5782. PMID: 2778953427789534. https://dx.doi.org/10.1136/bmj.i5782 KQ1E4, KQ2E4.
8 Anttila A, Hakama M, Kotaniemi-Talonen L, Alternative technologies in cervical cancer screening: a randomised evaluation trial. BMC Public Health. 2006;6:252. PMID: 17042938. http://dx.doi.org/10.1186/1471-2458-6-252 KQ1E4, KQ2E4.17042938
9 Anttila A, Kotaniemi-Talonen L, Leinonen M, Rate of cervical cancer, severe intraepithelial neoplasia, and adenocarcinoma in situ in primary HPV DNA screening with cytology triage: randomised study within organised screening programme. BMJ. 2010;340:c1804. PMID: 20423964. http://dx.doi.org/10.1136/bmj.c1804 KQ1E4, KQ2E4.20423964
10 Ascus-Lsil Traige Study Group. Results of a randomized trial on the management of cytology interpretations of atypical squamous cells of undetermined significance. Am J Obstet Gynecol. 2003;188(6):1383–92. PMID: 12824967. http://dx.doi.org/10.1067/mob.2003.457 KQ1E5b, KQ2E5b.12824967
11 Ascus-Lsil Traige Study Group. A randomized trial on the management of low-grade squamous intraepithelial lesion cytology interpretations. Am J Obstet Gynecol. 2003;188(6):1393–400. PMID: 12824968. http://dx.doi.org/10.1067/mob.2003.462 KQ1E5b, KQ2E5b.12824968
12 Baussano I, Franceschi S, Gillio-Tos A, Difference in overall and age-specific prevalence of high-risk human papillomavirus infection in Italy: evidence from NTCC trial. BMC Infect Dis. 2013;13:238. PMID: 23706168. http://dx.doi.org/10.1186/1471-2334-13-238 KQ1E6, KQ2E6, X4.23706168
13 Belinson J, Qiao YL, Pretorius R, Shanxi Province Cervical Cancer Screening Study: a cross-sectional comparative trial of multiple techniques to detect cervical neoplasia. Gynecol Oncol. 2001;83(2):439–44. PMID: 11606114. http://dx.doi.org/10.1006/gyno.2001.6370 KQ1E2a, KQ2E2a.11606114
14 Bergeron C, Giorgi-Rossi P, Cas F, Informed cytology for triaging HPV-positive women: substudy nested in the NTCC randomized controlled trial. J Natl Cancer Inst. 2015;107(2). PMID: 25568167. http://dx.doi.org/10.1093/jnci/dju423 KQ1E1, KQ2E1.25568167
15 Bergeron C, Jeannel D, Poveda J, Human papillomavirus testing in women with mild cytologic atypia. Obstet Gynecol. 2000;95(6 Pt 1):821–7. PMID: 10831974. KQ1E5b, KQ2E5b.10831974
16 Bigras G, de Marval F. The probability for a Pap test to be abnormal is directly proportional to HPV viral load: results from a Swiss study comparing HPV testing and liquid-based cytology to detect cervical cancer precursors in 13,842 women. Br J Cancer. 2005;93(5):575–81. PMID: 16136031. http://dx.doi.org/10.1038/sj.bjc.6602728 KQ1E7b, KQ2E7b.16136031
17 Bjerre P, Silfverdal L, Dillner L, A randomized trial of basing treatment on human papillomavirus and/or cytology results in low-grade cervical lesion triage. Am J Obstet Gynecol. 2008;199(1):24e1–7. PMID: 18295172. http://dx.doi.org/10.1016/j.ajog.2007.11.053 KQ1E5b, KQ2E5b.18295172
18 Blatt AJ, Kennedy R, Luff RD, Comparison of cervical cancer screening results among 256,648 women in multiple clinical practices. Cancer Cytopathol. 2015;123(5):282–8. PMID: 25864682. http://dx.doi.org/10.1002/cncy.21544 KQ1E5c, KQ2E5c.25864682
19 Bowring J, Albrow R, Fisher A, A prospective study of human papillomavirus (HPV) testing to resolve uncertainty in colposcopy. Cytopathology. 2013;24(5):309–13. PMID: 22925374. http://dx.doi.org/10.1111/j.1365-2303.2012.01003.x KQ1E5b, KQ2E5b.22925374
20 Budenholzer B. Adding HPV testing to cytology screening reduced > grade 3 cervical intraepithelial neoplasia at 5 years. Ann Intern Med. 2012;157(2):Jc2–6. PMID: 22801698. http://dx.doi.org/10.7326/0003-4819-157-2-201207170-02006 KQ1E7, KQ2E7.22801698
21 Bulkmans NW, Berkhof J, Rozendaal L, Human papillomavirus DNA testing for the detection of cervical intraepithelial neoplasia grade 3 and cancer: 5-year follow-up of a randomised controlled implementation trial. Lancet. 2007;370(9601):1764–72. PMID: 17919718. http://dx.doi.org/10.1016/S0140-6736(07)61450-0 KQ1E4, KQ2E4.17919718
22 Burger EA, Nygard M, Gyrd-Hansen D, Does the primary screening test influence women’s anxiety and intention to screen for cervical cancer? A randomized survey of Norwegian women. BMC Public Health. 2014;14:360. PMID: 24735469. http://dx.doi.org/10.1186/1471-2458-14-360 KQ1E6, KQ2E6, X2.24735469
23 Cardenas-Turanzas M, Nogueras-Gonzalez GM, Scheurer ME, The performance of human papillomavirus high-risk DNA testing in the screening and diagnostic settings. Cancer Epidemiol Biomarkers Prev. 2008;17(10):2865–71. PMID: 18843032. http://dx.doi.org/10.1158/1055-9965.EPI-08-0137 KQ1E7a, KQ2E7a.18843032
24 Carozzi F, Gillio-Tos A, Confortini M, Risk of high-grade cervical intraepithelial neoplasia during follow-up in HPV-positive women according to baseline p16-INK4A results: A prospective analysis of a nested substudy of the NTCC randomised controlled trial. The Lancet Oncology.2013 Available from:http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/249/CN-00912249/frame.html. KQ1E1, KQ2E1.
25 Carozzi F, Ronco G, Gillio-Tos A, Concurrent infections with multiple human papillomavirus (HPV) types in the New Technologies for Cervical Cancer (NTCC) screening study. Eur J Cancer. 2012;48(11):1633–7. PMID: 22088483. http://dx.doi.org/10.1016/j.ejca.2011.10.010 KQ1E4, KQ2E4.22088483
26 Castle PE, Fetterman B, Poitras N, Variable risk of cervical precancer and cancer after a human papillomavirus-positive test. Obstet Gynecol. 2011;117(3):650–6. PMID: 21343769. http://dx.doi.org/http://dx.doi.org/10.1097/AOG.0b013e318209da59 KQ1E4, KQ2E4.21343769
27 Castle PE, Hunt WC, Langsfeld E, Three-year risk of cervical precancer and cancer after the detection of low-risk human papillomavirus genotypes targeted by a commercial test. Obstet Gynecol. 2014;123(1):49–56. PMID: 24463663. http://dx.doi.org/10.1097/AOG.0000000000000013 KQ1E3, KQ2E3.24463663
28 Castle PE, Stoler MH, Wright TC, Performance of carcinogenic human papillomavirus (HPV) testing and HPV16 or HPV18 genotyping for cervical cancer screening of women aged 25 years and older: a subanalysis of the ATHENA study. Lancet Oncol. 2011;12(9):880–90. PMID: 21865084. http://dx.doi.org/10.1016/S1470-2045(11)70188-7 KQ1E4, KQ2E4.21865084
29 Catteau X, Simon P, Noel JC. Evaluation of the Oncogenic Human Papillomavirus DNA Test with Liquid-Based Cytology in Primary Cervical Cancer Screening and the Importance of the ASC/SIL Ratio: A Belgian Study. ISRN Obstet Gynecol. 2014;2014:536495. PMID: 24693444. http://dx.doi.org/10.1155/2014/536495 KQ1E6, KQ2E6, X4.24693444
30 Choi JW, Kim Y, Lee JH, The clinical performance of primary HPV screening, primary HPV screening plus cytology cotesting, and cytology alone at a tertiary care hospital. Cancer Cytopathol. 2016;124(2):144–52. PMID: 26457676. http://dx.doi.org/10.1002/cncy.21632 KQ1E7, KQ2E7.26457676
31 Cochand-Priollet B, Le Gales C, de Cremoux P, Cost-effectiveness of monolayers and human papillomavirus testing compared to that of conventional Papanicolaou smears for cervical cancer screening: protocol of the study of the French Society of Clinical Cytology. Diagn Cytopathol. 2001;24(6):412–20. PMID: 11391824. KQ1E4a, KQ2E4a.11391824
32 Cook DA, Smith LW, Law J, Aptima HPV Assay versus Hybrid Capture 2 HPV test for primary cervical cancer screening in the HPV FOCAL trial. J Clin Virol. 2017;87:23–9. PMID: 27988420. https://dx.doi.org/10.1016/j.jcv.2016.12.004 KQ1E4, KQ2E4.27988420
33 Coste J, Cochand-Priollet B, de Cremoux P, Cross sectional study of conventional cervical smear, monolayer cytology, and human papillomavirus DNA testing for cervical cancer screening. BMJ. 2003;326(7392):733. PMID: 12676841. http://dx.doi.org/10.1136/bmj.326.7392.733 KQ1E4a, KQ2E4a.12676841
34 Cox JT, Castle PE, Behrens CM, Comparison of cervical cancer screening strategies incorporating different combinations of cytology, HPV testing, and genotyping for HPV 16/18: results from the ATHENA HPV study. Am J Obstet Gynecol. 2013;208(3):184e1–.e11. PMID: 23174289. http://dx.doi.org/10.1016/j.ajog.2012.11.020 KQ1E4, KQ2E4.23174289
35 Daley EM, Vamos CA, Wheldon CW, Negative emotions and stigma associated with a human papillomavirus test result: A comparison between human papillomavirus-positive men and women. J Health Psychol. 2015;20(8):1073–82. PMID: 24217064. http://dx.doi.org/10.1177/1359105313507963 KQ1E1, KQ2E1.24217064
36 de Cremoux P, Coste J, Sastre-Garau X, Efficiency of the hybrid capture 2 HPV DNA test in cervical cancer screening. A study by the French Society of Clinical Cytology. Am J Clin Pathol. 2003;120(4):492–9. PMID: 14560561. http://dx.doi.org/10.1309/XFUC-PP6M-5XUA-94B8 KQ1E4a, KQ2E4a.14560561
37 Del Mistro A, Frayle H, Ferro A, Cervical cancer screening by high risk HPV testing in routine practice: results at one year recall of high risk HPV-positive and cytology-negative women. J Med Screen. 2014;21(1):30–7. PMID: 24488593. http://dx.doi.org/10.1177/0969141314522219 KQ1E7b, KQ2E7b.24488593
38 Del Mistro A, Frayle-Salamanca H, Trevisan R, Triage of women with atypical squamous cells of undetermined significance (ASC-US): results of an Italian multicentric study. Gynecol Oncol. 2010;117(1):77–81. PMID: 20116836. http://dx.doi.org/10.1016/j.ygyno.2010.01.003 KQ1E5b, KQ2E5b.20116836
39 Dijkstra MG, van Niekerk D, Rijkaart DC, Primary hrHPV DNA testing in cervical cancer screening: how to manage screen-positive women? A POBASCAM trial substudy. Cancer Epidemiol Biomarkers Prev. 2014;23(1):55–63. PMID: 23733907. http://dx.doi.org/10.1158/1055-9965.EPI-13-0173 KQ1E7, KQ2E7.23733907
40 Drolet M, Brisson M, Maunsell E, The psychosocial impact of an abnormal cervical smear result. Psychooncology. 2012;21(10):1071–81. PMID: 21695747. http://dx.doi.org/10.1002/pon.2003 KQ1E6, KQ2E6.21695747
41 Ehlen T, Ogilvie G, Niekerk D, editors. HPV focal: First round screen results from a randomized controlled trial in a canadian population based program. 14th Biennial Meeting of the International journal of gynecological cancer; 2012 Oct 13–16; Vancouver, BC Canada. Search 1 CENTRAL 20150806. KQ1E4, KQ2E4.
42 Elfgren K, Elfstrom KM, Naucler P, Management of women with human papillomavirus persistence: long-term follow-up of a randomized clinical trial. Am J Obstet Gynecol. 2016. PMID: 2782597727825977. https://dx.doi.org/10.1016/j.ajog.2016.10.042 KQ1E4, KQ2E4.
43 Elfgren K, Rylander E, Radberg T, Colposcopic and histopathologic evaluation of women participating in population-based screening for human papillomavirus deoxyribonucleic acid persistence. Am J Obstet Gynecol. 2005;193(3 Pt 1):650–7. PMID: 16150255. http://dx.doi.org/10.1016/j.ajog.2005.01.056 KQ1E4, KQ2E4.16150255
44 Elfstrom KM, Smelov V, Johansson AL, Long-term HPV type-specific risks for ASCUS and LSIL: a 14-year follow-up of a randomized primary HPV screening trial. Int J Cancer. 2015;136(2):350–9. PMID: 24842156. http://dx.doi.org/10.1002/ijc.28984 KQ1E4, KQ2E4.24842156
45 Gage JC, Hunt WC, Schiffman M, Risk Stratification Using Human Papillomavirus Testing among Women with Equivocally Abnormal Cytology: Results from a State-Wide Surveillance Program. Cancer Epidemiol Biomarkers Prev. 2016;25(1):36–42. PMID: 26518316. http://dx.doi.org/10.1158/1055-9965.EPI-15-0669 KQ1E7, KQ2E7.26518316
46 Gage JC, Katki HA, Schiffman M, Age-stratified 5-year risks of cervical precancer among women with enrollment and newly detected HPV infection. Int J Cancer. 2015;136(7):1665–71. PMID: 25136967. http://dx.doi.org/10.1002/ijc.29143 KQ1E4, KQ2E4.25136967
47 Gillio-Tos A, De Marco L, Carozzi FM, Clinical impact of the analytical specificity of the hybrid capture 2 test: data from the New Technologies for Cervical Cancer (NTCC) study. J Clin Microbiol. 2013;51(9):2901–7. PMID: 23804385. http://dx.doi.org/10.1128/JCM.01047-13 KQ1E1, KQ2E1.23804385
48 Giorgi Rossi P, Carozzi F, Collina G, HPV testing is an efficient management choice for women with inadequate liquid-based cytology in cervical cancer screening. Am J Clin Pathol. 2012;138(1):65–71. PMID: 22706859. http://dx.doi.org/10.1309/AJCP6J2OEFOYTRFD KQ1E1, KQ2E1.22706859
49 Gok M, Heideman DA, van Kemenade FJ, HPV testing on self collected cervicovaginal lavage specimens as screening method for women who do not attend cervical screening: cohort study. BMJ. 2010;340:c1040. PMID: 20223872 http://dx.doi.org/10.1136/bmj.c1040 KQ1E5c, KQ2E5c.20223872
50 Goodman A. HPV testing as a screen for cervical cancer. BMJ. 2015;350:h2372. PMID: 26126623. http://dx.doi.org/10.1136/bmj.h2372 KQ1E7, KQ2E7, X8.26126623
51 Gyllensten U, Gustavsson I, Lindell M, Primary high-risk HPV screening for cervical cancer in post-menopausal women. Gynecol Oncol. 2012;125(2):343–5. PMID: 22293044. http://dx.doi.org/10.1016/j.ygyno.2012.01.036 KQ1E9b, KQ2E9b.22293044
52 Habbema D, Weinmann S, Arbyn M, Harms of cervical cancer screening in the United States and the Netherlands. Int J Cancer. 2017;140(5):1215–22. PMID: 27864938. https://dx.doi.org/10.1002/ijc.30524 KQ1E4, KQ2E4.27864938
53 Herweijer E, Feldman AL, Ploner A, The Participation of HPV-Vaccinated Women in a National Cervical Screening Program: Population-Based Cohort Study. PLoS ONE. 2015;10(7):e0134185. PMID: 26218492. http://dx.doi.org/http://dx.doi.org/10.1371/journal.pone.0134185 KQ1E1, KQ2E1.26218492
54 Huh WK, Sideri M, Stoler M, Relevance of random biopsy at the transformation zone when colposcopy is negative. Obstet Gynecol. 2014. 124(4): Available from: http://graphics.tx.ovid.com/ovftpdfs/FPDDNCOBEADEFA00/fs046/ovft/live/gv023/00006250/00006250-201410000-00004.pdf. KQ1E4, KQ2E4.
55 Ikenberg H, Bergeron C, Schmidt D, Screening for cervical cancer precursors with p16/Ki-67 dual-stained cytology: results of the PALMS study. J Natl Cancer Inst. 2013;105(20):1550–7. PMID: 24096620. http://dx.doi.org/10.1093/jnci/djt235 KQ1E7b, KQ2E7b.24096620
56 Isidean SD, Mayrand MH, Ramanakumar AV, Human papillomavirus testing versus cytology in primary cervical cancer screening: End-of-study and extended follow-up results from the Canadian cervical cancer screening trial. Int J Cancer. 2016;139(11):2456–66. PMID: 27538188. https://dx.doi.org/10.1002/ijc.30385 KQ1E4, KQ2E4.27538188
57 Isidean SD, Mayrand MH, Ramanakumar AV, COMPARISON OF TRIAGE STRATEGIES FOR HPV POSITIVE WOMEN: CANADIAN CERVICAL CANCER SCREENING TRIAL RESULTS. Cancer Epidemiol Biomarkers Prev. 2017. PMID: 2809619828096198. https://dx.doi.org/10.1158/1055-9965.epi-16-0705 KQ1E4, KQ2E4.
58 Jin XW, Lipold L, Foucher J, Cost-Effectiveness of Primary HPV Testing, Cytology and Co-testing as Cervical Cancer Screening for Women Above Age 30 Years. J Gen Intern Med. 2016;14:14. PMID: 27418345. http://dx.doi.org/10.1007/s11606-016-3772-5 KQ1E7, KQ2E7.27418345
59 Katki HA, Cheung LC, Fetterman B, A joint model of persistent human papillomavirus infection and cervical cancer risk: Implications for cervical cancer screening. Journal of Royal Statistical Society-Series-A. 2015;178(4):903–23. PMID: 26556961. http://dx.doi.org/10.1111/rssa.12101 KQ1E7, KQ2E7.26556961
60 Katki HA, Gage JC, Schiffman M, Follow-up testing after colposcopy: five-year risk of CIN 2+ after a colposcopic diagnosis of CIN 1 or less. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S69–77. PMID: 23519308. http://dx.doi.org/10.1097/LGT.0b013e31828543b1 KQ1E5, KQ2E5.23519308
61 Katki HA, Schiffman M, Castle PE, Five-year risk of CIN 3+ to guide the management of women aged 21 to 24 years. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S64–8. PMID: 23519307. http://dx.doi.org/10.1097/LGT.0b013e3182854399 KQ1E5, KQ2E5.23519307
62 Katki HA, Schiffman M, Castle PE, Five-year risks of CIN 3+ and cervical cancer among women with HPV-positive and HPV-negative high-grade Pap results. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S50–5. PMID: 23519305. http://dx.doi.org/10.1097/LGT.0b013e3182854282 KQ1E5, KQ2E5.23519305
63 Katki HA, Schiffman M, Castle PE, Five-year risks of CIN 2+ and CIN 3+ among women with HPV-positive and HPV-negative LSIL Pap results. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S43–9. PMID: 23519304. http://dx.doi.org/10.1097/LGT.0b013e3182854269 KQ1E5, KQ2E5.23519304
64 Katki HA, Schiffman M, Castle PE, Five-year risks of CIN 3+ and cervical cancer among women with HPV testing of ASC-US Pap results. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S36–42. PMID: 23519303. http://dx.doi.org/10.1097/LGT.0b013e3182854253 KQ1E5b, KQ2E5b.23519303
65 Katki HA, Schiffman M, Castle PE, Benchmarking CIN 3+ risk as the basis for incorporating HPV and Pap cotesting into cervical screening and management guidelines. J Low Genit Tract Dis. 2013;17(5 Suppl 1):S28–35. PMID: 23519302. http://dx.doi.org/http://dx.doi.org/10.1097/LGT.0b013e318285423c KQ1E4, KQ2E4.23519302
66 Katki HA, Wentzensen N. How might HPV testing be integrated into cervical screening? Lancet Oncol. 2012;13(1):8–10. PMID: 22177578. http://dx.doi.org/10.1016/S1470-2045(11)70334-5 KQ1E7, KQ2E7.22177578
67 Kitchener HC, Almonte M, Wheeler P, HPV testing in routine cervical screening: cross sectional data from the ARTISTIC trial. Br J Cancer. 2006;95(1):56–61. PMID: 16773068. http://dx.doi.org/10.1038/sj.bjc.6603210 KQ1E4, KQ2E4.16773068
68 Kitchener HC, Gilham C, Sargent A, A comparison of HPV DNA testing and liquid based cytology over three rounds of primary cervical screening: extended follow up in the ARTISTIC trial. European journal of cancer (Oxford, England: 1990) 2011.Available from:http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/590/CN-00801590/frame.html. KQ1E4, KQ2E4.
69 Kotaniemi-Talonen L, Anttila A, Malila N, Screening with a primary human papillomavirus test does not increase detection of cervical cancer and intraepithelial neoplasia 3. Eur J Cancer. 2008;44(4):565–71. PMID: 18248809. http://dx.doi.org/10.1016/j.ejca.2007.12.002 KQ1E4, KQ2E4.18248809
70 Kotaniemi-Talonen L, Nieminen P, Anttila A, Routine cervical screening with primary HPV testing and cytology triage protocol in a randomised setting. Br J Cancer. 2005;93(8):862–7. PMID: 16189520. http://dx.doi.org/10.1038/sj.bjc.6602799 KQ1E4, KQ2E4.16189520
71 Krajden M, Niekerk D, Ceballos K, HPV FOCAL: Round one results of a cervical cancer screening trial. Canadian Journal of Infectious Diseases and Medical Microbiology. 2012;23:19b. PMID: None. KQ1E4, KQ2E4.23449046
72 Kulasingam SL, Hughes JP, Kiviat NB, Evaluation of human papillomavirus testing in primary screening for cervical abnormalities: comparison of sensitivity, specificity, and frequency of referral. JAMA. 2002;288(14):1749–57. PMID: 12365959. http://dx.doi.org/10.1001/jama.288.14.1749 KQ1E4a, KQ2E4a.12365959
73 Kwan TT, Cheung AN, Lo SS, Psychological burden of testing positive for high-risk human papillomavirus on women with atypical cervical cytology: a prospective study. Acta Obstet Gynecol Scand. 2011;90(5):445–51. PMID: 21306349. http://dx.doi.org/10.1111/j.1600-0412.2011.01092.x KQ1E5b, KQ2E5b.21306349
74 Lagos M, Van De Wyngard V, Poggi H, HPV16/18 genotyping for the triage of HPV positive women in primary cervical cancer screening in Chile. Infectious Agents & Cancer 2015;10:43. PMID: 26600869. http://dx.doi.org/10.1186/s13027-015-0038-5 KQ1E7, KQ2E7.26600869
75 Lata K, Bhatla N. HPV testing for cervical cancer screening: Time for a new paradigm. Natl Med J India. 2014. Available from:http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/936/CN-01052936/frame.html. KQ1E7, KQ2E7.
76 Leinonen M, Nieminen P, Kotaniemi-Talonen L, Age-specific evaluation of primary human papillomavirus screening vs conventional cytology in a randomized setting. J Natl Cancer Inst. 2009;101(23):1612–23. PMID: 19903804. http://dx.doi.org/10.1093/jnci/djp367 KQ1E4, KQ2E4.19903804
77 Leinonen MK, Anttila A, Malila N, Type- and age-specific distribution of human papillomavirus in women attending cervical cancer screening in Finland. Br J Cancer. 2013;109(11):2941–50. PMID: 24136148. http://dx.doi.org/10.1038/bjc.2013.647 KQ1E3, KQ2E3.24136148
78 Lonnberg S, Nieminen P, Kotaniemi-Talonen L, Large performance variation does not affect outcome in the Finnish cervical cancer screening programme. Cytopathology. 2012;23(3):172–80. PMID: 21255160. http://dx.doi.org/10.1111/j.1365-2303.2011.00849.x KQ1E6, KQ2E6.21255160
79 Louvanto K, Chevarie-Davis M, Ramanakumar AV, HPV testing with cytology triage for cervical cancer screening in routine practice. Am J Obstet Gynecol. 2014;210(5):474e1–7. PMID: 24373948. http://dx.doi.org/10.1016/j.ajog.2013.12.033 KQ1E7b, KQ2E7b.24373948
80 Louwers JA, Berkhof J, Zaal A, HrHPV-testing in a university hospital gynecology outpatient clinic: recommendations for clinical practice. Gynecol Oncol. 2012;124(3):518–24. PMID: 22115855. http://dx.doi.org/10.1016/j.ygyno.2011.11.027 KQ1E5c, KQ2E5c.22115855
81 Luquain A, Belglaiaa E, Guenat D, High prevalence of abnormal cervical smears in a hospital cohort of French women beyond the upper age limit screening program. Prev Med. 2015;81:157–62. PMID: 26348451. http://dx.doi.org/10.1016/j.ypmed.2015.08.018 KQ1E7, KQ2E7.26348451
82 Maissi E, Marteau TM, Hankins M, Psychological impact of human papillomavirus testing in women with borderline or mildly dyskaryotic cervical smear test results: cross sectional questionnaire study. BMJ. 2004;328(7451):1293. PMID: 15166066. http://dx.doi.org/10.1136/bmj.328.7451.1293 KQ1E5b, KQ2E5b.15166066
83 Maissi E, Marteau TM, Hankins M, The psychological impact of human papillomavirus testing in women with borderline or mildly dyskaryotic cervical smear test results: 6-month follow-up. Br J Cancer. 2005;92(6):990–4. PMID: 15785734. http://dx.doi.org/10.1038/sj.bjc.6602411 KQ1E5b, KQ2E5b.15785734
84 Manos MM, Kinney WK, Hurley LB, Identifying women with cervical neoplasia: using human papillomavirus DNA testing for equivocal Papanicolaou results. JAMA. 1999;281(17):1605–10. PMID: 10235153. http://dx.doi.org/10.1001/jama.281.17.1605 KQ1E5b, KQ2E5b.10235153
85 Mayrand MH, Duarte-Franco E, Coutlee F, Randomized controlled trial of human papillomavirus testing versus Pap cytology in the primary screening for cervical cancer precursors: design, methods and preliminary accrual results of the Canadian cervical cancer screening trial (CCCaST). Int J Cancer. 2006;119(3):615–23. PMID: 16572425. http://dx.doi.org/10.1002/ijc.21897 KQ1E7b, KQ2E7b.16572425
86 Mayrand MH, Duarte-Franco E, Rodrigues I, Human papillomavirus DNA versus Papanicolaou screening tests for cervical cancer. N Engl J Med. 2007;357(16):1579–88. PMID: 17942871. http://dx.doi.org/10.1056/NEJMoa071430 KQ1E7b, KQ2E7b.17942871
87 McCaffery K, Waller J, Forrest S, Testing positive for human papillomavirus in routine cervical screening: examination of psychosocial impact. BJOG. 2004;111(12):1437–43. PMID: 15663132. http://dx.doi.org/http://dx.doi.org/10.1111/j.1471-0528.2004.00279.x KQ1E4, KQ2I1.15663132
88 McCaffery KJ, Irwig L, Turner R, Psychosocial outcomes of three triage methods for the management of borderline abnormal cervical smears: an open randomised trial. BMJ. 2010;340:b4491. PMID: 20179125. http://dx.doi.org/10.1136/bmj.b4491 KQ1E5b, KQ2E5b.20179125
89 McKenna M, McMenamin MM. Human papillomavirus testing in young women: clinical outcomes of human papillomavirus triage in a UK cervical screening program. Cancer Cytopathol. 2014;122(9):702–10. PMID: 24888573. http://dx.doi.org/10.1002/cncy.21444 KQ1E6, KQ2E6.24888573
90 Monsonego J, Hudgens MG, Zerat L, Evaluation of oncogenic human papillomavirus RNA and DNA tests with liquid-based cytology in primary cervical cancer screening: the FASE study. Int J Cancer. 2011;129(3):691–701. PMID: 20941740. http://dx.doi.org/10.1002/ijc.25726 KQ1E4a, KQ2E4a.20941740
91 Monsonego J, Hudgens MG, Zerat L, Risk assessment and clinical impact of liquid-based cytology, oncogenic human papillomavirus (HPV) DNA and mRNA testing in primary cervical cancer screening (the FASE study). Gynecol Oncol. 2012;125(1):175–80. PMID: 22233689. http://dx.doi.org/10.1016/j.ygyno.2012.01.002 KQ1E4a, KQ2E4a.22233689
92 Moy LM, Zhao FH, Li LY, Human papillomavirus testing and cervical cytology in primary screening for cervical cancer among women in rural China: comparison of sensitivity, specificity, and frequency of referral. Int J Cancer. 2010;127(3):646–56. PMID: 19960441. http://dx.doi.org/10.1002/ijc.25071 KQ1E2a, KQ2E2a.19960441
93 Naucler P, Ryd W, Tornberg S, Efficacy of HPV DNA testing with cytology triage and/or repeat HPV DNA testing in primary cervical cancer screening. J Natl Cancer Inst. 2009;101(2):88–99. PMID: 19141778. http://dx.doi.org/10.1093/jnci/djn444 KQ1E4, KQ2E4.19141778
94 Niekerk D, Ogilvie G, Krajden M, hrHPV DNA testing in cervical cancer screening. First round results From the HPV for CervicAL screening (HPV FOCAL) trial. Histopathology. 2012 61: Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/086/CN-01004086/frame.html. KQ1E4, KQ2E4.
95 Ogilvie G, Krajden M, Ehlen T, Age specific round 1 results of a cervical cancer screening trial: HPV FOCAL. Sex Transm Infect. 2013. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/410/CN-01060410/frame.html. KQ1E4, KQ2E4.
96 Ogilvie G, Smith L, Cook D, HPV focal trial: HPV infection rates at 48 month exit for women HPV negative at baseline. International Journal of Gynecology and Obstetrics (varpagings). 2015;131:E269. PMID: None. KQ1E4, KQ2E4.
97 Ogilvie GS, Krajden M, van Niekerk DJ, Primary cervical cancer screening with HPV testing compared with liquid-based cytology: results of round 1 of a randomised controlled trial - the HPV FOCAL Study. Br J Cancer. 2012;107(12):1917–24. PMID: 23169286. http://dx.doi.org/10.1038/bjc.2012.489 KQ1E4, KQ2E4.23169286
98 Ogilvie GS, Smith LW, van Niekerk DJ, Women’s intentions to receive cervical cancer screening with primary human papillomavirus testing. Int J Cancer. 2013;133(12):2934–43. PMID: 23754203. http://dx.doi.org/10.1002/ijc.28324 KQ1E1, KQ2E1.23754203
99 Pan Q, Belinson JL, Li L, A thin-layer, liquid-based pap test for mass screening in an area of China with a high incidence of cervical carcinoma. A cross-sectional, comparative study. Acta Cytol. 2003;47(1):45–50. PMID: 12585030. KQ1E2a, KQ2E2a.12585030
100 Passamonti B, Gustinucci D, Giorgi Rossi P, Cervical human papilloma virus (HPV) DNA primary screening test: Results of a population-based screening programme in central Italy. J Med Screen. 2016. PMID: 2761499227614992. https://dx.doi.org/10.1177/0969141316663580 KQ1E4, KQ2E4.
101 Petry KU, Menton S, Menton M, Inclusion of HPV testing in routine cervical cancer screening for women above 29 years in Germany: results for 8466 patients. Br J Cancer. 2003;88(10):1570–7. PMID: 12771924. http://dx.doi.org/10.1038/sj.bjc.6600918 KQ1E7, KQ2E7.12771924
102 Petry KU, Rinnau F, Bohmer G, Annual Papanicolaou screening for 5 years among human papillomavirus-negative women. BMC Cancer. 2013;13:379. PMID: 23937771. http://dx.doi.org/10.1186/1471-2407-13-379 KQ1E7, KQ2E7.23937771
103 Phillips S, Cornall AM, Machalek DA, Comparison of the Roche Cobas 4800 HPV assay to Roche Amplicor for detection of high-risk human papillomavirus. Eur J Clin Microbiol Infect Dis. 2016;35(8):1305–7. PMID: 27177752. http://dx.doi.org/10.1007/s10096-016-2665-1 KQ1E7, KQ2E7.27177752
104 Poljak M, Ostrbenk A, Seme K, Three-year longitudinal data on the clinical performance of the Abbott RealTime High Risk HPV test in a cervical cancer screening setting. J Clin Virol. 2016;76 Suppl 1:S29–39. PMID: 26643051. http://dx.doi.org/10.1016/j.jcv.2015.11.021 KQ1E7a, KQ2E7a.26643051
105 Porras C, Wentzensen N, Rodriguez AC, Switch from cytology-based to human papillomavirus test-based cervical screening: implications for colposcopy. Int J Cancer. 2012;130(8):1879–87. PMID: 21607948. http://dx.doi.org/10.1002/ijc.26194 KQ1E2a, KQ2E2a.21607948
106 Qiao YL, Sellors JW, Eder PS, A new HPV-DNA test for cervical-cancer screening in developing regions: a cross-sectional study of clinical accuracy in rural China. Lancet Oncol. 2008;9(10):929–36. PMID: 18805733. http://dx.doi.org/10.1016/S1470-2045(08)70210-9 KQ1E2a, KQ2E2a.18805733
107 Reid JL, Wright TC, Jr., Stoler MH, Human papillomavirus oncogenic mRNA testing for cervical cancer screening: baseline and longitudinal results from the CLEAR study. Am J Clin Pathol. 2015;144(3):473–83. PMID: 26276778. http://dx.doi.org/10.1309/AJCPHVD7MIP3FYVV KQ1E5, KQ2E5.26276778
108 Rijkaart DC, Berkhof J, van Kemenade FJ, Evaluation of 14 triage strategies for HPV DNA-positive women in population-based cervical screening. Int J Cancer. 2012;130(3):602–10. PMID: 21400507. http://dx.doi.org/10.1002/ijc.26056 KQ1E7b, KQ2E7b.21400507
109 Rijkaart DC, Berkhof J, van Kemenade FJ, HPV DNA testing in population-based cervical screening (VUSA-Screen study): results and implications. Br J Cancer. 2012;106(5):975–81. PMID: 22251922. http://dx.doi.org/10.1038/bjc.2011.581 KQ1E7b, KQ2E7b.22251922
110 Ronco G, Brezzi S, Carozzi F, The New Technologies for Cervical Cancer Screening randomised controlled trial. An overview of results during the first phase of recruitment. Gynecol Oncol. 2007;107(1 Suppl 1):S230–2. PMID: 17822751. http://dx.doi.org/10.1016/j.ygyno.2007.07.021 KQ1E4, KQ2E4.17822751
111 Ronco G, Cuzick J, Segnan N, HPV triage for low grade (L-SIL) cytology is appropriate for women over 35 in mass cervical cancer screening using liquid based cytology. Eur J Cancer. 2007;43(3):476–80. PMID: 17223540. http://dx.doi.org/10.1016/j.ejca.2006.11.013 KQ1E5b, KQ2E5b.17223540
112 Ronco G, Giorgi Rossi P, Giubilato P, A first survey of HPV-based screening in routine cervical cancer screening in Italy. Epidemiol Prev. 2015;39(3 Suppl 1):77–83. PMID: 26405779. KQ1E7, KQ2E7.26405779
113 Royer HR, Falk EC. Young women’s beliefs regarding human papillomavirus. Journal of Obstetric, Gynecologic, & Neonatal Nursing: Clinical Scholarship for the Care of Women, Childbearing Families, & Newborns. 2012;41(1):92–102. PMID: 22150824. http://dx.doi.org/10.1111/j.1552-6909.2011.01309.x KQ1E1, KQ2E1.22150824
114 Sankaranarayanan R, Chatterji R, Shastri SS, Accuracy of human papillomavirus testing in primary screening of cervical neoplasia: results from a multicenter study in India. Int J Cancer. 2004;112(2):341–7. PMID: 15352050. http://dx.doi.org/10.1002/ijc.20396 KQ1E2a, KQ2E2a.15352050
115 Sankaranarayanan R, Nene BM, Shastri SS, HPV screening for cervical cancer in rural India. N Engl J Med. 2009;360(14):1385–94. PMID: 19339719. http://dx.doi.org/http://dx.doi.org/10.1056/NEJMoa0808516 KQ1E2a, KQ2E2a.19339719
116 Sasaki Y, Iwanari O, Arakawa I, Cervical Cancer Screening With Human Papillomavirus DNA and Cytology in Japan. Int J Gynecol Cancer. 2016. PMID: 2799745527997455. https://dx.doi.org/10.1097/igc.0000000000000898 KQ1E4, KQ2E4.
117 Schiffman M, Glass AG, Wentzensen N, A long-term prospective study of type-specific human papillomavirus infection and risk of cervical neoplasia among 20,000 women in the Portland Kaiser Cohort Study.[Erratum appears in Cancer Epidemiol Biomarkers Prev. 2012 Aug;21(8):1390-1]. Cancer Epidemiol Biomarkers Prev. 2011;20(7):1398–409. PMID: 21602310. http://dx.doi.org/10.1158/1055-9965.EPI-11-0206 KQ1E7, KQ2E7.21602310
118 Schiffman M, Hyun N, Raine-Bennett TR, A cohort study of cervical screening using partial HPV typing and cytology triage. Int J Cancer. 2016;139(11):2606–15. PMID: 27509172. https://dx.doi.org/10.1002/ijc.30375 KQ1E4, KQ2E4.27509172
119 Shastri SS, Dinshaw K, Amin G, Concurrent evaluation of visual, cytological and HPV testing as screening methods for the early detection of cervical neoplasia in Mumbai, India. Bull World Health Organ. 2005;83(3):186–94. PMID: 15798842. http://dx.doi.org/S0042-96862005000300011 KQ1E2a, KQ2E2a.15798842
120 Smelov V, Elfstrom KM, Johansson ALV, Long-term HPV type-specific risks of high-grade cervical intraepithelial lesions: A 14-year follow-up of a randomized primary HPV screening trial. Int J Cancer. 2015 Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/151/CN-01072151/frame.html. KQ1E4, KQ2E4.
121 Smelov V, Elfstrom M. HPV type-specific risks for high-grade lesions: Long-term follow-up of the swedescreen study. Sex Transm Infect. 2013. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/716/CN-01010716/frame.html. KQ1E4, KQ2E4.
122 Sorbye SW, Fismen S, Gutteberg TJ, Primary cervical cancer screening with an HPV mRNA test: a prospective cohort study. BMJ Open. 2016;6(8):e011981. PMID: 27515759. https://dx.doi.org/10.1136/bmjopen-2016-011981 KQ1E4, KQ2E4.27515759
123 Thomsen LT, Frederiksen K, Munk C, High-risk and low-risk human papillomavirus and the absolute risk of cervical intraepithelial neoplasia or cancer. Obstet Gynecol. 2014;123(1):57–64. PMID: 24463664. http://dx.doi.org/10.1097/AOG.0000000000000056 KQ1E3c, KQ2E3c.24463664
124 Uijterwaal MH, Polman NJ, Van Kemenade FJ, Five-Year Cervical (Pre)Cancer Risk of Women Screened by HPV and Cytology Testing. Cancer Prevention Research. 2015;8(6):502–8. PMID: 25776933. http://dx.doi.org/10.1158/1940-6207.CAPR-14-0409 KQ1E7b, KQ2E7b.25776933
125 Veijalainen O, Kares S, Kujala P, Human papillomavirus test with cytology triage in organized screening for cervical cancer. Acta Obstet Gynecol Scand. 2016;95(11):1220–7. PMID: 27591407. https://dx.doi.org/10.1111/aogs.13013 KQ1E4, KQ2E4.27591407
126 Veldhuijzen NJ, Berkhof J, Gillio-Tos A, The age distribution of type-specific high-risk human papillomavirus incidence in two population-based screening trials. Cancer Epidemiol Biomarkers Prev. 2015;24(1):111–8. PMID: 25300476. http://dx.doi.org/10.1158/1055-9965.EPI-14-0628 KQ1E4, KQ2E4.25300476
127 Wheeler CM, Hunt WC, Cuzick J, The influence of type-specific human papillomavirus infections on the detection of cervical precancer and cancer: A population-based study of opportunistic cervical screening in the United States. Int J Cancer. 2014;135(3):624–34. PMID: 24226935. http://dx.doi.org/10.1002/ijc.28605 KQ1E5c, KQ2E5c.24226935
128 Wright TC, Jr., Stoler MH, Behrens CM, The ATHENA human papillomavirus study: design, methods, and baseline results. Am J Obstet Gynecol. 2012;206(1):46e1–e11. PMID: 21944226. http://dx.doi.org/10.1016/j.ajog.2011.07.024 KQ1E9b, KQ2E9b.21944226
129 Wright TC, Jr., Stoler MH, Behrens CM, Interlaboratory variation in the performance of liquid-based cytology: insights from the ATHENA trial. Int J Cancer. 2014;134(8):1835–43. PMID: 24122508. http://dx.doi.org/10.1002/ijc.28514 KQ1E1, KQ2E1.24122508
130 Wright TC, Stoler MH, Behrens CM, Primary cervical cancer screening with human papillomavirus: End of study results from the ATHENA study using HPV as the first-line screening test. Gynecol Oncol. 2015;136(2):189–97. PMID: 25579108. http://dx.doi.org/http://dx.doi.org/10.1016/j.ygyno.2014.11.076 KQ1E9b, KQ2E9b.25579108
131 Wright TC, Jr., Stoler MH, Sharma A, Evaluation of HPV-16 and HPV-18 genotyping for the triage of women with high-risk HPV+ cytology-negative results. Am J Clin Pathol. 2011;136(4):578–86. PMID: 21917680. http://dx.doi.org/10.1309/AJCPTUS5EXAS6DKZ KQ1E1, KQ2E1.21917680
132 Zhao C, Weng B, Li Z, Follow-up outcomes of a large cohort of low-risk women with negative imaged liquid-based cytology and negative HPV test results. Am J Clin Pathol. 2013;139(1):32–8. PMID: 23270896. http://dx.doi.org/10.1309/AJCP4DF7ACLBFFGY KQ1E5c, KQ2E5c.23270896
133 Zhou H, Mody RR, Luna E, Clinical performance of the Food and Drug Administration-Approved high-risk HPV test for the detection of high-grade cervicovaginal lesions. Cancer Cytopathol. 2016;124(5):317–23. PMID: 26774025. http://dx.doi.org/10.1002/cncy.21687 KQ1E5c, KQ2E5c.26774025