# Appendix B Recommendations of Others

Appendix B Cervical Cancer Screening Recommendations of Other Organizations Published Since the 2012 USPSTF Recommendation

Organization | Year | Recommendation Statement
American Society of Clinical Oncology (ASCO)^182^ | 2016 | - HPV testing is recommended in all resource settings. Co-testing is an option in maximal settings (which would include the US), however the added value on the basis of increased costs is limited.; - Self-collection of samples may be used for HPV testing.; - In maximal settings, women aged 25–65 years should be screened every 5 years (≥ 9 screens in a lifetime).; - Women with abnormal triage results should receive colposcopy, followed by LEEP or cryotherapy/cold coagulation. 12-month post-treatment followup is recommended.
American College of Physicians (ACP)^183^ | 2015 | Best practice advice:; - Clinicians should not screen average-risk women younger than 21 years for cervical cancer.; - Clinicians should start screening average-risk women for cervical cancer at age 21 years once every 3 years with cytology (cytologic tests without human papillomavirus [HPV] tests).; - Clinicians should not screen average-risk women for cervical cancer with cytology more often than once every 3 years.; - Clinicians may use a combination of cytology and HPV testing once every 5 years in average-risk women aged 30 years or older who prefer screening less often than every 3 years.; - Clinicians should not perform HPV testing in average-risk women younger than 30 years.; - Clinicians should stop screening average-risk women older than 65 years for cervical cancer if they have had 3 consecutive negative cytology results or 2 consecutive negative cytology plus HPV test results within 10 years, with the most recent test performed within 5 years.; - Clinicians should not screen average-risk women of any age for cervical cancer if they have had a hysterectomy with removal of the cervix.
Society for Gynecologic Oncology (SGO), the American Society for Colposcopy and Cervical Pathology (ASCCP), the American College of Obstetricians and Gynecologists (ACOG), the American Cancer Society (ACS), the American Society of Cytopathology (ASC), the College of American Pathologists (CAP) and the American Society for Clinical Pathology (ASCP)^66^ | 2015 | Interim guidance: A negative hrHPV test provides greater reassurance of low CIN3+ risk than a negative cytology result. Because of equivalent or superior effectiveness, primary hrHPV screening can be considered as an alternative to current U.S. cytology-based cervical cancer screening methods. Cytology alone and co-testing remain the screening options specifically recommended in major guidelines. Based on limited data, triage of hrHPV-positive women using a combination of genotyping for HPV 16 and 18 and reflex cytology for women positive for the 12 other hrHPV genotypes appears to be a reasonable approach to managing hrHPV-positive women. Re-screening after a negative primary hrHPV screen should occur no sooner than every 3 years. Primary hrHPV screening should not be initiated before 25 years of age.
National Comprehensive Cancer Network (NCCN)^184,^ ^185^ | 2014 | The NCCN endorses the 2012 ACS, ASCCP, and ASCP recommendations (see below).
Canadian Preventive Services Task Force (CPSTF)^186^ | 2013 | For women younger than 20 years of age, the CPSTF recommends not routinely screening for cervical cancer (strong recommendation; high-quality evidence). For women aged 20–24 years, the CPSTF recommends not routinely screening for cervical cancer (weak recommendation; moderate-quality evidence). For women aged 25–29 years, the CPSTF recommends routine screening for cervical cancer every 3 years (weak recommendation; moderate-quality evidence). For women aged 30–69 years, the CPSTF recommends routine screening for cervical cancer every 3 years (strong recommendation; high-quality evidence). For women aged 70 years and older who have undergone adequate screening (i.e., 3 successive negative Pap test results in the previous 10 years), the CPSTF recommends that routine screening may end. For women aged 70 years and older who have not undergone adequate screening, the CPSTF recommends continued screening until 3 negative test results have been obtained (weak recommendation; low-quality evidence).
Institute for Clinical Systems Improvement (ICSI)^187^ | 2013 | Endorses the 2012 USPSTF recommendations (see Section II).
World Health Organization (WHO)^188^ | 2013 | Where resources permit, HPV screening should be done on women aged 30 years and older, followed by treating with cryotherapy (or LEEP when not available), over screening with visual inspection with acetic acid or screening with cytology followed by colposcopy. This strategy is favored over screening with HPV testing followed by colposcopy.
American Cancer Society (ACS), American Society for Colposcopy and Cervical Pathology (ASCCP), and the American Society for Clinical Pathology (ASCP)^64^ | 2012 | Age to Begin Screening: Cervical cancer screening should begin at age 21 years. Women aged younger than 21 years should not be screened regardless of the age of sexual initiation or other risk factors. Screening Periodicity: Women at any age should NOT be screened annually by any screening method; rather, recommended screening intervals for women are based on age and clinical history. Women Aged 21 to 29 Years: For women aged 21 to 29 years, screening with cytology alone every 3 years is recommended. For women aged 21 to 29 years with 2 or more consecutive negative cytology results, there is insufficient evidence to support a longer screening interval (i.e., more than 3 years). HPV testing should not be used to screen women in this age group, either as a stand-alone test or as a co-test with cytology. Women Aged 30 to 65 Years: Women aged 30 to 65 years should be screened with cytology and HPV testing (“co-testing”) every 5 years (preferred) or cytology alone every 3 years (acceptable). There is insufficient evidence to change screening intervals in this age group following a history of negative screens. Management of Women With HPV-Positive, Cytology-Negative Co-tests: Women co-testing HPV positive, cytology negative should be followed with either (as noted in the interim ASCCP guidelines): Option 1) repeat co-testing in 12 months or Option 2) immediate HPV genotype-specific testing for HPV16 alone or for HPV16/18. If co-testing is repeated at 12 months, women testing positive on either test (HPV positive or LSIL or more severe cytology) should be referred to colposcopy; women testing negative on both tests (HPV-negative and ASC-US or negative cytology) should return to routine screening. If immediate HPV genotype-specific testing is used, women testing positive for HPV16 or HPV16/18 should be referred directly to colposcopy; women testing negative for HPV16 or HPV16/18 should be co-tested in 12 months, with management of results as described in option 1. Women co-testing HPV positive, cytology negative should not be referred directly to colposcopy. Furthermore, they should not be tested for individual HPV genotypes other than HPV16 and HPV18. The use of HPV genotype-specific testing for HPV16 or HPV16/18 is recommended only for the management of HPV-positive, cytology-negative women. Currently, there is insufficient evidence to support the use of non-HPV biomarkers. Management of Women With HPV-Negative, ASC-US Cytology Results: Women with ASC-US cytology and a negative HPV test result should continue with routine screening as per age-specific guidelines. Screening With HPV Testing Alone: In most clinical settings, women aged 30 years to 65 years should not be screened with HPV testing alone as an alternative to co-testing at 5-year intervals or cytology alone at 3-year intervals. Women Aged Older Than 65 Years: Women aged older than 65 years with evidence of adequate negative prior screening and no history of CIN2+ within the last 20 years should not be screened for cervical cancer with any modality (adequate negative prior screening is defined as 3 consecutive negative cytology results or 2 consecutive negative co-tests within the 10 years before ceasing screening, with the most recent test occurring within the past 5 years). Once screening is discontinued it should not resume for any reason, even if a woman reports having a new sexual partner. Women Aged Older Than 65 Years With a History of CIN2, CIN3, or Adenocarcinoma In Situ: Following spontaneous regression or appropriate management of CIN2, CIN3, or adenocarcinoma in situ, routine screening should continue for at least 20 years (even if this extends screening past age 65 years). Women Who Have Undergone Hysterectomy and Have No History of CIN2+: Women at any age following a hysterectomy with removal of the cervix who have no history of CIN2+ should not be screened for vaginal cancer using any modality. Evidence of adequate negative prior screening is not required. Once screening is discontinued, it should not resume for any reason, including a woman’s report of having a new sexual partner. Screening Following Vaccination: Looking to the Future: Recommended screening practices should not change on the basis of HPV vaccination status.
American Academy of Family Physicians (AAFP)^189^ | 2012 | Endorses the 2012 USPSTF recommendation (see Section II).
American College of Obstetrics and Gynecologists (ACOG)^190^ | 2012 | The following recommendations are based on good and consistent scientific evidence (Level A):; - Cervical cancer screening should begin at age 21 years. Women younger than age 21 years should not be screened regardless of the age of sexual initiation or the presence of other behavior-related risk factors.; - Women aged 21–29 years should be tested with cervical cytology alone, and screening should be performed every 3 years. Co-testing should not be performed in women younger than 30 years.; - For women aged 30–65 years, co-testing with cytology and HPV testing every 5 years is preferred.; - In women aged 30–65 years, screening with cytology alone every 3 years is acceptable. Annual screening should not be performed.; - Women who have a history of cervical cancer, have HIV infection, are immunocompromised, or were exposed to diethylstilbestrol in utero should not follow routine screening guidelines.; - Both liquid-based and conventional methods of cervical cytology collection are acceptable for screening.; - In women who have had a hysterectomy with removal of the cervix (total hysterectomy) and have never had CIN 2 or higher, routine cytology screening and HPV testing should be discontinued and not restarted for any reason.; - Screening by any modality should be discontinued after age 65 years in women with evidence of adequate negative prior screening results and no history of CIN 2 or higher. Adequate negative prior screening results are defined as three consecutive negative cytology results or two consecutive negative co-test results within the previous 10 years, with the most recent test performed within the past 5 years.; The following recommendations are based on limited and inconsistent scientific evidence (Level B):; - Women with ASC-US cytology and negative HPV co-testing results have a very low risk of CIN 3 and should continue with routine screening as indicated for their age.; - Women with a history of CIN 2, CIN 3, or adenocarcinoma in situ should continue to undergo routine age-based screening for 20 years after the initial posttreatment surveillance period, even if it requires that screening continue past age 65 years.; - Women should continue to be screened if they have had a total hysterectomy and have a history of CIN 2 or higher in the past 20 years or cervical cancer ever. Continued screening for 20 years is recommended in women who still have a cervix and a history of CIN 2 or higher. Therefore, screening with cytology alone every 3 years for 20 years after the initial post treatment surveillance period seems reasonable for women with a hysterectomy.; - Women with negative cytology and positive HPV co-testing results who are aged 30 years and older should be managed in one of two ways:; 1. Repeat co-testing in 12 months. If the repeat cervical cytology test result is LSIL or higher or the HPV test result is still positive; the patient should be referred for colposcopy. Otherwise, the patient should return to routine screening (see Figure 1 in the original guideline document).; 2. Immediate HPV genotype-specific testing for HPV-16 alone or HPV-16/18 should be performed. Women with positive results from tests for HPV-16 alone or HPV-16/18 should be referred directly for colposcopy. Women with negative results from tests for HPV-16 or HPV-16/18 should be co-tested in 12 months, with management of results as described (see Figure 2 in the original guideline document).; The following recommendations are based primarily on consensus and expert opinion (Level C):; - Women who have received the HPV vaccine should be screened according to the same guidelines as women who have not been vaccinated.

Abbreviations: ASC-US = atypical squamous cells of undetermined significance; CC = conventional cytology; CIN = cervical intraepithelis neoplasia; HIV = human immunodeficiency virus; HPV = human papillomavirus; HSIL = high-grade squamous intraepithelial lesions; LBC = liquid-based cytology; LSIL = low-grade squamous intraepithelial lesion