# Appendix A Detailed Methods

## Synthesized Literature Search Strategies

### CDSR

#1 (cervical or cervix):ti,ab,kw near/3 (screen* or detect*):ti,ab,kw
#2 “liquid based cytology”:ti,ab,kw
#3 (papillomavirus or “papilloma virus” or hpv):ti,ab,kw near/3 (test* or screen* or detect*):ti,ab,kw
#4 (papillomavirus or “papilloma virus” or hpv):ti,ab,kw near/3 vaccin*:ti,ab,kw
#5 (or #1-#4) Publication Year from 2010 to 2015, in Cochrane Reviews (Reviews and Protocols)

### DARE

Line | Search
1 | (((cervical or cervix) ADJ3 (screen* or detect*))) IN DARE FROM 2010 TO 2015
2 | (“liquid based cytology”) IN DARE FROM 2010 TO 2015
3 | (papillomavirus or “papilloma virus” or hpv) ADJ3 (test* or screen or detect*) IN DARE FROM2010TO2015
4 | (papillomavirus or “papilloma virus” or hpv) ADJ3 vaccin*) IN DARE FROM 2010 TO 2015
5 | #1 OR #2 OR #3 OR #4

### HTA (via CRD)

Line | Search
1 | ((cervicalor cervix) ADJ3 (screen* or detect*)) IN HTAFROM 2010 TO 2015
2 | (“liquid based cytology”) IN HTA FROM 2010 TO 2015
3 | ((papillomavirus or “papilloma virus” or hpv) ADJ3 (test* or detect*)) IN HTAFROM 2010 TO 2015
4 | ((papillomavirus or “papilloma virus” or hpv) ADJ3 vaccin*) IN HTAFROM 2010 TO 2015
5 | #1 OR #2 OR #3 OR #4

### Medline

Database: Ovid MEDLINE(R) <1946 to February Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <February 24, 2015>, Ovid MEDLINE(R) Daily Update <February 15, 2017>

Search Strategy:

--------------------------------------------------------------------------------

1. Cervical Intraepithelial Neoplasia/ ()
2. “Squamous Intraepithelial Lesions of the Cervix”/ ()
3. Uterine Cervical Neoplasms/ ()
4. Uterine Cervical Dysplasia/ ()
5. Papillomaviridae/ ()
6. Papillomavirus Infections/ ()
7. Alphapapillomavirus/ ()
8. Human papillomavirus 16/()
9. Human papillomavirus 18/()
10. Human papillomavirus 31/()
11. or/1–10 ()
12. Mass screening/ ()
13. Vaginal Smears/()
14. Papanicolaou Test/ ()
15. DNA Probes, HPV/()
16. Human Papillomavirus DNA Tests/ ()
17. screen$.ti,ab. ()
18. vaginal smear$.ti,ab. ()
19. (papanicolauorpapanicolaou).ti,ab. ()
20. pap.ti,ab. ()
21. cervical smear$.ti,ab. ()
22. or/12–21 ()
23. 11 and 22 ()
24. ((cervical or cervix) adj3 (screen$ or detect$)).ti,ab. ()
25. liquid based cytology.ti,ab. ()
26. ((papillomavirus or papilloma virus) adj3 (test$ or screen$ or detect$)).ti,ab. ()
27. (hpv adj3 (test$ or screen$ or detect$)).ti,ab. ()
28. 23 or 24 or 25 or 26 or 27 ()
29. Papillomavirus Vaccines/()
30. ((Papillomavirus or papilloma virus) adj3 vaccin$).ti,ab. ()
31. (hpv adj3 vaccin$).ti,ab. ()
32. 29 or 30 or 31 ()
33. 28 or 32 ()
34. limit 33 to (english language and yr=“2010 -Current”) ()
35. limit 34 to systematic reviews ()
36. remove duplicates from 35 ()
37. Animals/ not (Humans/ and Animals/) ()
38. 36 not 37 ()

### PubMed, publisher-supplied

Search | Query
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #7 AND systematic[sb] AND publisher[sb] AND English[Language] AND (“2010”[Date - Publication]: “3000”[Date - Publication])
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search hpv[tiab] AND vaccin*[tiab]
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search hpv[tiab] AND (test*[tiab] OR screen*[tiab] OR detect*[tiab])
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (papillomavirus[tiab] or “papilloma virus “[tiab]) AND (vaccin*[tiab])
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (papillomavirus[tiab] or “papilloma virus”[tiab]) AND (test*[tiab] OR screen*[tiab] OR detect*[tiab])
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “liquid based cytology”[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (cervical[tiab] OR cervix[tiab]) AND (screen*[tiab] OR detect*[tiab])

## Primary Literature Search Strategies

### CENTRAL

#1 hpv*:ti,ab,kw near (test* or detect* or screen* or smear* or assay*):ti,ab,kw
#2 papillomavir*:ti,ab,kw near (test* or detect* or screen* or smear* or assay*):ti,ab,kw
#3 (papilloma* next vir*):ti,ab,kw near (test* or detect* or screen* or smear* or assay*):ti,ab,kw
#4 #1 or #2 or #3
#5 “hybrid capture”:ti,ab,kw
#6 (HC2 or “HC 2” orHCII or “HC II”):ti,ab,kw
#7 cobas:ti,ab,kw
#8 APTIMA:ti,ab,kw
#9 Cervista:ti,ab,kw
#10 digene:ti,ab,kw
#11 amplicor:ti,ab,kw
#12 pcr:ti,ab,kw
#13 (polymerase next chain next reaction*):ti,ab,kw
#14 “linear array”:ti,ab,kw
#15 #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14
#16 (hpv* or papillomavir* or (papilloma nextvir*)):ti,ab,kw
#17 #15and#16
#18 #4 or #17 Publication Year from 2011 to 2017, in Trials

### MEDLINE

Database: Ovid MEDLINE(R), Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily Update

Search Strategy:

--------------------------------------------------------------------------------

1. Papillomavirus Infections/di [Diagnosis] ()
2. Papillomaviridae/cy, ip [Cytology, Isolation & Purification] ()
3. Alphapapillomavirus/ip [Isolation & Purification] ()
4. Human papillomavirus 16/ip [Isolation & Purification] ()
5. Human papillomavirus 18/ip [Isolation & Purification] ()
6. DNA Probes, HPV/ ()
7. Human Papillomavirus DNA Tests/ ()
8. (hpv$ adj5 (test$ or detect$ or screen$ or smear$ or assay$)).ti,ab. ()
9. (papillomavir$ adj5 (test$ or detect$ or screen$ or smear$ or assay$)).ti,ab. ()
10. (papilloma vir$ adj5 (test$ or detect$ or screen$ or smear$ or assay$)).ti,ab. ()
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 ()
12. Papillomavirus Infections/ ()
13. Papillomaviridae/ ()
14. Alphapapillomavirus/ ()
15. Human papillomavirus 16/ ()
16. Human papillomavirus 18/ ()
17. Human papillomavirus 31/ ()
18. 12 or 13 or 14 or 15 or 16 or 17 ()
19. Mass screening/ ()
20. Early detection of cancer/ ()
21. Vaginal smears/ ()
22. Papanicolaou Test/ ()
23. “Diagnostic Techniques, Obstetrical and Gynecological”/ ()
24. Cytological Techniques/ ()
25. Histocytological Preparation Techniques/ ()
26. Cytodiagnosis/ ()
27. 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 ()
28. 18 and 27 ()
29. Hybrid Capture.ti,ab. ()
30. HC2.ti,ab. ()
31. hc 2.ti,ab. ()
32. hcII.ti,ab. ()
33. hc II.ti,ab. ()
34. cobas.ti,ab. ()
35. APTIMA.ti,ab. ()
36. Cervista.ti,ab. ()
37. digene.ti,ab. ()
38. amplicor.ti,ab. ()
39. polymerase chain reaction/ ()
40. Reverse Transcriptase Polymerase Chain Reaction/ ()
41. polymerase chain reaction$.ti. ()
42. pcr.ti. ()
43. linear array.ti,ab. ()
44. 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 ()
45. papillomavir$.ti,ab,hw. ()
46. papilloma vir$.ti,ab,hw. ()
47. hpv$.ti,ab,hw. ()
48. 45 or 46 or 47 ()
49. 44 and 48 ()
50. 11 or 28 or 49 ()
51. limit 50 to systematic reviews ()
52. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
53. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
54. Random$.ti,ab. ()
55. control groups/ or double-blind method/ or single-blind method/ ()
56. clinical trial$.ti,ab. ()
57. controlled trial$.ti,ab. ()
58. meta analy$.ti,ab. ()
59. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/ ()
60. cohort.ti,ab. ()
61. longitudinal.ti,ab. ()
62. (follow up or followup).ti,ab. ()
63. Registries/ ()
64. (registr$ or register$).ti,ab. ()
65. 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 ()
66. 50 and 65 ()
67. 51 or 66 ()
68. Animal/ not (Animal/ and Human/) ()
69. 67 not 68 ()
70. Male/ not (Female/ and Male/) ()
71. 69 not 70 ()
72. limit 71 to (english language and yr=“2011 -Current”) ()
73. remove duplicates from 72 ()

### PsycInfo (via Ovid)

Database: PsycINFO

Search Strategy:

------------------------------------------------------------

1. human papillomavirus/ ()
2. testing/ ()
3. Cancer Screening/ ()
4. Screening/ ()
5. exp Screening Tests/ ()
6. 2 or 3 or 4 or 5 ()
7. 1 and 6 ()
8. (hpv$ adj5 (test$ or detect$ or screen$ or smear$ or assay$)).ti,ab. ()
9. (papillomavir$ adj5 (test$ or detect$ or screen$ or smear$ or assay$)).ti,ab. ()
10. (papilloma vir$ adj5 (test$ or detect$ or screen$ or smear$ or assay$)).ti,ab. ()
11. 7 or 8 or 9 or 10 ()
12. limit 11 to (english language and yr=“2011 -Current”) ()

### PubMed

Search | Query
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#7) AND English[Language]) AND ("2011/01/01"[Date - Publication]: “3000”[Date - Publication])
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #6 AND publisher[sb]
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND (systematic[sb] OR random*[tiab] OR trial*[tiab] OR cohort*[tiab] OR longitudinal[tiab] OR follow up[tiab] OR followup[tiab] OR retrospective[tiab] OR prospective[tiab] OR register*[tiab] OR registr*[tiab])
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #4
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search HPV [tiab] OR papillomavir* [tiab] OR papilloma vir*[tiab] OR “hybrid capture*” [tiab] OR HC2 [tiab] OR HCII [tiab] OR “HC 2” [tiab] OR “HC II” [tiab] OR cobas[tiab] OR aptima[tiab] OR cervista[tiab] OR digene[tiab] OR amplicor[tiab] OR PCR[tiab] OR polymerase chain reaction*[tiab] OR “linear array”[tiab] OR ((viral [tiab] OR virolog* [tiab]) AND (DNA [tiab]))
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #2
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (cancer* [tiab] OR carcinoma OR adenocarcinoma OR neoplas* [tiab] OR dysplas* [tiab] OR lesion*[tiab] OR dyskaryos* [tiab] OR squamous [tiab] OR CIN [tiab] OR CINII* [tiab] OR CIN2* [tiab] OR CINIII* [tiab] OR CIN3* [tiab] OR SIL [tiab] OR HSIL [tiab] OR H-SIL [tiab] OR LSIL [tiab] OR L-SIL [tiab] OR ASCUS [tiab] OR AS-CUS [tiab])
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (cervix [tiab] OR cervical [tiab] OR cervico* [tiab])

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | KQs 1, 2: Studies targeting cervical cancer screening or development of cervical cancer over time | KQs 1, 2: Use of HPV or cytology testing for posttreatment surveillance or other purposes
Population | KQs 1, 2: Women age ≥21 years who have a cervix | KQs 1, 2:; - High-risk populations (e.g., women who are HIV-positive); - Women without a cervix; - Women who have had a hysterectomy with the removal of the cervix; - Pregnant women
Interventions | KQs 1, 2:; - Primary HPV screening strategies^*,†^:; ○ Alone; ○ In combination with cytology (cotesting); ○ In combination with cytology triage of positive HPV (reflex cytology); - Self- or clinician-collected HPV specimens, collected at home or in a clinic | KQs 1, 2: Nonprimary HPV screening strategies (e.g., primary cytology-based screening, cytology with HPV triage [reflex HPV])
Comparators | KQs 1, 2: Comparative effectiveness (i.e., cytology-based [conventional or liquid-based] or other primary HPV screening strategies [cotesting, reflex cytology, or reflex HPV]) | KQs 1, 2: Comparative effectiveness of cytology-based screening strategies (liquid-based cytology vs. conventional cytology alone); cytology with HPV triage vs. cytology-based screening strategies
Outcomes | KQ 1:; - Early detection of disease (CIN3+); - Invasive cancer; - Mortality (all-cause or cervical cancer); - Improved quality of life; The following hierarchy^108^ of outcomes for new cervical cancer screening methods will be used:; - Rank 1: Cervical cancer mortality (quality-adjusted life-years gained); - Rank 2: Cervical cancer morbidity/stage IB+ incidence; - Rank 3: Cervical cancer incidence (including microinvasive); - Rank 4: Reduced CIN3+ incidence or p16 immunohistochemistry-associated high-grade squamous intraepithelial lesion incidence^109^; - Rank 5: Increased detection of CIN3+ (or CIN2+); - More CIN3+ detection overall (cumulative CIN3+); - More CIN2+ detection followed by less CIN3+ detection at subsequent screening (note: CIN2+ detection may include overdiagnosis); - Rank 6: Increased test positivity with increased, similar, or minimally reduced positive predictive value; KQ 2:; - Rates of false-positive and false-negative screening test results; - Rates of colposcopy and/or biopsy; - Labeling; - Stigma (e.g., sexually transmitted infection); - Partner discord; - Psychological distress (e.g., anxiety); - Reduced quality of life
Study Designs | KQs 1, 2:; - Individual patient data meta-analyses and systematic reviews; - Randomized, controlled trials; controlled clinical trials; - Cohort studies, including patient registries | KQs 1, 2:; - Case-control studies; - Case reports; - Case series; - Narrative reviews; - Editorials
Setting | KQs 1, 2: Primary care (e.g., internal medicine, family medicine, obstetrics/gynecology) or other settings generalizable to primary care (e.g., university-based health clinics, mobile clinics, sexually transmitted infection clinics, family planning clinics) | KQs 1, 2:; - Community/university research laboratories or other nonmedical centers; - Correctional facilities; - Worksites; - Inpatient/residential facilities
Country | KQs 1, 2: Countries with cervical cancer screening programs comparable to those of the United States and categorized as “Very High” or equivalent on the 2014 Human Development Index (as defined by the United Nations Development Programme) | KQs 1, 2: Countries not categorized as “Very High” on the Human Development Index or not applicable to U.S. clinical settings or populations
Language | KQs 1, 2: English only | KQs 1, 2: Non-English publications
Quality | KQs 1, 2: Fair- or good-quality, according to USPSTF design-specific criteria | KQs 1, 2: Poor-quality, according to USPSTF design-specific criteria

* Primary screening strategies refer to the use of a certain type of test in the first step of a screening approach.

† HPV tests approved by the U.S. Food and Drug Administration include: the Hybrid Capture 2 High-Risk HPV DNA Test (Digene Corp., Gaithersburg, MD), cobas HPV Test (Roche Molecular Systems, Inc., Pleasanton, CA), APTIMA® HPV Assay (E6/E7 mRNA) (Gen-Probe Inc., San Diego, CA), Cervista™ HPV 16/18 (Hologic, Inc., Madison, WI), and Cervista™ HR HPV.

Abbreviations: CIN = cervical intraepithelial neoplasia; HPV = human papillomavirus; KQ = Key Question; USPSTF = U.S. Preventive Services Task Force

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized and nonrandomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^110^ | - Was there adequate participation in the study by eligible/invited persons?; - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was there a difference in attrition between groups after randomization?; - Was the reading (interpretation) of the pathology results adequate?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there risk of contamination?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?
Cohort studies, adapted from the Newcastle-Ottawa Scale^111^ | - Was there representativeness of the exposed cohort?; - Was the non-exposed systematic selected?; - Was the ascertainment of exposure reported?; - Were eligibility criteria specified?; - Were groups similar at baseline?; - Was the reading (interpretation) of the pathology results adequate?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was followup long enough for outcomes to occur?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there adjustment for confounders?; - Was there acceptable followup?

Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Figure 1 Literature Flow Diagram

Abbreviations: KQ = Key Question

Appendix A Figure 1 displays the literature search results and article flow for the review. A total of 5,175 articles were identified through database searching and 57 through selected systematic evidence reviews and other sources. 2,972 articles were screened and 163 full-text articles were assessed for eligibility. 29 articles (11 studies) were included for KQ1. 31 articles (12 studies) were included for KQ2.