# References

1 National Cancer Institute. Ovarian Epithelial, Fallopian Tube, and Primary Peritoneal Cancer Treatment (PDQ®)–Health Professional Version. https://www.cancer.gov/types/ovarian/hp/ovarian-epithelial-treatment-pdq. Accessed November 17, 2016.
2 Institute of Medicine, Committee on the State of the Science in Ovarian Cancer Research, Board on Health Care Services, . Ovarian Cancers: Evolving Paradigms in Research and Care. Washington (DC): National Academies Press (US); 2016. PMID: 2725300027253000.
3 Prat J, FIGO Committee on Gynecologic Oncology. Staging classification for cancer of the ovary, fallopian tube, and peritoneum. Int J Gynaecol Obstet. 2014;124(1):1-5. PMID: 24219974. http://dx.doi.org/10.1016/j.ijgo.2013.10.001 24219974
4 National Cancer Institute. Staging. https://www.cancer.gov/about-cancer/diagnosis-staging/staging. Accessed November 2, 2016.
5 Jayson GC, Kohn EC, Kitchener HC, . Ovarian cancer. Lancet. 2014;384(9951):1376-88. PMID: 24767708. http://dx.doi.org/10.1016/S0140-6736(13)62146-7 24767708
6 Kurman RJ, Shih Ie M. The Dualistic Model of Ovarian Carcinogenesis: Revisited, Revised, and Expanded. Am J Pathol. 2016;186(4):733-47. PMID: 27012190. http://dx.doi.org/s10.1016/j.ajpath.2015.11.011 27012190
7 McCluggage WG. Morphological subtypes of ovarian carcinoma: a review with emphasis on new developments and pathogenesis. Pathology. 2011;43(5):420-32. http://dx.doi.org/10.1097/PAT.0b013e328348a6e7 21716157
8 Howlader N, Noone AM, Krapcho M, . SEER cancer statistics review, 1975–2013. http://seer.cancer.gov/csr/1975_2013/. Accessed November 6, 2016.
9 American Cancer Society. Cancer Facts & Figures 2017. Atlanta: American Cancer Society. 2017.
10 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999-2014 Incidence and Mortality Web-based Report. www.cdc.gov/uscs. Accessed June 28, 2017.
11 National Cancer Institute. Cancer Stat Facts: Ovarian Cancer. https://seer.cancer.gov/statfacts/html/ovary.html. Accessed June 28, 2017.
12 Howlader N, Noone AM, Krapcho M, . SEER Cancer Statistics Review, 1975-2014. https://seer.cancer.gov/csr/1975_2014/. Accessed June 28, 2017.
13 National Cancer Institute. NCI Dictionary of Cancer Terms. https://www.cancer.gov/publications/dictionaries/cancer-terms. Accessed November 2, 2016.
14 Koshiyama M, Matsumura N, Konishi I. Recent concepts of ovarian carcinogenesis: type I and type II. Biomed Res Int 2014;934261. PMID: 24868556. http://dx.doi.org/10.1155/2014/934261 24868556
15 Reade CJ, McVey RM, Tone AA, . The fallopian tube as the origin of high grade serous ovarian cancer: review of a paradigm shift. J Obstet Gynaecol Can. 2014;36(2):133-40. PMID: 24518912. http://dx.doi.org/10.1016/S1701-2163(15)30659-9 24518912
16 Kurman RJ, Shih Ie M Molecular pathogenesis and extraovarian origin of epithelial ovarian cancer--shifting the paradigm. Hum Pathol. 2011;42(7):918-31. PMID: 21683865. http://dx.doi.org/10.1016/j.humpath.2011.03.003 21683865
17 North American Association of Central Cancer Registries. Average-annual age-adjusted cancer incidence rates by race/ethnicity, sex, and registry for selected sites. http://www.naaccr.org/DataandPublications/CINAPubs.aspx. Accessed November 2, 2016.
18 Permuth-Wey J, Besharat A, Sellers T Epidemiology of ovarian cancer: An update. In: Advances in diagnosis and management of ovarian cancer. Farghaly SA, editor. New York: Springer Science and Business Media; 2014. PMID: None.
19 Wentzensen N, Poole EM, Trabert B, . Ovarian Cancer Risk Factors by Histologic Subtype: An Analysis From the Ovarian Cancer Cohort Consortium. J Clin Oncol. 2016;34(24):2888-98. PMID: 27325851. http://dx.doi.org/10.1200/JCO.2016.66.8178 27325851
20 Shulman LP, Dungan JS Cancer genetics: risks and mechanisms of cancer in women with inherited susceptibility to epithelial ovarian cancer. Cancer Treat Res. 2010;156:69-85. PMID: 20811826. http://dx.doi.org/10.1007/978-1-4419-6518-9_6 20811826
21 Lu KH, Daniels M Endometrial and ovarian cancer in women with Lynch syndrome: update in screening and prevention. Fam Cancer. 2013;12(2):273-7. PMID: 23765559. http://dx.doi.org/10.1007/s10689-013-9664-5 23765559
22 Kempers MJ, Kuiper RP, Ockeloen CW, . Risk of colorectal and endometrial cancers in EPCAM deletion-positive Lynch syndrome: a cohort study. Lancet Oncol. 2011;12(1):49-55. PMID: 21145788. http://dx.doi.org/10.1016/S1470-2045(10)70265-5 21145788
23 Hendriks YM, de Jong AE, Morreau H, . Diagnostic approach and management of Lynch syndrome (hereditary nonpolyposis colorectal carcinoma): a guide for clinicians. CA Cancer J Clin. 2006;56(4):213-25. PMID: 16870997. http://dx.doi.org/10.3322/canjclin.56.4.213 16870997
24 Hampel H, Bennett RL, Buchanan A, . A practice guideline from the American College of Medical Genetics and Genomics and the National Society of Genetic Counselors: referral indications for cancer predisposition assessment. Genet Med. 2015;17(1):70-87. PMID: 25394175. http://dx.doi.org/10.1038/gim.2014.147 25394175
25 Song H, Ramus SJ, Tyrer J, . A genome-wide association study identifies a new ovarian cancer susceptibility locus on 9p22.2. Nat Genet. 2009;41(9):996-1000. PMID: 19648919. http://dx.doi.org/10.1038/ng.424 19648919
26 Pharoah PD, Tsai YY, Ramus SJ, . GWAS meta-analysis and replication identifies three new susceptibility loci for ovarian cancer. Nat Genet. 2013;45(4):362-70, 70e1-2. PMID: 23535730. http://dx.doi.org/10.1038/ng.2564 23535730
27 Permuth-Wey J, Lawrenson K, Shen HC, . Identification and molecular characterization of a new ovarian cancer susceptibility locus at 17q21.31. Nat Commun. 2013;4:1627. PMID: 23535648. http://dx.doi.org/10.1038/ncomms2613 23535648
28 Kuchenbaecker KB, Ramus SJ, Tyrer J, . Identification of six new susceptibility loci for invasive epithelial ovarian cancer. Nat Genet. 2015;47(2):164-71. PMID: 25581431. http://dx.doi.org/10.1038/ng.3185 25581431
29 Bolton KL, Tyrer J, Song H, . Common variants at 19p13 are associated with susceptibility to ovarian cancer. Nat Genet. 2010;42(10):880-4. PMID: 20852633. http://dx.doi.org/10.1038/ng.666 20852633
30 Bojesen SE, Pooley KA, Johnatty SE, . Multiple independent variants at the TERT locus are associated with telomere length and risks of breast and ovarian cancer. Nat Genet. 2013;45(4):371-84, 84e1-2. PMID: 23535731. http://dx.doi.org/10.1038/ng.2566 23535731
31 National Institute for Health and Care Excellence (NICE). Clinical guideline [CG164]: Familial breast cancer: classification, care and managing breast cancer and related risks in people with a family history of breast cancer. 2013. PMID: None.
32 Daly MB, Pilarski R, Axilbund JE, . Genetic/Familial High-Risk Assessment: Breast and Ovarian, Version 2.2015. J Natl Compr Canc Netw. 2016;14(2):153-62. PMID: 26850485. http://dx.doi.org/10.6004/jnccn.2016.0018 26850485
33 Moyer VA, Force USPST. Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer in women: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;160(4):271-81. PMID: 24366376. http://dx.doi.org/10.7326/M13-2747 24366376
34 Collaborative Group on Epidemiological Studies of Ovarian Cancer, Beral V, Doll R, . Ovarian cancer and oral contraceptives: collaborative reanalysis of data from 45 epidemiological studies including 23,257 women with ovarian cancer and 87,303 controls. Lancet. 2008;371(9609):303-14. PMID: 18294997. http://dx.doi.org/10.1016/S0140-6736(08)60167-1 18294997
35 Whittemore AS, Harris R, Itnyre J Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136(10):1184-203. PMID: 1476141.1476141
36 Fortner RT, Ose J, Merritt MA, . Reproductive and hormone-related risk factors for epithelial ovarian cancer by histologic pathways, invasiveness and histologic subtypes: Results from the EPIC cohort. Int J Cancer. 2015;137(5):1196-208. PMID: 25656413. http://dx.doi.org/10.1002/ijc.29471 25656413
37 Gates MA, Rosner BA, Hecht JL, . Risk factors for epithelial ovarian cancer by histologic subtype. Am J Epidemiol. 2010;171(1):45-53. PMID: 19910378. http://dx.doi.org/10.1093/aje/kwp314 19910378
38 Merritt MA, De Pari M, Vitonis AF, . Reproductive characteristics in relation to ovarian cancer risk by histologic pathways. Hum Reprod. 2013;28(5):1406-17. PMID: 23315066. http://dx.doi.org/10.1093/humrep/des466 23315066
39 Yang HP, Trabert B, Murphy MA, . Ovarian cancer risk factors by histologic subtypes in the NIH-AARP Diet and Health Study. Int J Cancer. 2012;131(4):938-48. PMID: 21960414. http://dx.doi.org/10.1002/ijc.26469 21960414
40 Setiawan VW, Yang HP, Pike MC, . Type I and II endometrial cancers: have they different risk factors? J Clin Oncol. 2013;31(20):2607-18. PMID: 23733771. http://dx.doi.org/10.1200/JCO.2012.48.2596 23733771
41 Hartge P, Whittemore AS, Itnyre J, . Rates and risks of ovarian cancer in subgroups of white women in the United States. The Collaborative Ovarian Cancer Group. Obstet Gynecol. 1994;84(5):760-4. PMID: 7936508.7936508
42 Rosner BA, Colditz GA, Webb PM, . Mathematical models of ovarian cancer incidence. Epidemiology. 2005;16(4):508-15. PMID: 15951669.15951669
43 Pfeiffer RM, Park Y, Kreimer AR, . Risk prediction for breast, endometrial, and ovarian cancer in white women aged 50 y or older: derivation and validation from population-based cohort studies. PLoS Med. 2013;10(7):e1001492. PMID: 23935463. http://dx.doi.org/10.1371/journal.pmed.1001492 23935463
44 Li K, Husing A, Fortner RT, . An epidemiologic risk prediction model for ovarian cancer in Europe: the EPIC study. Br J Cancer. 2015;112(7):1257-65. PMID: 25742479. http://dx.doi.org/10.1038/bjc.2015.22 25742479
45 Domchek SM, Friebel TM, Singer CF, . Association of risk-reducing surgery in BRCA1 or BRCA2 mutation carriers with cancer risk and mortality. JAMA. 2010;304(9):967-75. PMID: 20810374. http://dx.doi.org/10.1001/jama.2010.1237 20810374
46 Jacoby VL, Grady D, Wactawski-Wende J, . Oophorectomy vs ovarian conservation with hysterectomy: cardiovascular disease, hip fracture, and cancer in the Women's Health Initiative Observational Study. Arch Intern Med. 2011;171(8):760-8. PMID: 21518944. http://dx.doi.org/10.1001/archinternmed.2011.121 21518944
47 Parker WH, Broder MS, Chang E, . Ovarian conservation at the time of hysterectomy and long-term health outcomes in the nurses' health study. Obstet Gynecol. 2009;113(5):1027-37. PMID: 19384117. http://dx.doi.org/10.1097/AOG.0b013e3181a11c64 19384117
48 Finch AP, Lubinski J, Moller P, . Impact of oophorectomy on cancer incidence and mortality in women with a BRCA1 or BRCA2 mutation. J Clin Oncol. 2014;32(15):1547-53. PMID: 24567435. http://dx.doi.org/10.1200/JCO.2013.53.2820 24567435
49 Falconer H, Yin L, Gronberg H, . Ovarian cancer risk after salpingectomy: a nationwide population-based study. J Natl Cancer Inst. 2015;107(2). PMID: 25628372 http://dx.doi.org/10.1093/jnci/dju410 25628372
50 Guldberg R, Wehberg S, Skovlund CW, . Salpingectomy as standard at hysterectomy? A Danish cohort study, 1977-2010. BMJ Open. 2013;3(6). PMID: 23794553 http://dx.doi.org/10.1136/bmjopen-2013-002845 23794553
51 Ammerican College on Obstetricians and Gynecologists (ACOG) Committee on Gynecologic Practice. Committee opinion no. 620: Salpingectomy for ovarian cancer prevention. Obstet Gynecol. 2015;125(1):279-81. PMID: 25560145. http://dx.doi.org/10.1097/01.AOG.0000459871.88564.09 25560145
52 Society of Gynecologic Oncology (SGO). SGO clinical practice statement: Salpingectomy for ovarian cancer prevention. https://www.sgo.org/clinical-practice/guidelines/sgo-clinical-practice-statement-salpingectomy-for-ovarian-cancer-prevention. Accessed November 23, 2016.
53 Rice MS, Murphy MA, Tworoger SS Tubal ligation, hysterectomy and ovarian cancer: A meta-analysis. J Ovarian Res. 2012;5(1):13. PMID: 22587442. http://dx.doi.org/10.1186/1757-2215-5-13 22587442
54 Walker JL, Powell CB, Chen LM, . Society of Gynecologic Oncology recommendations for the prevention of ovarian cancer. Cancer. 2015;121(13):2108-20. PMID: 25820366. http://dx.doi.org/10.1002/cncr.29321 25820366
55 Havrilesky LJ, Gierisch JM, Moorman PG, . Oral Contraceptive Use for the Primary Prevention of Ovarian Cancer. Evidence Report/Technology Assessment No. 212. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.). AHRQ Publication No 13-E002-EF PMID: None.
56 Bristow RE, Chang J, Ziogas A, . Adherence to treatment guidelines for ovarian cancer as a measure of quality care. Obstet Gynecol. 2013;121(6):1226-34. PMID: 23812456. http://dx.doi.org/10.1097/AOG.0b013e3182922a17 23812456
57 Bristow RE, Chang J, Ziogas A, . High-volume ovarian cancer care: survival impact and disparities in access for advanced-stage disease. Gynecol Oncol. 2014;132(2):403-10. PMID: 24361578. http://dx.doi.org/10.1016/j.ygyno.2013.12.017 24361578
58 Chan JK, Kapp DS, Shin JY, . Influence of the gynecologic oncologist on the survival of ovarian cancer patients. Obstet Gynecol. 2007;109(6):1342-50. PMID: 17540806. http://dx.doi.org/10.1097/01.AOG.0000265207.27755.28 17540806
59 Goff BA, Mandel LS, Melancon CH, . Frequency of symptoms of ovarian cancer in women presenting to primary care clinics. JAMA. 2004;291(22):2705-12. PMID: 15187051. http://dx.doi.org/10.1001/jama.291.22.2705 15187051
60 Goff BA, Mandel LS, Drescher CW, . Development of an ovarian cancer symptom index: possibilities for earlier detection. Cancer. 2007;109(2):221-7. PMID: 17154394. http://dx.doi.org/10.1002/cncr.22371 17154394
61 Ebell MH, Culp MB, Radke TJ A Systematic Review of Symptoms for the Diagnosis of Ovarian Cancer. Am J Prev Med. 2016;50(3):384-94. PMID: 26541098. http://dx.doi.org/10.1016/j.amepre.2015.09.023 26541098
62 Bast RC, Jr., Skates S, Lokshin A, . Differential diagnosis of a pelvic mass: improved algorithms and novel biomarkers. International Journal of Gynecological Cancer. 2012;22 Suppl 1:S5-8. http://dx.doi.org/10.1097/IGC.0b013e318251c97d 22543921
63 Jacobs I, Oram D, Fairbanks J, . A risk of malignancy index incorporating CA 125, ultrasound and menopausal status for the accurate preoperative diagnosis of ovarian cancer. British journal of obstetrics and gynaecology. 1990;97(10):922-9. PMID: 2223684.2223684
64 Moore RG, McMeekin DS, Brown AK, . A novel multiple marker bioassay utilizing HE4 and CA125 for the prediction of ovarian cancer in patients with a pelvic mass. Gynecol Oncol. 2009;112(1):40-6. http://dx.doi.org/10.1016/j.ygyno.2008.08.031 18851871
65 Skates SJ, Xu FJ, Yu YH, . Toward an optimal algorithm for ovarian cancer screening with longitudinal tumor markers. Cancer. 1995;76(10 Suppl):2004-10. PMID: 8634992.8634992
66 Manegold-Brauer G, Bellin AK, Tercanli S, . The special role of ultrasound for screening, staging and surveillance of malignant ovarian tumors: distinction from other methods of diagnostic imaging. Arch Gynecol Obstet. 2014;289(3):491-8. PMID: 24253338. http://dx.doi.org/10.1007/s00404-013-3081-8 24253338
67 Woolas RP, Xu FJ, Jacobs IJ, . Elevation of multiple serum markers in patients with stage I ovarian cancer. J Natl Cancer Inst. 1993;85(21):1748-51. PMID: 8411259.8411259
68 Menon U, Gentry-Maharaj A, Hallett R, . Sensitivity and specificity of multimodal and ultrasound screening for ovarian cancer, and stage distribution of detected cancers: results of the prevalence screen of the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Lancet Oncol. 2009;10(4):327-40. PMID: 19282241. http://dx.doi.org/10.1016/S1470-2045(09)70026-9 19282241
69 Stormo AR, Cooper CP, Hawkins NA, . Physician characteristics and beliefs associated with use of pelvic examinations in asymptomatic women. Prev Med. 2012;54(6):415-21. PMID: 22484240. http://dx.doi.org/10.1016/j.ypmed.2012.03.012 22484240
70 Doroudi M, Kramer B, Pinsky P The bimanual ovarian palpation examination in the Prostate, Lung, Colorectal and Ovarian cancer screening trial: Performance and complications. J Med Screen. 2016;0(0):1-3. PMID: 27903809. http://dx.doi.org/10.1177/0969141316680381 27903809
71 Qaseem A, Humphrey LL, Harris R, . Screening pelvic examination in adult women: a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2014;161(1):67-72. PMID: 24979451. http://dx.doi.org/10.7326/M14-0701 24979451
72 US Preventive Services Task Force. Screening for Gynecologic Conditions With Pelvic Examination: US Preventive Services Task Force Recommendation Statement. JAMA. 2017;317(9):947-53. PMID: None. http://dx.doi.org/10.1001/jama.2017.0807 28267862
73 American College of Obstetricians and Gynecologists (ACOG). The role of the obstetrician–gynecologist in the early detection of epithelial ovarian cancer. Committee Opinion No. 477. Obstet Gynecol. 2011;117:742-6. PMID: 21343791. http://dx.doi.org/10.1097/AOG.0b013e31821477db 21343791
74 Moyer VA, U. S. Preventive Services Task Force. Screening for ovarian cancer: U.S. Preventive Services Task Force reaffirmation recommendation statement.[Summary for patients in Ann Intern Med. 2012 Dec 18;157(12):I-56; PMID: 23362519]. Ann Intern Med. 2012;157(12):900-4. PMID: 22964825. http://dx.doi.org/10.7326/0003-4819-157-11-201212040-00539 22964825
75 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Ovarian Cancer. http://www.aafp.org/patient-care/clinical-recommendations/all/ovarian-cancer.html. Accessed November 17, 2016.
76 Smith RA, Brooks D, Cokkinides V, . Cancer screening in the United States, 2013: a review of current American Cancer Society guidelines, current issues in cancer screening, and new guidance on cervical cancer screening and lung cancer screening. CA Cancer J Clin. 2013;63(2):88-105. PMID: 23378235. http://dx.doi.org/10.3322/caac.21174 23378235
77 Smith RA, Andrews K, Brooks D, . Cancer screening in the United States, 2016: A review of current American Cancer Society guidelines and current issues in cancer screening. CA Cancer J Clin. 2016;66(2):96-114. http://dx.doi.org/10.3322/caac.21336 26797525
78 Pandharipande PV, Harvey HB, Javitt MC, . ACR Appropriateness Criteria® ovarian cancer screening. 2012. PMID: None.
79 Baldwin LM, Trivers KF, Matthews B, . Vignette-based study of ovarian cancer screening: do U.S. physicians report adhering to evidence-based recommendations?.[Erratum appears in Ann Intern Med. 2012 Jun 19;156(12):908]. Ann Intern Med. 2012;156(3):182-94. PMID: 22312138. http://dx.doi.org/10.7326/0003-4819-156-3-201202070-00006 22312138
80 Baldwin LM, Trivers KF, Andrilla CH, . Accuracy of ovarian and colon cancer risk assessments by U.S. physicians. J Gen Intern Med. 2014;29(5):741-9. PMID: 24519100. http://dx.doi.org/10.1007/s11606-014-2768-2 24519100
81 U.S. Food and Drug Administration. The FDA recommends against using screening tests for ovarian cancer screening: FDA Safety Communication. http://www.fda.gov/MedicalDevices/Safety/AlertsandNotices/ucm519413.htm. Accessed December 30, 2016.
82 Abcodia. Abcodia Statement on the ROCA Test for Ovarian Cancer Screening. https://www.rocatest.com/about-us/news-events/news-item/abcodia-statement-roca-test-ovarian-cancer-screening/. Accessed December 30, 2016.
83 Danforth KN, Im TM, Whitlock EP Addendum to Screening for Ovarian Cancer: Evidence Update for the U.S. Preventive Services Task Force Reaffirmation Recommendation Statement. AHRQ Publication No 12-05165-EF4 Rockville, MD: Agency for Healthcare Research and Quality: . April 2012. PMID: None.
84 Barton M, Lin K Screening for Ovarian Cancer: Evidence Update for the U.S. Preventive Services Task Force Reaffirmation Recommendation Statement. AHRQ publication no. 12-05165-EF3. Rockville, MD: Agency for Healthcare Research and Quality: . April 2012. PMID: None.
85 Nelson H, Westhoff C, Piepert J, . Screening for Ovarian Cancer: Brief Evidence Update. AHRQ Publication No 04-0542-B. Rockville, MD: Agency for Healthcare Research and Quality: May 2004. PMID: None.
86 Kaiser Permanente Southern California. Ovarian Cancer Screening Clinical Practice Guideline. Recommendations and Rationale. December 2014. PMID: None.
87 Reade CJ, Riva JJ, Busse JW, . Risks and benefits of screening asymptomatic women for ovarian cancer: a systematic review and meta-analysis. Gynecol Oncol. 2013;130(3):674-81. http://dx.doi.org/10.1016/j.ygyno.2013.06.029 23822892
88 Wallace BC, Small K, Brodley CE, ., editors. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. 2nd ACM SIGHIT International Health Informatics Symposium 2012. PMID: None.
89 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. PMID: 11306229. http://dx.doi.org/10.1016/S0749-3797(01)00261-6 11306229
90 Daya D, Cheung A, Khunamornpong S, . Tumors of the peritoneum: epithelial tumors of Müllerian type. in: RJ Kurman, ML Carcangiu, CS Herrington, RH Young (Eds.) In: WHO classification of tumors of female reproductive organs. 4th edn: International Agency for Research on Cancer, Lyon; 2014. p. 92-3. PMID: None.
91 Buys SS, Partridge E, Black A, . Effect of screening on ovarian cancer mortality: the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Randomized Controlled Trial. JAMA. 2011;305(22):2295-303. PMID: 21642681. http://dx.doi.org/10.1001/jama.2011.766 21642681
92 Jacobs IJ, Menon U, Ryan A, . Ovarian cancer screening and mortality in the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS): a randomised controlled trial. Lancet. 2016;387(10022):945-56. PMID: 26707054. http://dx.doi.org/10.1016/s0140-6736(15)01224-6 26707054
93 Menon U, Kalsi JK, Gentry-Maharaj A, . Reply to P.F. Pinsky, C.P. Crum, and M.W. McIntosh et al. J Clin Oncol. 2016;34(2):201-2. PMID: 26573079. http://dx.doi.org/10.1200/JCO.2015.64.1365 26573079
94 Schulz KF, Altman DG, Moher D, . CONSORT 2010 statement: updated guidelines for reporting parallel group randomized trials. Ann Intern Med. 2010;152(11):726-32. PMID: 20335313. http://dx.doi.org/10.7326/0003-4819-152-11-201006010-00232 20335313
95 Berkman ND, Santaguida PL, Viswanathan M, . In: The Empirical Evidence of Bias in Trials Measuring Treatment Differences. Rockville (MD) 2014. PMID: 2539289825392898.
96 Atkins D, Best D, Briss PA, . Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. PMID: 15205295. http://dx.doi.org/10.1136/bmj.328.7454.1490 15205295
97 Andersen MR, Drescher CW, Zheng Y, . Changes in cancer worry associated with participation in ovarian cancer screening. Psychooncology. 2007;16(9):814-20. PMID: 17225260. http://dx.doi.org/10.1002/pon.1151 17225260
98 Jacobs IJ, Skates SJ, MacDonald N, . Screening for ovarian cancer: a pilot randomised controlled trial. Lancet. 1999;353(9160):1207-10. PMID: 10217079. http://dx.doi.org/10.1016/s0140-6736(98)10261-1 10217079
99 Jacobs I, Davies AP, Bridges J, . Prevalence screening for ovarian cancer in postmenopausal women by CA 125 measurement and ultrasonography. BMJ. 1993;306(6884):1030-4. PMID: 8490497. http://dx.doi.org/10.1136/bmj.306.6884.1030 8490497
100 Gren L, Broski K, Childs J, . Recruitment methods employed in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Clin. 2009;6(1):52-9. PMID: 19254935. http://dx.doi.org/10.1177/1740774508100974 19254935
101 Buys SS, Partridge E, Greene MH, . Ovarian cancer screening in the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial: findings from the initial screen of a randomized trial. Am J Obstet Gynecol. 2005;193(5):1630-9. PMID: 16260202. http://dx.doi.org/10.1016/j.ajog.2005.05.005 16260202
102 Prorok PC, Andriole GL, Bresalier RS, . Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Controlled clinical trials. 2000;21(6 Suppl):273s-309s. PMID: 11189684.11189684
103 Menon U, Ryan A, Kalsi J, . Risk Algorithm Using Serial Biomarker Measurements Doubles the Number of Screen-Detected Cancers Compared With a Single-Threshold Rule in the United Kingdom Collaborative Trial of Ovarian Cancer Screening. J Clin Oncol. 2015;33(18):2062-71. PMID: 25964255. http://dx.doi.org/10.1200/JCO.2014.59.4945 25964255
104 Barrett J, Jenkins V, Farewell V, . Psychological morbidity associated with ovarian cancer screening: results from more than 23,000 women in the randomised trial of ovarian cancer screening (UKCTOCS). BJOG. 2014;121(9):1071-9. PMID: 24865441. http://dx.doi.org/10.1111/1471-0528.12870 24865441
105 Spielberger C, Gorsuch R, Lushene R, . Manual for the Stait-Trait Anxiety Inventory (Form Y1–Y2). Palo Alto, CA: Consulting Psychology Press; 1983. PMID: None.
106 Goldberg D Manual of the General Health Questionnaire. Windsor: NFER-Nelso: 1978. PMID: None.
107 Gewandter JS, Smith SM, McKeown A, . Reporting of primary analyses and multiplicity adjustment in recent analgesic clinical trials: ACTTION systematic review and recommendations. Pain. 2014;155(3):461-6. PMID: 24275257. http://dx.doi.org/10.1016/j.pain.2013.11.009 24275257
108 Moher D, Hopewell S, Schulz K, . CONSORT 2010 Explanation and Elaboration: updated guidelines for reporting parallel group randomised trials. BMJ 2010;340(c869). PMID: 20332511. http://dx.doi.org/10.1136/bmj.c869 20332511
109 Fleming TR Clinical trials: discerning hype from substance. Ann Intern Med. 2010;153(6):400-6. PMID: 20855804. http://dx.doi.org/10.7326/0003-4819-153-6-201009210-00008 20855804
110 Thornton JG, Bewley S Ovarian cancer screening: UKCTOCS trial. Lancet. 2016;387(10038):2601-2. PMID: 27353818. http://dx.doi.org/10.1016/S0140-6736(16)30846-7 27353818
111 Menon U UK Collaborative Trial of Ovarian Cancer Screening. ISRCTN. 2017;ISRCTN22488978. PMID: None. http://dx.doi.org/10.1186/ISRCTN22488978
112 Pinsky PF, Yu K, Kramer BS, . Extended mortality results for ovarian cancer screening in the PLCO trial with median 15years follow-up. Gynecol Oncol. 2016. PMID: 27615399. http://dx.doi.org/10.1016/j.ygyno.2016.08.334 27615399
113 Pinsky PF, Zhu C, Skates SJ, . Potential effect of the risk of ovarian cancer algorithm (ROCA) on the mortality outcome of the Prostate, Lung, Colorectal and Ovarian (PLCO) trial. Int J Cancer. 2013;132(9):2127-33. PMID: 23065684. http://dx.doi.org/10.1002/ijc.27909 23065684
114 Lai T, Kessel B, Ahn HJ, . Ovarian cancer screening in menopausal females with a family history of breast or ovarian cancer. J Gynecol Oncol. 2016;27(4):e41. PMID: 27102249. http://dx.doi.org/https://dx.doi.org/10.3802/jgo.2016.27.e41 27102249
115 Henderson JT, Harper CC, Gutin S, . Routine bimanual pelvic examinations: practices and beliefs of US obstetrician-gynecologists. Am J Obstet Gynecol. 2013;208(2):109 e1-7. PMID: 23159688. http://dx.doi.org/10.1016/j.ajog.2012.11.015 23159688
116 Guirguis-Blake J, Henderson J, Perdue L, . Screening for Gynecologic Conditions With Pelvic Examination: A Systematic Review for the U.S. Preventive Services Task Force. Agency for Healthcare Research and Quality; 2016. PMID: None.
117 Temkin SM, Miller EA, Samimi G, . Outcomes from ovarian cancer screening in the PLCO trial: Histologic heterogeneity impacts detection, overdiagnosis and survival. Eur J Cancer. 2017;87:182-8. PMID: 29156299. http://dx.doi.org/10.1016/j.ejca.2017.10.015 29156299
118 Wennberg JE Unwarranted variations in healthcare delivery: implications for academic medical centres. BMJ. 2002;325(7370):961-4. PMID: 12399352. http://dx.doi.org/10.1136/bmj.325.7370.961 12399352
119 Evans EC, Matteson KA, Orejuela FJ, . Salpingo-oophorectomy at the Time of Benign Hysterectomy: A Systematic Review. Obstet Gynecol. 2016;128(3):476-85. PMID: 27500347. http://dx.doi.org/10.1097/AOG.0000000000001592 27500347
120 U. S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
121 Kobayashi H, Yamada Y, Sado T, . A randomized study of screening for ovarian cancer: a multicenter study in Japan. Int J Gynecol Cancer. 2008;18(3):414-20. PMID: 17645503. http://dx.doi.org/10.1111/j.1525-1438.2007.01035.x 17645503
122 van Nagell JR, Jr., Miller RW, DeSimone CP, . Long-term survival of women with epithelial ovarian cancer detected by ultrasonographic screening. Obstet Gynecol. 2011;118(6):1212-21. PMID: 22105249. http://dx.doi.org/10.1097/AOG.0b013e318238d030 22105249
123 Miller RW, Pavlik EJ, Baldwin LA, . Complications from surgeries prompted by ovarian cancer screening. Gynecol Oncol. 2015;137:180. PMID: None. http://dx.doi.org/10.1016/j.ygyno.2015.01.452 25636459
124 Lowder JL, Oliphant SS, Ghetti C, . Prophylactic bilateral oophorectomy or removal of remaining ovary at the time of hysterectomy in the United States, 1979-2004. Am J Obstet Gynecol. 2010;202(6):538 e1-9. PMID: 20060093. http://dx.doi.org/10.1016/j.ajog.2009.11.030 20060093
125 Rice MS, Hankinson SE, Tworoger SS Tubal ligation, hysterectomy, unilateral oophorectomy, and risk of ovarian cancer in the Nurses' Health Studies. Fertil Steril. 2014;102(1):192-8 e3. PMID: 24825424. http://dx.doi.org/10.1016/j.fertnstert.2014.03.041 24825424
126 Hanley GE, McAlpine JN, Pearce CL, . The performance and safety of bilateral salpingectomy for ovarian cancer prevention in the United States. Am J Obstet Gynecol. 2016. PMID: 27810554. http://dx.doi.org/10.1016/j.ajog.2016.10.035 27810554
127 Garcia C, Martin M, Tucker LY, . Experience With Opportunistic Salpingectomy in a Large, Community-Based Health System in the United States. Obstet Gynecol. 2016;128(2):277-83. PMID: 27399999. http://dx.doi.org/10.1097/AOG.0000000000001531 27399999
128 Russell MR, D'Amato A, Graham C, . Novel risk models for early detection and screening of ovarian cancer. Oncotarget. 2016. PMID: 27903971. http://dx.doi.org/10.18632/oncotarget.13648 27903971
129 Drescher CW, Hawley S, Thorpe JD, . Impact of screening test performance and cost on mortality reduction and cost-effectiveness of multimodal ovarian cancer screening. Cancer Prev Res (Phila). 2012;5(8):1015-24. PMID: 22750949. http://dx.doi.org/10.1158/1940-6207.CAPR-11-0468 22750949