# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, of AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Paul Hoskins, MA, Usha Menon, MD, Edward Pavlik, PhD, Paul Pinsky, PhD, Joanne Schottinger, MD, Shelly Tworoger, PhD, and John van Nagell, MD, who provided expert support; Barry Kramer, MD, MPH at the National Cancer Institute and Sherri Stewart, PhD, at the Centers for Disease Control and Prevention for providing federal partner review of the draft report; Jennifer S. Lin, M.D., for mentoring and project oversight; and Megan Rushkin MPH, Ning Smith PHD, and Katherine Essick, for technical and editorial assistance at the Center for Health Research.