# Chapter 3 Results

## Description of Included Studies

Our literature search yielded 1,381 unique citations. From these, we reviewed the full text of 74 articles. After full text review and critical appraisal, we included 4 trials (published in 17 articles) (Appendix A Figure 1). Appendix B contains a full list of included studies.

Of the 74 articles that were reviewed, the most common reason for exclusion were not having an included study design (i.e., not RCT) or not reporting a relevant outcome. No trials were rated as poor quality. Appendix C contains a list of all excluded trials and their reasons for exclusion.

Four RCTs (n = 293,587) were included; three reported health outcomes (KQ1), and all reported potential harms of screening (KQ2) (Table 1). Two were conducted in the United States^91, 97^ and two in the United Kingdom.^92, 98^ Analyzed sample sizes ranged from 549 to 202,546 participants. The three trials^91, 92, 98^ reporting health outcomes and potential harms were rated good-quality and the small trial^97^ reporting only on psychological harms of screening was rated fair-quality.

Table 1 Characteristics of Ovarian Cancer Screening Randomized Trials

Trial, year of publication | UKCTOCS, 2016^92^ | PLCO, 2011^91^ | QUEST, 2007^97^ | U.K. Pilot, 1999^98^
Quality | Good | Good | Fair | Good
Included key questions | 1, 2 | 1, 2 | 2 | 1, 2
Country | U.K. | U.S. | U.S. | U.K.
Study dates | 2001-2014 | 1993-2010^*^ | NR | 1989-1998
Randomization allocation | 1:1:2 (CG) | 1:1 | 1:1 | 1:1
N randomized | 202,638 | 78,216 | 592 | 21,955
N analyzed | 202,546 | 68,557^†^ | 549 | 21,935
Key outcomes reported^‡^ | KQ1: Ovarian cancer incidence and mortality KQ2: Screening false positive rates and surgical complications | KQ1: Ovarian cancer incidence and mortality KQ2: Screening false positive rates and surgical complications | KQ2: Psychological harms of screening program participation | KQ1: Ovarian cancer incidence and mortality^§^ KQ2: Screening false positive rates and surgical complications
Enrollment/recruitment source | National Health Service catchments of 13 regional centers in Wales, England, and Northern Ireland; women recruited from 27 primary care service groups in the regions. | Community volunteers from the catchment areas of 10 screening centers | Population volunteers, physician referral | Community volunteers and postal invitations to 40 primary care practices in England, Scotland, and Wales
Inclusion criteria | Post-menopausal, age 50-74 | Aged 55-74 | Age ≥30 | Post-menopausal, age ≥45
Exclusion criteria | Self-reported history of bilateral oophorectomy or ovarian malignancy, increased risk of familial ovarian cancer, active nonovarian malignancy | Previous bilateral oophorectomy; history of lung, colorectal, or ovarian cancer; current treatment for cancer other than nonmelanoma skin cancer; colonoscopy, sigmoidoscopy, or barium enema in past 3 years; pervious surgical removal of lung or entire colon; participation in other screening trialǁ | High risk of ovarian cancer^¶^; cancer diagnosis in past year; plans to become pregnant in the following 2 years | History of bilateral oophorectomy, ovarian cancer, or any active malignancy

* Additional mortality data published through 2012^112^

† 9,659 women excluded from analysis due to oophorectomy prior to trial entry (included in n randomized because they were screened for other cancers in PLCO)

‡ Ovarian cancer was defined according to the 2014 World Health Organization and Fédération Internationale de Gynécologie Obstétrique definitions which includes ovarian, tubal, and peritoneal cancers.^90^ Cancer cases were abstracted or calculated using this definition when possible, even if it was not the primary outcome reported in the trial.

§ Data from the U.K. Pilot trial did not capture information related to peritoneal cancer; therefore, these results are limited to primary cancer of the ovary and fallopian tubes.

ǁ Exclusion based on CRC screening began in April 1995. Trial initially excluded women with of previous oophorectomy (dropped in 1996) and current tamoxifen use (dropped in 1999)

¶ High risk of ovarian cancer: reported family history predicted at least a 10% probability of a germline mutation in the BRCA1 or BRCA2 genes or Amsterdam criteria for hereditary nonpolyposis colorectal cancer syndrome^129^

Abbreviations: CG = control group; N = number; NR = not reported; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; QUEST = Quality of life, Education, and Screening Trial; U.K. = United Kingdom; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening; U.S. = United States.

## Included Populations

The two U.K. trials (U.K. Pilot and UKCTOCS) were limited to postmenopausal women aged ≥45 and 50 to 74,^92, 98^ the PLCO to women aged 55 to 74,^91^ and the Quality of life, Education, and Screening Trial (QUEST) to women aged 30 or older^97^ (Table 1). Women with a history of bilateral oophorectomy or ovarian malignancy, at increased familial risk of cancer, or with an active malignancy where excluded from the largest U.K. trial.^92^ Exclusions were similar for the other trials included for KQ1,^91, 98^ but the PLCO additionally excluded women with a history of colorectal or lung cancer, or who had undergone an investigation or treatment for these cancers.^91^ The QUEST study, included only for KQ2, also excluded women with plans to become pregnant.^97^

## Results of Included Studies

### KQ 1 Does Screening for Ovarian Cancer in Asymptomatic Women Using Single Tests or Combined Algorithms Reduce All-Cause or Disease-Specific Morbidity and Mortality?

#### Summary

Three trials evaluating four screening strategies showed no effect of screening on ovarian cancer mortality on the basis of a priori per protocol statistical analyses testing. The screening tests evaluated were annual transvaginal ultrasound, annual transvaginal ultrasound and CA-125 serum testing, annual CA-125 testing, and annual CA-125 serum testing interpreted with an algorithm (ROCA) that incorporates changes over time to inform triage and rescreening intervals.

#### Description of Included Studies

Three large, good-quality trials reported ovarian cancer incidence and mortality for women randomized to ovarian cancer screening versus no screening or usual care. The largest (n=202,546) and most recent trial is the UKCTOCS,^92^ which began enrolling trial participants in 2001 through 13 National Health Service centers in England, Wales, and Northern Ireland. Identification of women was centralized using primary care registers, and eligible women received personalized invitations. A smaller included trial (n=21,935) was conducted in the United Kingdom by the same research group in preparation for UKCTOCS (U.K. Pilot).^98^ This trial recruited women who had participated in a previous ovarian cancer screening study.^99^ The third included trial is the PLCO^91^ cancer screening randomized trial, begun in 1993 at 10 clinical screening centers in the United States (n = 68,557). The 10 screening centers developed individual recruitment methods. Women were primarily recruited via direct mail; however, other methods included community outreach and mass media.^100^

The demographic characteristics of randomized trial participants are described in Table 2. In the UKCTOCS and U.K. Pilot trials, the race/ethnic composition of the study population was over 95 percent white.^92, 98^ Eighty-eight percent of women in the PLCO^91^ were white, non-Hispanic (6% were black, non-Hispanic, 4% were Asian or Pacific Islander, and very few were Hispanic or Native American). The PLCO^91^ and UKCTOCS^92^ had similar participant age distributions, with over half of UKCTOCS participants between the ages of 56 and 66 at baseline and 65% in the PLCO between the ages of 55 and 64. The U.K. trials^92, 98^ included post-menopausal women as young as 45 or 50, whereas the PLCO^91^ did not include any women younger than age 55. Nineteen percent of women in UKCTOCS^92^ and 27 percent of PLCO^91^ participants had had a prior hysterectomy at baseline (without bilateral oophorectomy). Although women with a known elevated familial ovarian cancer risk were excluded, 1.6 percent of women in UKCTOCS^92^ reported maternal history of ovarian cancer, and 6.4 percent a maternal history of breast cancer. 17 percent of women in the PLCO ^91^ reported any family history of breast or ovarian cancer.

Table 2 Baseline Characteristics of Ovarian Cancer Screening Trial Participants

Trial, year of publication | UKCTOCS, 2016^92^ | PLCO, 2011^91^ | QUEST, 2007^97^ | U.K. Pilot, 1999^98^
Quality | Good | Good | Fair | Good
Mean age, years | 61 | NR | NR | 56
Age distribution | IQR: 56.0-66.2 | 55-59: 34.2% 60-64: 30.3% 65-69: 21.9% 70-74: 13.6% | 30-49: 54.1%^*^ >49: 45.9%^*^ | 45-54: 40.6%^†^ 55-64: 48.4%^†^ 65-74: 10.0%^†^ >74: 1.0%^†^
Race (%) | White: 96.4 Black: 1.4 Asian: 0.9 Other: 0.8 | White, non-Hispanic: 88.5 Black, non-Hispanic: 5.7 Hispanic: 1.5 Asian/Pacific Islander: 3.5 American Indian/Alaskan Native: 0.8 | White, non-Hispanic: 95 Other: 5 | White: 95 Asian: 0.5 Black: 0.6 Other: 3.9
Prior hysterectomy (%) | 18.8 | 27.2 | NR | NR
Personal history of cancer (%) | 6.0 | Breast cancer: 3.6 | 9.9^*^ | NR
Family history of breast or ovarian cancer (%) | Maternal ovarian: 1.6 Maternal breast: 6.4 | 17.4 | 17.1 | NR

* Percent in screening arms only

† Data from initial prevalence screen study, n=22,000

Abbreviations: IQR = interquartile range; NR = not reported; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; QUEST = Quality of life, Education, and Screening Trial; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening

All three trials tested annual screening for ovarian cancer with CA-125 and/or transvaginal ultrasound (Table 3). The UKCTOCS^92^ had two intervention arms and a no-screening control arm (randomized 1:1:2, respectively). Women assigned to CA-125 risk algorithm screening received CA-125 serum testing, with triage and followup determined by application of the Risk of Ovarian Cancer Algorithm (ROCA). Three levels of followup, depending on the ROCA estimate were assigned: continue annual screening (low risk), repeat CA-125 in 12 weeks (intermediate risk), or repeat CA-125 testing and transvaginal ultrasound in 6 weeks (elevated risk). Women with persistent abnormalities were referred for surgical investigation at tertiary care health centers in the U.K. National Health Service system. Women in the ultrasound intervention arm had yearly transvaginal ultrasound testing, with repeat ultrasounds scheduled for unsatisfactory or abnormal results and referral to surgical diagnostic testing and recommended treatment through usual care in the U.K., as in the CA-125 screening arm. Women in the intervention arms of the UKCTOCS underwent a maximum of 11 screening rounds with a median of 11.1 years of follow up.^92^ The U.K. Pilot^98^ trial compared annual CA-125 screening tests to no screening. Women with CA-125 serum levels of 30 U/mL or greater were considered screening test positive, and further evaluated using ultrasonography. Women in the intervention arm of the U.K. Pilot study underwent a maximum of 3 rounds of screening with up to 8 years of follow up.^98^ Women in the screening intervention arm of the PLCO^91^ received both CA-125 testing and ultrasonography. The cutoff designating an abnormal result on the CA-125 test was serum level of 35 U/mL or greater. Women with abnormal results on either the CA-125 test or ultrasound were referred for additional evaluation by notifying the woman and her usual community physician.^91, 101^ The original trial design for PLCO called for screening for only four annual ovarian cancer screening rounds. A modification of the protocol in 1998 extended screening to 6 annual rounds, with the purpose of increasing the power of the trial. During this 2-round extension, only CA-125 was used for screening.^102^ Therefore, women in the intervention arm of PLCO underwent a maximum of 6 rounds of screening (4 with CA-125 and ultrasound, 2 with CA-125 alone) with a median of 12.4 years of follow up. Additionally, in the first 5 years of the PLCO, palpation of the ovaries with a bimanual pelvic examination was also included in the screening protocol. This component of the intervention was dropped, however, as no cancers were identified solely on the basis of this screening component.^70^

Table 3 Ovarian Cancer Screening Trial Protocols

Trial, year of publication | UKCTOCS, 2016^92^ | PLCO, 2011^91^ | U.K. Pilot, 1999^98^
Quality | Good | Good | Good
Screening intervention | Arm 1: Initial CA-125 testing with ROCA algorithm used to determine risk and followup testing and assessment through clearly defined, trial specific protocols.; followup included repeat CA-125 test (intermediate risk) or repeat CA-125 and ultrasound (elevated risk) based on ROCA Arm 2: Ultrasound (primarily transvaginal); followup ultrasound for unsatisfactory or abnormal ultrasounds | Ultrasound (mainly TVU) and CA-125^§^ | Initial CA-125 testing; followup included ultrasound for elevated CA-125 levels
Study definition of positive screening result | Referral to surgery for suspected ovarian cancer following positive screening and clinical assessment | Abnormal CA-125 or ultrasound | Referral to surgery for suspected ovarian cancer
Followup protocol for women with positive screening test result | Clinical assessment and surgical investigation conducted by trial clinicians | Notification of patients and their primary care physicians; community care | Referral through family physician to a gynecologist for surgical investigation
Comparison group | No screening | Standard community care | No screening
Screening frequency | Annual | Annual | Annual
Maximum number of screening rounds | 6 (original protocol) 7-11 (extended screening based on interim analysis) | CA-125: 4-6 depending on enrollment date. TVU: 4 | 3^#^
Median length of followup, years (range) | 11.1 (IQR 10.0 - 11.0) (Range 0 – 13.6) | 12.4 (IQR 10.9 -13) | NR (Range 0 - 8)
Positive test result definitions | CA-125 ROCA: Intermediate risk (risk ≥1/1818), elevated risk (risk ≥1/500)^*^ Ultrasound: One or both ovaries with complex morphology, simple cysts greater 60 cm^3^, or ascites | CA-125: ≥35 U/mL Ultrasound: Ovarian volume >10 cm^3^; Cyst volume >10 cm^3^; Any solid area or papillary projection extending into the cavity of a cystic ovarian tumor of any size; or any mixed (solid and cystic) component within a cystic ovarian tumor | CA-125 ≥30 U/mL
Definition of cancer | Primary outcome: Malignant neoplasms of the ovary including epithelial and nonepithelial ovarian cancer and malignant neoplasms of the fallopian tube^†^ and undesignated malignancies of the ovaries, fallopian tube, or peritoneum Secondary outcome: Ovarian (as defined above) and primary peritoneal cancer^‡^ | Ovarian, primary peritoneal, and fallopian tube cancersǁ^¶^ | Invasive primary epithelial cancers of the ovary and fallopian tube
Identification of ovarian cancer cases and deaths | Administrative records (e.g., National Health Service), cancer registries, followup questionnaires, direct communication with participants, their families, and physicians, death certificates. | Annual questionnaire to participants, National Death Index, and population-based cancer registries (when possible). | National Health Service, followup questionnaires, communication with physicians and participant families, death certificates.
Confirmation of ovarian cancer cases and deaths | Blinded review of diagnosis and mortality by members of a designated panel (2 pathologists, 2 gynecological oncologists) | Blinded review of mortality by qualified (i.e., epidemiology, surgery, medicine, radiation oncology) member of a designated panel | Blinded pathology review of diagnosed cases

* CA-125 levels were changed in 2005 to maintain the % in each risk level (intermediate ≥1/3500, elevated ≥1/1000). 84.6% of screens were classified using pre-2005 cutoffs.

† ICD-10 C56, C57

‡ ICD-10 C48.1, C48.2

§ Annual bimanual clinical examination of the ovaries discontinued in 1998 because no cases identified solely with this screening test

ǁ ICD for Classification of Diseases for Oncology, Revision 2: C569, C481, C482, C570

¶ Borderline tumors were considered false positive screens

# All of the women in this trial (including the control group) had undergone a previous round of screening approximately 10 years prior

Abbreviations: CA-125 = cancer antigen 125; cm = centimeter; IQR = interquartile range; NR = not reported; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; ROCA = Risk of Ovarian Cancer Algorithm TVU = transvaginal ultrasound; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening; U/mL = units per milliliter

#### Screening Adherence and Contamination

In the UKCTOCS^92^, 95 percent of women in the ultrasound arm completed at least one screen, and 99 percent of women in the CA-125 ROCA intervention arm completed at least one screen (Table 4). Overall 81 percent of screens were attended in the CA-125 ROCA intervention arm and 78 percent were attended in the ultrasound intervention arm. Adherence varied by round, ranging from 47 to 98 percent in the CA-125 ROCA group and 36 to 95 percent in the ultrasound group.^92^ In the U.K. Pilot^98^ trial, 86 percent of randomized participants completed at least one screen and 71 percent completed all three screening rounds. Adherence in the PLCO^91^ was similar, with 78 to 84 percent of participants attending ultrasound screening and 73 to 85 percent of women attending CA-125 screening depending on the screening round. Rates of screening contamination in the control group were not reported in the U.K. Pilot^98^ trial, but were below 5 percent in the UKCTOCS^92^ and PLCO^91^.

Table 4 Adherence to Screening in Ovarian Cancer Screening Trials

Trial, Year of publication | UKCTOCS, 2016^92^ | PLCO, 2011^91^ | U.K. Pilot, 1999^98^
Quality | Good | Good | Good
Completed at least one screening round (%) | CA-125 ROCA: 98.9 ultrasound: 95.3 | NR | 85.5
Screening adherence (%) | CA-125 ROCA: 80.8 (% of screens attended) ultrasound: 78.0 (% of screens attended) Adherence in each round: CA-125 ROCA: 47.2-98.4 ultrasound: 35.9-94.9 | ultrasound: 78-84 CA-125: 73-85 | 1st round: 79.7 2nd round: 79.3 3rd round: 77.4 (70.7% completed all 3 screens)
Screening contamination in control group % | 4.3^*^ | ultrasound: 2.3 - 3.2 per year CA-125: 2.7 - 4.6 per year | NR

* Self-reported ultrasound or CA-125 screening in the control arm over the entire trial period

Abbreviations: CA-125 = cancer antigen 125; NR = not reported; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; U.K. = United Kingdom; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening

#### Definition of Outcomes in the Trials

The following results from the PLCO^91^ and UKCTOCS^92^ include cases of ovarian, fallopian, and primary peritoneal cancer cases, the prioritized outcome for this review. Data from the U.K. Pilot trial did not capture information related to peritoneal cancer^98^; therefore, these results are limited to primary cancer of the ovary and fallopian tubes.

#### Ovarian Cancer Incidence

The incidence of ovarian cancer did not differ significantly between study arms in any of the included trials. In the UKCTOCS^92^ ovarian cancer was diagnosed 0.7 percent of those in the CA-125 ROCA arm (354 cases), and 0.6 percent of those in the ultrasound arm (324 cases) and control arm (645 cases). The incidence rate of ovarian cancer was 6.4 per 10,000 person-years in the CA-125 ROCA screening arm, and 5.9 per 10,000 person-years in both the ultrasound and no screening control arms. In the PLCO,^91^ ovarian cancer was diagnosed in 0.6 percent (212 cases) of those in the intervention arm and 0.5 percent (176 cases) of those in the usual care arm (RR 1.21 95% CI, 0.99 to 1.48). In the U.K. Pilot trial, ovarian cancer was diagnosed in 0.1 percent (16 cases) of women in intervention arm and 0.2 percent (20 cases) in the no-screening arm. The low incidence may be due to smaller sample sizes, or the fact that women underwent a prevalence screen 10 years prior to the study. Incidence rates were not reported for the U.K. Pilot trial.^98^

#### Ovarian Cancer Mortality

##### CA-125 Screening

The UKCTOCS^92^ and U.K. Pilot^98^ trial included intervention arms that compared CA-125 screening to no screening (Table 5). Although both of the trials used an initial CA-125 screening test to determine followup, the U.K. Pilot study used a single cutpoint level to refer participants to further evaluation (CA-125 ≥ 30 u/ml), and the UKCTOCS used the ROCA algorithm^103^ to triage intermediate and high CA-125 ROCA results for repeat screening and ultrasound. The ROCA CA-125 screening arm was described as multimodal screening in the UKCTOCS trial publications, and included a standard protocol for all followup screening tests. The ROCA algorithm is more complex than single cutpoint CA-125 testing approaches because it incorporates changes in CA-125 changes over time for individual women. In the UKCTOCS, ovarian cancer mortality (calculated to include peritoneal cancers) in the intervention arm and control arm was similar (IG: 0.32% versus CG: 0.35%) and in survival analysis was 2.9 ovarian cancer deaths per 10,000 person-years in the intervention group and 3.3 ovarian cancer deaths per 10,000 person-years in the control group. This difference was not statistically significant based on a Cox proportional hazards model (HR = 0.89 [95% CI, 0.74 to 1.08]).^92^

Table 5 Benefits Reported in Ovarian Cancer Screening Trials: Ovarian Cancer Mortality^*^

Trial, Year of publication | UKCTOCS, 2016^92^ (CA-125 ROCA arm) | UKCTOCS, 2016^92^ (ultrasound arm) | PLCO, 2011^91^ | U.K. Pilot, 1999^98^ǁ
Quality | Good | Good | Good | Good
N analyzed per arm | IG: 50,624 CG: 101,299 | IG: 50,623 CG: 101,299 | IG: 34,253 CG: 34,304 | IG: 10,958 CG: 10,977
Ovarian cancer cases, n (%) | IG: 354 (0.7) CG: 645 (0.6) | IG: 324 (0.6) CG: 645 (0.6) | IG: 212 (0.6) CG: 176 (0.5) | IG: 16 (0.1) CG: 20 (0.2)
Ovarian cancer incidence rate | IG: 6.4 per 10,000 p-y CG: 5.9 per 10,000 p-y | IG: 5.9 per 10,000 p-y CG: 5.9 per 10,000 p-y | IG: 5.7 per 10,000 p-y CG: 4.7 per 10,000 p-y | NR
Ovarian cancer incidence between group difference | NR | NR | RR: 1.21 (95% CI, 0.99 to 1.48) | NR
Ovarian cancer mortality, n (%) | IG: 160 (0.32) CG: 358 (0.35) | IG: 163 (0.32) CG: 358 (0.35) | IG: 118 (0.34) CG: 100 (0.29)^‡^ | IG: 9 (0.082) CG: 18 (0.16)
Ovarian cancer mortality rate | IG: 2.9 per 10,000 p-y CG: 3.3 per 10,000 p-y | IG: 3.0 per 10,000 p-y CG: 3.3 per 10,000 p-y | IG: 3.1 per 10,000 p-y CG: 2.6 per 10,000 p-y | NR
Ovarian cancer mortality between group difference | HR: 0.89 (95% CI, 0.74 to 1.08), p=0.23^†^ | HR: 0.91 (0.76 to 1.09), p=0.31^†^ | RR: 1.18 (95% CI, 0.82 to 1.71) p=NR^§^ | RR: 0.50 (95% CI, 0.22 to 1.11) p=0.083^¶^
Ovarian cancer survival | NR | NR | Survival difference from date of randomization p = 0.67 Survival difference from date of diagnosis (lead time bias), p=0.18. | IG: survival 72.9 months (median) CG: 41.8 months (median) Survival difference from date of randomization, p=0.011^#^
Ovarian cancer treatment | NR | NR | Surgery with systemic chemotherapy IG: 171 (81%) CG: 140 (80%) p=NR, NS | NR

* Includes ovarian, fallopian, and primary peritoneal cancers if reported

† Cox model

‡ Extended mortality data reported in results text

§ Sequentially adjusted

ǁ Does not include peritoneal cancer

¶ Calculated (article reports RR calculated in in terms of increased relative risk)

# Log rank

Abbreviations: CG = control group; CI = confidence interval; HR = hazard ratio; IG = intervention group; n = number; NR = not reported; NS = not statistically significant; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; RR = rate ratio; U.K. = United Kingdom; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening

The smaller U.K. Pilot^98^ trial (n = 21,935) was designed to assess feasibility and performance of screening and was not powered to test mortality differences. There were 9 ovarian cancer deaths in the intervention group (0.08%) and 18 in the no-screening comparison group (0.16%); the difference was not statistically significant e (RR 0.50 [95% CI, 0.22 to 1.11]). A statistically significant difference in survival between women with index cancers in the IG and the CG was observed when computed from the date of randomization (IG median 72.9 months, CG median 41.8 months; p=.01). This finding was based on a small number of events, and only 6 of 16 index cancers identified in the intervention arm were screen detected. Survival in the control group noted by the study authors as being unusually poor.

##### Ultrasound Screening

The ultrasound screening intervention arm in the UKCTOCS^92^ did not reduce ovarian cancer mortality compared with no screening (Table 5). Ovarian cancer mortality in the intervention arm and control arm was similar (IG 0.32% versus CG 0.35%) and in survival analysis was 3.0 per 10,000 person-years in the intervention group and 3.3 per 10,000 person-years in the comparison group (HR 0.91[95% CI, 0.76 to 1.09]).^92^

##### Combined CA-125 and Ultrasound Screening

The incidence of ovarian cancer mortality in the PLCO^91^ was 3.1 per 10,000 person-years in the intervention arm and 2.6 per 10,000 person-years in the usual care comparison arm. There were 118 deaths in the intervention group (0.34%) and 100 deaths in the control group (0.29%), a not statistically significant difference (RR 1.18 [95% CI, 0.82 to 1.71]). Survival with ovarian cancer did not differ significantly between study arms when estimated from the date of diagnosis (p=0.18) and from the date of randomization (p=0.67), which better accounts for possible lead-time bias (Table 5).^91^

#### Quality of Life

Two studies addressed changes in quality of life associated with ovarian cancer screening,^97, 104^both with regard to potential anxiety associated with screening. These results are therefore reported for Key Question 2 as potential harms.

#### Ovarian Cancer Morbidity

There were no differences in treatment approach by study arm in the PLCO; 81 percent in the intervention group received surgery plus systemic therapy, compared with 80 percent in the usual care group.^91^

### KQ 2 What Are the Harms of Screening for Ovarian Cancer, Including Harms of the Screening Test and of Diagnostic Evaluation?

#### Summary

Four trials reported on the harms of ovarian cancer screening. False positive rates and surgical harms were highest for screening programs using transvaginal ultrasound as an initial test. Major surgical complications as estimated in the two largest trials occurred in women with investigations from screening that did not lead to a cancer diagnosis, ranging from 3 to 15 percent of surgeries. The screening tests themselves resulted in minor complications, at rates widely ranging based on study specific definitions from 0.86 to 58.3 per 10,000 screens/women for CA-125 test blood draws (e.g., fainting, bruising) and from 1.86 to 3.3 per 10,000 screens/women for ultrasound testing (e.g., pain, discomfort, infection, bruising).

#### Description of Included Studies

Evidence on false positive rates and surgical harms of screening were included from the three trials^91, 92, 98^ included for KQ1. A substudy of the UKCTOCS^104^ (n=23,374) and an additional fair-quality trial (QUEST)^97^ (n=549) aimed at evaluating the effects of ovarian cancer screening on quality of life (QoL) and psychological outcomes are described below.

#### False Positive Rates and Complications

##### CA-125 Screening

False positive rates calculated for screening with CA-125 across all rounds of the U.K. Pilot trial were 4.2 percent.^98^ In the UKCTOCS the false positive rate in the prevalence round of screening was 9.0 percent^68^ and cumulatively across all subsequent incidence rounds of the UKCTOCS the false positive rate rose to 44.2 percent with a total of 44.3 percent of women screened receiving a positive test result at least once^68^ (Table 6). Screening test complications were minor for CA-125 screening, including bruising, fainting, and pain. These complications were reported to occur for 0.86 per 10,000 screens in UKCTOCS^92^ and 58.3 per 10,000 women in the PLCO.^91^

Table 6 Harms Reported in Ovarian Cancer Screening Trials: Positive Testing, False Positive Testing, and Surgical Complications in Ovarian Cancer Screening^*^

Trial, year of publication | UKCTOCS, 2016^92^ (CA-125 ROCA arm) | UKCTOCS, 2016^92^ (ultrasound arm) | PLCO, 2011^91^ | U.K. Pilot, 1999^98^
Quality | Good | Good | Good | Good
Prevalence of positive screening test results, by round % (n positive test/N screened)^†^ | Round 1: 9.1 (4,555/50,078) | Round 1: 12.0 (5779/48,230) | Round 1: 5.9 (1,706/28,816) Round 2: 4.9 (1341/27,541) Round 3: 4.6 (1224/26,584) Round 4: 4.5 (1148/25,423) | Round 1: 3.2 (284/8,732) Round 2: 1.5 (163/10,936) Round 3: 3.0 (334/10,925)
Cumulative prevalence of positive screening test results % (n with positive test/N screened)^†^ | Rounds 2 to 11: 44.3 (20,485/46,237) | NR | Overall screening program: 9.8 (3,358/34,253) | Overall screening program: 4.3 (468/10958)
False positive rate: Women without cancer who had a positive screening result % (n with false positive screen/N women without cancer) | Prevalence round: 9.0 (4,513/50,031)^§^ Rounds 2 to 11: 44.2 (20,340/46,067) | Prevalence round: 11.9 (5,734/48,177)^§^ NR for subsequent rounds | Overall screening program: 9.6 (3,285/34,041) | Overall screening program: 4.2 (462/10,942)^§^
False positive surgery rate: Women without cancer undergoing surgery % (n surgery/N women without cancer) | 0.97 (488/50,270) | 3.25 (1634/50,299) | 3.17 (1,080/34,041) | 0.2 (23/10,942)^§^
Screening test complications | 0.86 per 10,000 screensǁ | 1.86 per 10,000 screens^††^ | CA-125: 58.3 per 10,000 women^§§^ TVU: 3.3 per 10,000 women^§§^ | NR
Women without cancer with surgical complications % (n complication/N with false positive surgery)^‡^ | 3.07 (15/488)^¶^ | 3.49 (57/1,634)^‡‡^ | 15.09 (163/1,080)ǁǁ | 0 (0)
Deaths from other causes | IG: 3376 (6.7%) 61.5 per 10,000 p-y^#^ CG: 6658 (6.6%) 60.7 per 10,000 p-y^#^ RR: 0.99, p=0.65^**^ | IG: 3262 (6.4%) 59.4 per 10,000 p-y^#^ CG: 6658 (6.6%) 60.7 per 10,000 p-y^#^ RR: 0.99, p=0.65^**^ | IG: 2924 (76.6 per 10,000 p-y)^¶¶^ CG: 2914 (76.2 per 10,000 p-y)^¶¶^ RR: 1.01 (95% CI, 0.96 to 1.06) p=NR | NR

* Includes ovarian, fallopian, and primary peritoneal cancers if reported

† Patient experience of first positive screening test result leading to additional triage/followup (including repeated testing due to unsatisfactory results).

‡ Among women with false positive results/benign findings who underwent surgery

§ Does not include peritoneal cancers

ǁ Includes: Bruising (13), pain (8), hematoma (3), fainting (1), cystitis/infection (1), other (4)

¶ Includes: anesthetic complications (1), injury to hollow viscus (2 gastrointestinal, 1 bladder), hemorrhage (2), deep vein thrombosis (1), bowel obstruction (4), wound breakdown(1), significant ileus (1), uterine perforation (1), infection (1)

# Excludes ovarian and primary peritoneal cancer deaths

** RR mortality ratio for no screening group vs CA-125 ROCA and ultrasound groups combined

†† Includes: Pain (20), cystitis/infection (11), discomfort (5), bruising (2), fainting (1), other (22)

‡‡ Includes: Injury to hollow viscus (4 gastrointestinal, 3 bladder, 1 ureter), hemorrhage (11), anesthetic complication/myocardial infarction (3), hernia (6), deep vein thrombosis/pulmonary embolism (3), wound breakdown (6), bowel obstruction (4), wound/supravaginal hematoma (4), infection (6), pain with readmission or further operation (3)

§§ Minor complications (e.g., fainting, bruising)

ǁǁ 222 total complications in 163 patients. Includes: Infection (89), direct surgical harms (63), cardiovascular or pulmonary events (31), or other (39)

¶¶ Excludes deaths from ovarian, colorectal, and lung cancer

Abbreviations: CA-125 = cancer antigen 125; CG = control group; CI = confidence interval; IG = intervention group; n = number; NR = not reported; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; P-Y = person-years; RR = relative risk; TVU = transvaginal ultrasound; U.K.= United Kingdom; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening

Table 7 Harms Reported in Ovarian Cancer Screening Trials: Psychological Effects of Screening

Trial, Author, Year of publication | UKCTOCS, ^92^ Barrett, 2014^104^ | QUEST,^97^ Andersen, 2007^97^
Quality | Good | Fair
Population | Random sample from UKCTOCS: CA-125 ROCA: 301 ultrasound: 283 CG: 755 Event sample^*^: CA-125 ROCA: 12,357 ultrasound: 9,678 | All screened patients participating in Quality of Life, Education, and Screening Trial (QUEST): IG: 292, CG: 150
Measures | Spielberger State/Trait Anxiety Inventory, General Health Questionnaire 12 | QoL: SF-36 Mental and Physical Health scores Distress: Impact of Events Scale Cancer worry: Modified Lerman cancer worry scale
Psychological effect of screening | Random sample: no evidence of difference in state anxiety between screening and control groups | QoL, Distress, Cancer Worry: No statistically significant differences between study arms
Psychological effects of positive test results or repeat screening tests | Random sample: No evidence of change in anxiety or psychological morbidity due to repeat screenings compared with annual screen. Event sample: Compared with a single repeat screen: evidence of higher anxiety for multiple repeat scans (p<0.010) (small absolute effect); greater odds of psychological morbidity (GHQ-12: score ≥4) with higher level referral screening: OR 1.28 (95% CI, 1.18 to 1.39) | Women with abnormal test results (n=32) compared with women with no abnormal results more likely to report cancer worry at 2 year followup (OR 2.8; 95% CI, 1.1 to 7.2)

* All women in the screening arms recalled for repeat screening (excluding those in the random sample)

Abbreviations: CG = control group; CI = confidence interval; GHQ-12 = General Health Questionnaire 12; OR = odds ratio; QoL = quality of life; QUEST = Quality of life, Education, and Screening Trial; SF-36 = 36-Item Short Form Survey; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening

Table 8 Summary of Evidence

Test | # studies (k), sample size (n) Design | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence for the KQ | Applicability
KQ1: Effectiveness
Annual screening with CA-125 testing | k=2 n=173,858 RCT | Ovarian cancer mortality (k=2, n=173,858). Screening with CA-125 did not result in improved ovarian cancer mortality compared with no screening (UKCTOCS^92^ HR 0.89, 95% CI, 0.74 to 1.08, U.K. Pilot^98^ RR=0.50, 95% CI, 0.22 to 1.11) | Reasonably consistent Reasonably precise | Undetected | Good | Followup not available beyond 10 years for a substantial proportion of UKCTOCS trial participants. Reporting bias undetected. | Moderate | Trial evidence from the U.K. where screening occurred in specialized trial settings and cancer treatment was provided through the National Health Service, which is a more centralized health system relative to the U.S. Study enrolled mostly white women UKCTOCS^92^ began in 2001 FDA does not support ROCA screening algorithm
Annual screening with transvaginal ultrasound examination | k=1 n=151,922 RCT | Ovarian cancer mortality (k=1, n=151,922). TVU screening did not result in improved ovarian cancer mortality compared with usual care (UKCTOCS^92^ HR 0.91, 95% CI, 0.76 to 1.09) | Consistency NA Reasonably precise | Undetected | Good | Followup data incomplete beyond 10 years for a substantial proportion of trial participants. | Moderate | Trial evidence from the U.K. where screening occurred in specialized trial settings and cancer treatment provided through the National Health Service, which is a more centralized health system relative to the U.S. Study enrolled few nonwhite participants
Annual screening with CA-125 testing and transvaginal ultrasound examination | k=1 n=68,557 RCT | Ovarian cancer mortality (k=1, n=68,557). No reduction was found in ovarian cancer mortality from combined TVU and CA-125 screening compared with usual care (PLCO^91^ RR 1.18, 95% CI, 0.82 to 1.71). | Consistency NA Reasonably precise | Undetected | Good | Changes to protocol, ovarian palpation dropped after first 4 trial years | Moderate | U.S. multisite trial with usual care control condition and referral to community clinicians for screen positives Majority white, non-Hispanic study participants Trial begun in 1993
KQ2: Harms
Annual screening with CA-125 testing | k=3 n=242,415 RCT | False positive rate from screening (k=2, n=173,858). False positive rate over multiple rounds of screening in the largest trial was 44%. Complications from screening (k=2, n=220,480). Complications from CA-125 testing were generally minor and ranged from 0.86 per 10,000 screens to 58.3 per 10,000 women. False positive surgery (k=2, n=173,858). False positive surgeries occurred in 0.2% to 1% of those screened with CA-125. Complications from false positive surgery (k=2, n=173,858). 1 larger trial (n=151,923) reported complications in 3.1% of false positive surgeries. 1 smaller trial (n= n=21,935) reported no surgical complications. Psychological effects of screening (k=1, n=13,413). Psychological harms reported in a subset of 1 trial. No statistically significant differences were found in psychological outcomes between the screening and no screening arms; increased psychological morbidity risk among women recalled for higher level screening. | Reasonably consistent or NA Reasonably precise | Undetected | Good | Psychological harms measured only for subsets of trial participants | Moderate (Low for psychological harms) | Trial evidence from the U.K. where screening occurred in specialized trial settings and cancer treatment provided through the National Health Service, which is a more centralized health system relative to the U.S.
Annual screening with transvaginal ultrasound examination | k=2 n =220,479 RCT | False positive rate and complications from screening (k=1, n=151,922). A false positive rate of 11.9% was reported in initial screening round. Complications from screening (k=2, n=220,479). Complications from screening with TVU ranged from 1.86 per 10,000 screens to 3.3 per 10,000 women. False positive surgery (k=1, n=151,922). False positive surgeries occurred in 3.2% of those screened with TVU. Complications from false positive surgery (k=1, n=151,922). Complications occurred in 3.5% of false positive surgeries. Psychological effects of screening (k=1, n=10,716). Psychological harms were reported in a subset of 1 trial. No statistically significant differences were found in psychological outcomes between the screening and no screening arms. | Reasonably consistent or NA Reasonably precise | Undetected | Good | Psychological harms measured only for subsets of trial participants Data on cumulative false positive rate not reported | Moderate (Low for psychological harms) | Screening conducted inspecialized trial centers Treatment for cancer (in all study arms) was through the centralized National Health Service system in U.K. and in community care settings in U.S.
Annual screening with CA-125 testing and transvaginal ultrasound examination | k=2 n=69,106 RCT | False positive rate and complications from screening (k=1, n=68,557). False positive screening rate of 9.8% over the course of the screening program. Complications from screening (see complication rates for individual components). False positive rate for screen positive surgery (k=1, n=68,557). False positive surgeries occurred in 3.17% of those screened. Complications from false positive surgery (k=1, n=68,557). Complications occurred in 15.09% of false positive surgeries. Psychological effects of screening (k=1, n=549). Women with abnormal test results (n=32) compared with women with no abnormal results more likely to report cancer worry at 2 year followup (OR 2.8; 95% CI, 1.1 to 7.2). | Consistency NA Reasonably precise (except psychological harms imprecise) | Undetected | Fair to Good | Psychological harms measured only for subsets of trial participants | Moderate (Low for psychological harms) | U.S. based, multisite trial Pragmatic trial with usual care control condition and referral to community clinicians for screen positives Majority white, non-Hispanic participants

Abbreviations: CA-125 = cancer antigen 125; CI = confidence interval; EPC = evidence-based practice center; FDA = U.S. Food and Drug Administration; HR = hazard ratio; KQ = key question; NA = not applicable; OR = odds ratio; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; QUEST = Quality of life, Education, and Screening Trial; RCT = randomized controlled trial; RR = rate ratio; TVU = transvaginal ultrasound; UKCTOCS = U.K. Collaborative Trial of Ovarian Cancer Screening; U.S. = United States

False positive surgeries, defined as surgery following a positive screen among women found to have normal or benign adnexa, occurred in nearly 1 percent of those in the CA-125 ROCA arm of the UKCTOCS^92^ (n = 488) and 0.2 percent of those screened in the U.K. Pilot (n=23).^98^ In the UKCTOCS, one or more major complication occurred in 3.1 percent of false positive surgeries in the CA-125 ROCA arm and included: infection, injury to hollow viscus, anesthetic complications, and cardiovascular and pulmonary events.^92^ No surgical complications were reported among the women undergoing surgical investigations in the U.K. Pilot trial.^98^

##### Ultrasound Screening

False positive rates calculated based on the results of the initial screening using ultrasound occurred in 11.9 percent in the prevalence screening round of the UKCTOCS^68^ (Table 6). The false positive rate from subsequent rounds was not reported for this arm. Complications from transvaginal ultrasound screening in the UKCTOCS included pain, cystitis or other infection, discomfort, bruising, and fainting, as well as others (unspecified), among 1.86 per 10,000 screens.^92^ In the PLCO complications from transvaginal ultrasound occurred in 3.3 per 10,000 women.^91^

False positive surgeries (benign findings on a screen positive investigation) occurred in 3.2 percent of women in the ultrasound arm of the UKCTOCS.^92^ Major complications occurred in 3.5 percent of these surgeries and included: injury to hollow viscus, hemorrhage, anesthetic complication/myocardial infarction, hernia, deep vein thrombosis/pulmonary embolism, wound breakdown, bowel obstruction, wound/supravaginal hematoma, infection, and pain with readmission or further operation.^92^

##### Combined CA-125 and Ultrasound Screening

The combined CA-125 and ultrasound intervention used for the PLCO^91^ had a 9.6 percent cumulative false positive rate across all rounds of screening (Table 6). Complications from each screening component are discussed above.

False positive surgeries (benign findings on a screen positive investigation) occurred in 3.2 percent of women undergoing combination screening in the PLCO. Major complications occurred in 15.1 percent of surgeries, with benign findings in the PLCO including: infection, direct surgical harms, cardiovascular/pulmonary events, and other adverse events that were not specified. ^91^

#### Deaths From Other Causes

The UKCTOCS provided data on causes of death other than ovarian cancer, and the PLCO provided data on causes of death other than ovarian, colorectal, and lung cancers. There were no statistically significant differences in causes of death in screening arms compared with control arms.

#### Psychological Harms of Screening

A study of the psychological morbidity associated with ovarian cancer screening was undertaken within the UKCTOCS (n=23,374).^104^ A random sample of women was drawn at baseline from each trial arm (n=1,339) and a survey was administered annually for 7 years to obtain variables for evaluating psychological effects of screening. Similar data were also collected for women in the screening arms who were at any time recalled for followup testing (CA-125 ROCA: n = 12,357; ultrasound: n = 9,678). For the event group, upon abnormal results and recall, questionnaires were administered, and thereafter on an annual basis.^104^ The main measures were the Spielberger State/Trait Anxiety Inventory (STAI)^105^ and the General Health Questionnaire 12 (GHQ-12)^106^ for evaluating psychological morbidity. A small but statistically significant difference in the education levels of women between the ROCA screening and ultrasound group of the random samples was observed, and in the event sample more women reported hormone replacement therapy use than in the random sample (21% versus 14%, p<.001).^104^ In light of these unexpected imbalances, the study authors recommended cautious interpretation of findings. In adjusted analyses with linear and logistic regression, no statistically significant differences in mean STAI or the risk of psychological morbidity (GHQ-12 ≥ 4) were observed between the control and intervention arms in the random sample. In the analysis of women with recall screening events, there was a statistically significant increased risk of psychological morbidity among women recalled for higher-level screening (adjusted OR 1.28 [95% CI, 1.18 to 1.39]).^104^

The QUEST^97^ trial analyzed 549 average-risk women age 30 years or older in the United States to examine the effect of ovarian cancer screening on cancer worry and QoL. Women were randomized to ovarian cancer screening, risk counseling, or a screening/risk counseling combination compared to a usual care-only protocol consisting of annual pelvic examination and routine education by a woman's primary care physician. We report only on results from the screening and usual care control arms of the trial (n = 442). Ovarian cancer screening consisted of alternating CA-125 measurement and TVU every 6 months for a maximum of 4 screening rounds. Overall, women had a high level of education, with 99 percent completing high school and 95 percent attending college. The QUEST^97^ study found no statistically significant differences for QoL measured with the SF-36, distress measured with the Impact of Events Scale, or cancer worry measured with a modified Lerman cancer worry scale. The only significant effect observed in participants was a higher level of cancer worry after 2 years among those who had experienced any abnormal test results.^97^