# Chapter 2 Methods

## Scope and Purpose

This systematic review addresses the benefits and harms of screening for ovarian cancer in women at average risk for ovarian cancer. The USPSTF will use this review to update its 2012 recommendation on this topic.^74^

## Key Questions and Analytic Framework

We developed an Analytic Framework (Figure 1) and two Key Questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework and Key Questions

1. Does screening for ovarian cancer in asymptomatic women using a single test or combined algorithm [such as, but not limited to, testing for serum cancer antigen [CA–125] and ultrasonography] reduce all-cause or disease-specific morbidity and mortality?
2. What are the harms of screening for ovarian cancer, including harms of the screening test and of diagnostic evaluation?

The figure is an analytic framework that depicts the two Key Questions described in the Research Plan: whether screening for ovarian cancer in asymptomatic women age 45 years or older leads to changes in all-cause or disease-specific mortality and morbidity (Key Question 1) or potential harms (Key Question 2).

1. Does screening for ovarian cancer in asymptomatic women using a single test or combined algorithm (such as, but not limited to, testing for serum cancer antigen [CA–125] and ultrasonography) reduce all-cause or disease-specific morbidity and mortality?
2. What are the harms of screening for ovarian cancer, including harms of the screening test and of diagnostic evaluation?

## Data Sources and Searches

In addition to considering all studies from the previous reviews on this topic^83-85^ for inclusion in the current review, we performed a comprehensive search of MEDLINE, PubMed Publisher-Supplied Records, and the Cochrane Collaboration Registry of Controlled Trials. We searched between January 1, 2003 and January 31, 2017, building upon the most recent full search for this topic.^85^

We worked with a research librarian to develop our search strategy, which was peer-reviewed by a second research librarian (Appendix A). All searches were limited to articles published in English. We managed literature search results using version X7 of Endnote® (Thomson Reuters, New York, NY), a bibliographic management software database.

To ensure comprehensiveness, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published before our search dates or were not identified in our literature searches.^86, 87^

## Study Selection

Two reviewers independently reviewed the title and abstracts of all identified articles using Abstrackr^88^ to determine if the study met our a priori inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A). Two reviewers then independently evaluated the full-text article(s) of all potentially relevant studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion.

For both KQs we considered randomized controlled trials in asymptomatic average risk women, including women of unknown risk, aged 45 and older. Studies focused on screening explicitly among high-risk populations (e.g., BRCA mutation carriers, individuals with first-degree relatives with ovarian cancer) were excluded from this review. We included any screening intervention conducted in primary care settings (including obstetrics and gynecology practices) compared with usual care or no screening. When available, as is the case for ovarian cancer screening, RCT evidence was prioritized, particularly when adequately powered to evaluate screening for a rare cancer. Trials that addressed only the accuracy of screening and cancer detection rates without reporting morbidity, mortality, or quality of life data were not included in this review.

For KQ 1 we considered a range of outcomes including: ovarian cancer-specific mortality (including primary peritoneal and fallopian tube cancer), cancer-related morbidity, and quality of life. KQ 2 included the following harms outcomes: mortality from other causes, rates of surgery, rates of false positive screening results, complications of diagnostic surgical procedures, and health and psychological effects of screening tests. Evidence of potential harms associated with screening was limited to trials reporting health outcomes. Effects of screening on quality of life are evaluated as a potential benefit or harm, but this outcome was reported only for harms. Importantly, direct trial evidence on the health outcomes associated with different screening programs (including not screening) offers the summary or net effect of harms and benefits of screening. Disease specific mortality is the key outcome for ovarian cancer rather than all-cause mortality because of the rarity of ovarian cancer, and because the mortality rates from ovarian cancer are quite high. Due to its rarity, ovarian cancer screening intervention effect sizes would not be expected to be large enough to have discernable effects on all-cause mortality. Nevertheless, it is important to compare mortality across study arms to determine whether there are any unexpected increases in other causes of mortality from the screening program, to assess for problems with coding or discernment of cause of death in the trial procedures, and to evaluate whether differential study continuation resulted in unrecognized study arm imbalances in participant risk of death.

## Quality Assessment and Data Abstraction

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF^89^. Disagreements in quality were resolved by discussion. Each study was given a final quality rating of good, fair, or poor.

Good-quality RCTs had adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar baseline characteristics between groups, low attrition (≥90% of participants had followup data with <10 percentage point difference in loss to followup between groups), used intention-to-screen analysis, and reported diagnostic criteria for outcome ascertainment. We rated trials as fair quality if they were unable to meet the majority of the good-quality criteria. We rated trials as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points, or if there were any other “fatal” flaws that seriously affected internal validity, as agreed upon by two independent investigators. Poor quality studies were excluded from this review.

We abstracted data from all included studies into standard evidence tables using Microsoft Word® (Microsoft Corporation, Redmond, WA). A second reviewer checked the data for accuracy. We abstracted information on study design, baseline data, intervention details, health outcomes, and adverse events.

## Data Synthesis and Analysis

Given the small number of studies and heterogeneity of screening interventions, meta-analyses were not conducted for any of the KQs in this report. We instead conducted a narrative synthesis of the results by screening strategy. We generated summary tables and descriptive text detailing the populations and protocols of included studies, and the interventions and followup procedures of the included trials. The pre-specified outcomes sought for this review were abstracted from each study, by key question, and results were presented in groups defined by the screening strategy. The selected pre-specified outcomes were prioritized for abstraction even when they were not the primary outcome of the included studies. Some outcomes were calculated from raw data reported in study publications where needed to adhere to Task Force priorities or to facilitate comparability across trials. As a result, some results reported in this review may differ from the findings highlighted in the main results of the original publications.

In 2014, the World Health Organization revised the classification of tumors of the female reproductive system. Following these revisions, most cancers historically classified as peritoneal cancer would be reclassified as ovarian and tubal cancers. Analyses with both ovarian and peritoneal cancer were prioritized, since their presentation and treatment are not distinct in clinical practice and because they are often difficult to distinguish pathologically.^90^ Ovarian cancer was defined as primary ovarian, peritoneal, and fallopian tube cancers in the Prostate, Lung, Colorectal and Ovarian (PLCO). The U.K. Collaborative Trial of Ovarian Cancer Screening (UKCTOCS) also reported results for this outcome, but excluded primary peritoneal cancer from primary analyses. We have noted where we have calculated results that included peritoneal cancer using raw numbers reported in the UKCTOCS. Data from the U.K. Pilot trial did not capture information related to peritoneal cancer; therefore, these results are limited to primary cancer of the ovary and fallopian tubes.

The number of participants stated throughout the report refers to the number analyzed, unless otherwise stated. The tables report both the n randomized and the n analyzed.

Data on false positive rates were calculated as the percent of those without ovarian cancer who received a positive test result. The PLCO^91^ defined a positive screen based on the results of the initial screening tests (i.e., positive on TVU or CA-125 screening test). In the UKCTOCS^92^ a positive screen was defined as a positive initial screen that eventually led to surgery. The definition used in the PLCO, where the screening test result defines test positives, is consistent with the USPSTF interest in evaluating how the initial test sets in motion a cascade of effects.^93^ Each definition, however, provides slightly different insights, so we calculated and report false positive rates based on both definitions.

In accordance with the CONSORT scientific standards for the design and analysis of randomized controlled trials, when multiple statistical tests are reported to test comparisons between trial arms, we prioritize statistical tests defined a priori in the trial protocol.^94^

When reporting study results from the two large trials included in this review, we aimed to provide comparable statistics, and have noted where this required additional calculations.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach^95^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^96^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan was posted for public comment on the USPSTF Web site from March 26, 2015, to April 22, 2015. The USPSTF received several comments about the population under consideration, particularly an interest in including women with specific genetic risk factors. Considerations for these populations are generally outside the scope of a review of a broad screening program among asymptomatic women at average risk for ovarian cancer; therefore, the included population for this topic was not changed. Several comments sought clarification on the analytic framework. In response, the USPSTF simplified the analytic framework to focus on direct evidence from screening trials. A few comments requested that specific screening interventions be evaluated. The USPSTF clarified the inclusion criteria to indicate that all screening tests and approaches evaluated in clinical trials will be included, and added a contextual question to consider whether there are promising screening approaches not yet evaluated by clinical trials. A final research plan was posted on the USPSTF's Web site on March 3, 2015.

A draft report was shared with invited expert reviewers and federal partners (see Acknowledgements) and their comments were compiled and addressed (where appropriate) in our report posted for public comment. The preliminary draft of the full report was posted for public comment on the USPSTF Web site from July 18, 2017 through August 14, 2017. A few commenters, raised concerns about the manner in which the review characterized the CA-125 ROCA screening algorithm. Following usual USPSTF procedures for evaluating screening programs, the screening test women would experience each year in the screening program was consider the screening test, and any followup tests that occur on the basis of that result are considered followup on a positive result. Some commenters preferred evaluating the combined effects of screening and followup when considering the potential harms of false positive results. Revisions to the Evidence Synthesis include clearer explanation of the approach, and more detail on the differences in the extent to which trials followed strict followup protocols (as in UKCTOCS) versus those that referred women to community practices where the followup was inevitably more variable (as in PLCO). The initial report, and the final version included the false positive results for both the annual screening test (screening false positive rate) and the combined effect of screening and followup on rates of referral to diagnostic surgery (surgery false positive rate). Providing both of these outcomes, whether or not they were reported as key outcomes in the trials, allows comparability between trials and additional information for discussion.

Commentators also requested further explication of the choice of study outcomes (ovarian cancer as defined by international criteria including ovarian, fallopian tube, and peritoneal cases) and analyses, particularly from the UKCTOCS trial. Several exploratory analyses are discussed in our Final report, along with further justification for a focus on complete intention-to-treat statistical analysis, preferably with study arms comparisons with prespecified statistical tests. Nevertheless, the report highlights the importance of continuing to evaluate the results of trials as new information comes to light that would either strengthen or dampen potential effects observed in exploratory analyses.

Overall, in response to valuable input from public comment and federal partners, the report was revised for clarity, to further explain our methods and decisions regarding the scope and focus of our synthesis.

## USPSTF Involvement

We worked with USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.