# Appendix D Benefits Reported in Ovarian Cancer Screening Trials: Ovarian Cancer Mortality in Analyses Excluding Peritoneal Cancer^*^

Trial, Year of publication | UKCTOCS, 2016 (CA-125 ROCA arm)^92^ | UKCTOCS, 2016 (ultrasound arm)^92^ | PLCO, 2011^91^ | U.K. Pilot, 1999^98^
Quality | Good | Good | Good | Good
N analyzed per arm | IG: 50,624 CG: 101,299 | IG: 50,623 CG: 101,299 | IG: 34,253 CG: 34,304 | IG: 10,958 CG: 10,977
Ovarian cancer incidence, n (%) | IG: 338 (0.7) CG: 630 (0.6) | IG: 314 (0.6) CG: 630 (0.6) | IG: 183 (0.5) CG: 158 (0.5) | IG: 16 (0.1) CG: 20 (0.2)
Ovarian cancer incidence rate | IG: 6.2 per 10,000 p-y CG: 5.7 per 10,000 p-y | IG: 5.7 per 10,000 p-y CG: 5.7 per 10,000 p-y | IG: 4.9 per 10,000 p-y CG: 4.7 per 10,000 p-y | NR
Between group difference | p=NR | p=NR | p=NR
Ovarian cancer mortality, n (%) | IG: 148 (0.29) CG: 347 (0.34) | IG: 163 (0.30) CG: 347 (0.34) | NR | IG: 9 (0.082) CG: 18 (0.16)
Ovarian cancer mortality rate | IG: 2.7 per 10,000 p-y CG: 3.2 per 10,000 p-y | IG: 2.8 per 10,000 p-y CG: 3.2 per 10,000 p-y | NR | NR
Ovarian cancer mortality between group difference | HR: 0.85 (95% CI, 0.70 to 1.03), p=0.10^†^ | HR: 0.89 (0.73, 1.07), p=0.21^†^ | NR | RR: 0.50 (95% CI, 0.22 to 1.11) p=0.083^‡^

* Includes ovarian and fallopian cancers

† Cox proportional hazards model

‡ Calculated (article reports RR calculated in in terms of increased relative risk)

Abbreviations: CG = control group; CI = confidence interval; HR = hazard ratio; IG = intervention group; NR = not reported; NS = not significant; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; P-Y = person-years; ROCA = Risk of Ovarian Cancer Algorithm; RR = relative risk; U.K. = United Kingdom; UKCTOCS: U.K. Collaborative Trial of Ovarian Cancer Screening