# Appendix C Excluded Studies

Reason for Exclusion^*^
E1. | Study aim
E2. | Study design (not RCT)
E3a. | Setting: Not conducted in a ‘very high’ HDI country
E3b. | Setting: Not primary care
E4a. | Population: High-risk (genetic or family history)
E4b. | Population: Symptomatic
E5. | No relevant outcomes or incomplete outcomes
E5a. | Detection rate only
E6. | Study quality: Poor quality rating
E7. | Language: Publication not in English
E8. | Intervention is not a screening test (i.e., staging, prognostic testing)

* Assigned at abstract and full-text phase

Abbreviations: E = exclude; HDI = human development index; KQ = key question; RCT = randomized, controlled trial

1 European randomized trial of ovarian cancer screening (protocol). London: 1995. PMID: KQ1E5, KQ2E5.
2 Screening CA-125 and transvaginal ultrasound does not reduce ovarian cancer mortality. J Natl Med Assoc. 2012;104(1-2):116-7. KQ1E1, KQ2E1.
3 Adonakis GL, Paraskevaidis E, Tsiga S, . A combined approach for the early detection of ovarian cancer in asymptomatic women. Eur J Obstet Gynecol Reprod Biol. 1996;65(2):221-5. KQ1E2, KQ2E2.8730628
4 Akulenko LV, Gar'kavtseva RF, Zhordania KI, . [Current status and perspectives for genetic consultation and prophylactic medical examination of risk groups with malignant neoplasms of the female reproductive system and breast]. TSitologiia i genetika. 1992;26(1):38-42. KQ1E2, KQ2E2.1621284
5 Andolf E, Svalenius E, Astedt B. Ultrasonography for early detection of ovarian carcinoma. Br J Obstet Gynaecol. 1986;93(12):1286-9. PMID: 3542015. KQ1E2, KQ2E2.3542015
6 Belinson JL, Okin C, Casey G, . The familial ovarian cancer registry: progress report. Cleve Clin J Med. 1995;62(2):129-34. PMID: 7736630. KQ1E2, KQ2E2.7736630
7 Bell R, Petticrew M, Luengo S, . Screening for ovarian cancer: a systematic review. Health Technol Assess. 1998;2(2):i-iv, 1-84. PMID: 9561894. KQ1E2, KQ2E2.9561894
8 Bourne TH, Campbell S, Reynolds K, . The potential role of serum CA 125 in an ultrasound-based screening program for familial ovarian cancer. Gynecol Oncol. 1994;52(3):379-85. PMID: 8157195. KQ1E2, KQ2E2.8157195
9 Bourne TH, Campbell S, Reynolds KM, . Screening for early familial ovarian cancer with transvaginal ultrasonography and colour blood flow imaging. BMJ. 1993;306(6884):1025-9. PMID: 8490496. KQ1E2, KQ2E2.8490496
10 Burnell M, Gentry-Maharaj A, Ryan A, . Impact on mortality and cancer incidence rates of using random invitation from population registers for recruitment to trials. Trials. 2011;12:61. PMID: 21362184. KQ1E5, KQ2E5.21362184
11 Campbell S, Bhan V, Royston P, . Transabdominal ultrasound screening for early ovarian cancer. BMJ. 1989;299(6712):1363-7. PMID: 2513964. KQ1E2, KQ2E2.2513964
12 Demidov VN, Krasnikova SP, Terskaia LV. [Role of echography in early detection of ovarian tumors]. Vopr Onkol. 1990;36(11):1365-8. PMID: 2281643. KQ1E2, KQ2E2.2281643
13 Dorum A, Kristensen GB, Abeler VM, . Early detection of familial ovarian cancer. Eur J Cancer. 1996;32a(10):1645-51. KQ1E2, KQ2E2.8983269
14 Drescher C, Nelson J, Peacock S, . Compliance of average- and intermediate-risk women to semiannual ovarian cancer screening. Cancer Epidemiol Biomarkers Prev. 2004;13(4):600-6. KQ1E5, KQ2E5.15066925
15 Gentry-Maharaj A, Sharma A, Burnell M, . Acceptance of transvaginal sonography by postmenopausal women participating in the United Kingdom Collaborative Trial of Ovarian Cancer Screening. Ultrasound Obstet Gynecol. 2013;41(1):73-9. PMID: 22791597. KQ1E5, KQ2E5.22791597
16 Gohagan JK, Prorok PC, Hayes RB, . The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute: history, organization, and status. Controlled clinical trials. 2000;21(6 Suppl):251s-72s. PMID: 11189683. KQ1E5, KQ2E5.11189683
17 Goswamy RK, Campbell S, Whitehead MI. Screening for ovarian cancer. Clinics in obstetrics and gynaecology. 1983;10(3):621-43. PMID: 6653033. KQ1E2, KQ2E2.6653033
18 Gren L, Broski K, Childs J, . Recruitment methods employed in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Clin. 2009;6(1):52-9. PMID: 19254935. KQ1E5, KQ2E5.19254935
19 Grover S, Quinn MA, Weideman P, . Screening for ovarian cancer using serum CA125 and vaginal examination: report on 2550 females. Int J Gynecol Cancer. 1995;5(4):291-5. PMID: 11578492. KQ1E2, KQ2E2.11578492
20 Holbert TR. Screening transvaginal ultrasonography of postmenopausal women in a private office setting. Am J Obstet Gynecol. 1994;170(6):1699-703; discussion 703-4. PMID: 8203429. KQ1E2, KQ2E2.8203429
21 Jacobs I, Stabile I, Bridges J, . Multimodal approach to screening for ovarian cancer. Lancet. 1988;1(8580):268-71. PMID: 2893084. KQ1E2, KQ2E2.2893084
22 Johnson D. The effects of an abnormal cancer screening test on health related quality of life. Int J Cancer Res. 2006;2:277-89. KQ1E5, KQ2E5.
23 Karlan BY, Raffel LJ, Crvenkovic G, . A multidisciplinary approach to the early detection of ovarian carcinoma: rationale, protocol design, and early results. Am J Obstet Gynecol. 1993;169(3):494-501. PMID: 8372851. KQ1E2, KQ2E2.8372851
24 Kobayashi H, Yamada Y, Sado T, . A randomized study of screening for ovarian cancer: a multicenter study in Japan. Int J Gynecol Cancer. 2008;18(3):414-20. PMID: 17645503. KQ1E5, KQ2E5.17645503
25 Kurjak A, Shalan H, Kupesic S, . An attempt to screen asymptomatic women for ovarian and endometrial cancer with transvaginal color and pulsed Doppler sonography. J Ultrasound Med. 1994;13(4):295-301. KQ1E2, KQ2E2.7932995
26 Lacey J, Greene M, Buys S, . Ovarian cancer screening in women with a family history of breast or ovarian cancer. Obstet Gynecol. 2006;108(5):1176-84. KQ1E5, KQ2E5.17077240
27 Lacey JV Jr, Greene MH, Buys SS, . Ovarian cancer screening in women with a family history of breast or ovarian cancer. Obstet Gynecol. 2006;108(5):1176-84. PMID: 17077240. KQ1E5, KQ2E5.17077240
28 Markman M, Petersen J, Belland A, . CA-125 monitoring in ovarian cancer: patient survey responses to the results of the MRC/EORTC CA-125 Surveillance Trial. Oncology. 2010;78(1):1-2. KQ1E1, KQ2E1.
29 Menon U, Burnell M, Sharma A, . Decline in use of hormone therapy among postmenopausal women in the United Kingdom. Menopause. 2007;14(3 Pt 1):462-7. PMID: 17237735. KQ1E5, KQ2E5.17237735
30 Menon U, Gentry-Maharaj A, Ryan A, . Recruitment to multicentre trials--lessons from UKCTOCS: descriptive study.[Erratum appears in BMJ. 2008;337:a2976]. BMJ. 2008;337:a2079. PMID: 19008269. KQ1E5, KQ2E5.19008269
31 Menon U, Skates SJ, Lewis S, . Prospective study using the risk of ovarian cancer algorithm to screen for ovarian cancer. J Clin Oncol. 2005;23(31):7919-26. PMID: 16258091. KQ1E5, KQ2E5.16258091
32 Miller RW, Pavlik EJ, Baldwin LA, . Complications from surgeries prompted by ovarian cancer screening. Gynecol Oncol. 2015;137:180. PMID: None. KQ1E2, KQ2E2.25636459
33 Millo R, Facca MC, Alberico S. Sonographic evaluation of ovarian volume in postmenopausal women: a screening test for ovarian cancer? Clin Exp Obstet Gynecol. 1989;16(2-3):72-8. PMID: 2667810. KQ1E2, KQ2E2.2667810
34 Muto MG, Cramer DW, Brown DL, . Screening for ovarian cancer: the preliminary experience of a familial ovarian cancer center. Gynecol Oncol. 1993;51(1):12-20. PMID: 8244166. KQ1E2, KQ2E2.8244166
35 Nyante SJ, Black A, Kreimer AR, . Pathologic findings following false-positive screening tests for ovarian cancer in the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial. Gynecol Oncol. 2011;120(3):474-9. PMID: 21144559. KQ1E5, KQ2E5.21144559
36 Parkes CA, Smith D, Wald NJ, . Feasibility study of a randomised trial of ovarian cancer screening among the general population. J Med Screen. 1994;1(4):209-14. PMID: 8790521. KQ1E5, KQ2E5.8790521
37 Partridge EE, Greenlee RT, Riley TL, . Assessing the risk of ovarian malignancy in asymptomatic women with abnormal CA 125 and transvaginal ultrasound scans in the prostate, lung, colorectal, and ovarian screening trial. Obstet Gynecol. 2013;121(1):25-31. PMID: 23262924. KQ1E5, KQ2E5.23262924
38 Pinsky PF, Ford M, Gamito E, . Enrollment of racial and ethnic minorities in the Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial. J Natl Med Assoc. 2008;100(3):291-8. PMID: 18390022. KQ1E5, KQ2E5.18390022
39 Pinsky PF, Miller A, Kramer BS, . Evidence of a healthy volunteer effect in the prostate, lung, colorectal, and ovarian cancer screening trial. Am J Epidemiol. 2007;165(8):874-81. PMID: 17244633. KQ1E5, KQ2E5.17244633
40 Prorok PC, Andriole GL, Bresalier RS, . Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):273s-309s. PMID: 11189684. KQ1E5, KQ2E5.11189684
41 Reding D, Fouad M, Ragard L, . Prevalence, incidence and natural history of simple ovarian cysts within the context of a large cancer screening trial. J Clin Oncol. 2008;26(15 suppl):5571. PMID: 27950424. KQ1E5, KQ2E5.
42 Robertson DM. Screening for the early detection of ovarian cancer. Womens Health. 2009;5(4):347-9. KQ1E2, KQ2E2.
43 Rufford BD, Jacobs IJ, Menon U. Feasibility of screening for ovarian cancer using symptoms as selection criteria. BJOG. 2007;114(1):59-64. PMID: 17233861. KQ1E4b, KQ2E4b.17233861
44 Sato S, Hasuo Y, Ohta S, . [Mass-screening for ovarian cancer by means of transvaginal ultrasonography]. Nihon Sanka Fujinka Gakkai zasshi. 1992;44(6):683-8. PMID: 1506730. KQ1E2, KQ2E2.1506730
45 Sato S, Yokoyama Y, Sakamoto T, . Usefulness of mass screening for ovarian carcinoma using transvaginal ultrasonography. Cancer. 2000;89(3):582-8. PMID: 10931457. KQ1E2, KQ2E2.10931457
46 Schincaglia P, Brondelli L, Cicognani A, . A feasibility study of ovarian cancer screening: does fine-needle aspiration improve ultrasound specificity? Tumori. 1994;80(3):181-7. PMID: 8053074. KQ1E2, KQ2E2.8053074
47 Schwartz PE, Chambers JT, Taylor KJ. Early detection and screening for ovarian cancer. J Cell Biochem Suppl. 1995;23:233-7. PMID: 8747402. KQ1E2, KQ2E2.8747402
48 Sharma A, Apostolidou S, Burnell M, . Risk of epithelial ovarian cancer in asymptomatic women with ultrasound-detected ovarian masses: a prospective cohort study within the UK collaborative trial of ovarian cancer screening (UKCTOCS). Ultrasound Obstet Gynecol. 2012;40(3):338-44. PMID: 22911637. KQ1E5, KQ2E5.22911637
49 Sharma A, Burnell M, Gentry-Maharaj A, . Factors affecting visualization of postmenopausal ovaries: descriptive study from the multicenter United Kingdom Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Ultrasound Obstet Gynecol. 2013;42(4):472-7. PMID: 23456790. KQ1E5, KQ2E5.23456790
50 Sharma A, Gentry-Maharaj A, Burnell M, . Assessing the malignant potential of ovarian inclusion cysts in postmenopausal women within the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS): a prospective cohort study. BJOG. 2012;119(2):207-19. PMID: 21762355. KQ1E5, KQ2E5.21762355
51 Tabor A, Jensen FR, Bock JE, . Feasibility study of a randomised trial of ovarian cancer screening. J Med Screen. 1994;1(4):215-9. PMID: 8790522. KQ1E5, KQ2E5.8790522
52 Taylor KL, Shelby R, Gelmann E, . Quality of life and trial adherence among participants in the prostate, lung, colorectal, and ovarian cancer screening trial. J Natl Cancer Inst. 2004;96(14):1083-94. PMID: 15265970. KQ1E5, KQ2E5.15265970
53 van Nagell JR, Jr., DePriest PD, Reedy MB, . The efficacy of transvaginal sonographic screening in asymptomatic women at risk for ovarian cancer. Gynecol Oncol. 2000;77(3):350-6. PMID: 10831341. KQ1E2, KQ2E2.10831341
54 van Nagell JR Jr, Gallion HH, Pavlik EJ, . Ovarian cancer screening. Cancer. 1995;76(10 Suppl):2086-91. PMID: 8635005. KQ1E2, KQ2E2.8635005
55 Vuento MH, Pirhonen JP, Makinen JI, . Evaluation of ovarian findings in asymptomatic postmenopausal women with color Doppler ultrasound. Cancer. 1995;76(7):1214-8. KQ1E2, KQ2E2.8630900
56 Vuento MH, Stenman UH, Pirhonen JP, . Significance of a single CA 125 assay combined with ultrasound in the early detection of ovarian and endometrial cancer. Gynecol Oncol. 1997;64(1):141-6. PMID: 8995563. KQ1E2, KQ2E2.8995563
57 Weiner Z, Beck D, Shteiner M, . Screening for ovarian cancer in women with breast cancer with transvaginal sonography and color flow imaging. J Ultrasound Med. 1993;12(7):387-93. PMID: 8355333. KQ1E2, KQ2E2.8355333