# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

1. Andersen MR, Drescher CW, Zheng Y, . Changes in cancer worry associated with participation in ovarian cancer screening. Psychooncology. 2007;16(9):814-20. PMID: 17225260. http://dx.doi.org/10.1002/pon.1151 17225260
  a. Drescher CW, Nelson J, Peacock S, . Compliance of average- and intermediate-risk women to semiannual ovarian cancer screening. Cancer Epidemiol Biomarkers Prev. 2004;13(4):600-6. PMID: 1506692515066925 .
2. Buys SS, Partridge E, Black A, . Effect of screening on ovarian cancer mortality: The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Randomized Controlled Trial. JAMA. 2011;305(22):2295-303. PMID: 21642681. http://dx.doi.org/10.1001/jama.2011.766 21642681
  a. Lai T, Kessel B, Ahn HJ, . Ovarian cancer screening in menopausal females with a family history of breast or ovarian cancer. J. 2016;27(4):e41. PMID: 27102249. https://dx.doi.org/10.3802/jgo.2016.27.e41 27102249
  b. Buys SS, Partridge E, Greene MH, . Ovarian cancer screening in the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial: findings from the initial screen of a randomized trial. Am J Obstet Gynecol. 2005;193(5):1630-9. PMID: 16260202. http://dx.doi.org/10.1016/j.ajog.2005.05.005 16260202
  c. Croswell JM, Kramer BS, Kreimer AR, . Cumulative incidence of false-positive results in repeated, multimodal cancer screening. Ann Fam Med. 2009;7(3):212-22. PMID: 19433838. http://dx.doi.org/10.1370/afm.942 19433838
  d. Partridge E, Kreimer AR, Greenlee RT, . Results from four rounds of ovarian cancer screening in a randomized trial. Obstet Gynecol. 2009;113(4):775-82. PMID: 19305319. http://dx.doi.org/10.1097/AOG.0b013e31819cda77 19305319
  e. Pinsky PF, Yu K, Kramer BS, . Extended mortality results for ovarian cancer screening in the PLCO trial with median 15years follow-up. Gynecol Oncol. 2016. PMID: 27615399. http://dx.doi.org/10.1016/j.ygyno.2016.08.334 27615399
  f. Pinsky PF, Zhu C, Skates SJ, . Potential effect of the risk of ovarian cancer algorithm (ROCA) on the mortality outcome of the Prostate, Lung, Colorectal and Ovarian (PLCO) trial. Int J Cancer. 2013;132(9):2127-33. PMID: 23065684. http://dx.doi.org/http://dx.doi.org/10.1002/ijc.27909 23065684
3. Jacobs IJ, Menon U, Ryan A, . Ovarian cancer screening and mortality in the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS): a randomised controlled trial. Lancet. 2016;387(10022):945-56. PMID: 26707054. 10.1016/s0140-6736(15)01224-626707054
  a. Barrett J, Jenkins V, Farewell V, . Psychological morbidity associated with ovarian cancer screening: results from more than 23,000 women in the randomised trial of ovarian cancer screening (UKCTOCS). BJOG. 2014;121(9):1071-9. PMID: 24865441. http://dx.doi.org/10.1111/1471-0528.12870 24865441
  b. Jenkins V, Fallowfield L, Langridge C, . Psychosocial Factors Associated With Withdrawal From the United Kingdom Collaborative Trial of Ovarian Cancer Screening After 1 Episode of Repeat Screening. Int J Gynecol Cancer. 2015;25(8):1519-25. PMID: 26222482. http://dx.doi.org/10.1097/IGC.0000000000000507 26222482
  c. Menon U, Gentry-Maharaj A, Hallett R, . Sensitivity and specificity of multimodal and ultrasound screening for ovarian cancer, and stage distribution of detected cancers: results of the prevalence screen of the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Lancet Oncol. 2009;10(4):327-40. PMID: 19282241. http://dx.doi.org/10.1016/S1470-2045(09)70026-9 19282241
  d. Menon U, Ryan A, Kalsi J, . Risk Algorithm Using Serial Biomarker Measurements Doubles the Number of Screen-Detected Cancers Compared With a Single-Threshold Rule in the United Kingdom Collaborative Trial of Ovarian Cancer Screening. J Clin Oncol. 2015;33(18):2062-71. PMID: 25964255. 10.1200/JCO.2014.59.494525964255
  e. Sharma A, Burnell M, Gentry-Maharaj A, . Quality assurance and its impact on ovarian visualization rates in the multicenter United Kingdom Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Ultrasound Obstet Gynecol. 2016;47(2):228-35. PMID: 26095052. http://dx.doi.org/10.1002/uog.14929 26095052
4. Jacobs IJ, Skates SJ, MacDonald N, . Screening for ovarian cancer: a pilot randomised controlled trial. Lancet. 1999;353(9160):1207-10. PMID: 10217079. http://dx.doi.org/10.1016/s0140-6736(98)10261-1 10217079
  a. Jacobs I, Davies AP, Bridges J, . Prevalence screening for ovarian cancer in postmenopausal women by CA 125 measurement and ultrasonography. BMJ. 1993;306(6884):1030-4. PMID: 8490497. http://dx.doi.org/10.1136/bmj.306.6884.1030 8490497