# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

- / = MeSH subject heading
- $ = truncation
- * = truncation
- ? = wildcard
- ab = word in abstract
- adj# = adjacent within x number of words
- ae = adverse effects
- hw = subject heading word
- id = identifier
- kw = keyword
- md = methodology
- near/# = adjacent within x number of words
- ti = word in title

### Cochrane Central Register of Controlled Trials (CENTRAL)

#1 | (ovar* or (fallopian next tub*) or adenx*):ti,ab,kw near/4 (cancer* or neoplas* or tumo* or malignan* or carcinoma* or adenocarcinoma* or mass*):ti,ab,kw
#2 | screen*:ti,ab,kw
#3 | detect*:ti
#4 | (sonog* or ultraso*):ti,ab,kw
#5 | (tumo* next marker*):ti,ab,kw
#6 | (serum next cancer next antigen*):ti,ab,kw
#7 | “CA 125”:ti,ab,kw
#8 | ^101-#7^
#9 | #1 and #8 Publication Year from 2003 to 2016, in Trials

### MEDLINE

1 | Ovarian Neoplasms/
2 | Fallopian Tube Neoplasms/
3 | ((ovar$ or fallopian tub$ or adenx$) adj4 (cancer$ or neoplas$ or tumo$ or malignan$ or carcinoma$ or adenocarcinoma$ or mass$)).ti,ab.
4 | or/1-3
5 | Mass screening/
6 | “Early detection of cancer”/
7 | (screen$ adj5 (ovar$ or fallopian tub$ or adnex$)).ti,ab.
8 | detect$.ti.
9 | Ultrasonography/
10 | (sonog$ or ultraso$).ti,ab.
11 | Tumor Markers, Biological/
12 | tumo?r marker$.ti,ab.
13 | serum cancer antigen$.ti,ab.
14 | CA 125.ti,ab.
15 | algorithm$.ti,ab.
16 | ROCA.ti,ab.
17 | or/5-16
18 | 4 and 17
19 | Ovarian Neoplasms/us [Ultrasonography]
20 | Fallopian Tube Neoplasms/us [Ultrasonography]
21 | 18 or 19 or 20
22 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
23 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
24 | Random$.ti,ab.
25 | control groups/ or double-blind method/ or single-blind method/
26 | clinical trial$.ti,ab.
27 | controlled trial$.ti,ab.
28 | meta analy$.ti,ab.
29 | or/22-28
30 | 21 and 29
31 | Animals/ not (Humans/ and Animals/)
32 | 30 not 31
33 | limit 32 to (english language and yr=“2003 -Current”)
34 | remove duplicates from 33

### PUBMED, publisher-supplied records

#14 | Search (((#13) AND publisher[sb]) AND (“2003/01/01”[Date - Publication] : “3000”[Date - Publication])) AND English[Language]
#13 | Search #8 AND #12
#12 | Search #9 OR #10 OR #11
#11 | Search (control[tiab] OR controls[tiab] OR controlled[tiab] OR controled[tiab]) AND (trial[tiab] OR trials[tiab])
#10 | Search “clinical trial”[tiab] OR “clinical trials”[tiab] OR random*[tiab]
#9 | Search systematic review[sb] OR metaanaly*[tiab] OR meta analysis[tiab]
#8 | Search #1 AND #7
#7 | Search #2 OR #3 OR #4 OR #5 OR #6
#6 | Search CA 125[tiab]
#5 | Search serum cancer antigen*[tiab]
#4 | Search tumo* marker*[tiab]
#3 | Search sonog*[tiab] or ultraso*[tiab]
#2 | Search screen*[tiab] OR detect*[tiab]
#1 | Search (ovar*[tiab] or fallopian tub*[tiab] or adenx*[tiab]) AND (cancer*[tiab] or neoplas*[tiab] or tumor*[tiab] OR tumour*[tiab] or malignan*[tiab] or carcinoma*[tiab] or adenocarcinoma*[tiab] or mass*[tiab])

Appendix A Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 1337 citations identified through literature databases. An additional 17 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, 27 citations were from the previous reviews for the USPSTF on screening for ovarian cancer. After duplicates were removed, 1381 unique citations were screened at the title/abstract stage. The full text of 74 citations were examined for inclusion for one or more of the Key Questions. There were 3 studies (in 14 articles) included for Key Question 1, and 4 studies (in 15 articles) included for Key Question 2. Reasons for excluding the other articles are available in Appendix C.

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | Screening for ovarian cancer in a primary care setting (alone or as part of a clinical examination) | Screening for ovarian cancer in selected high-risk populations, such as women who are BRCA mutation carriers or patients of a specialty practice, such as oncology
Populations | Asymptomatic, average risk women, ages 45 years and older | Trials enrolling only women who are selected based on an increased risk for ovarian cancer (e.g. known predisposing genetic syndromes, strong family history)
Screening tests | Screening tests and approaches evaluated in clinical trials such as, but not limited to: testing for serum cancer antigen (CA–125), transvaginal ultrasonography, and combined screening approaches or algorithms | Screening tests not evaluated in clinical trials
Comparisons | Comparison of screening with usual care or no screening; comparison of different included screening methods or programs
Outcomes | KQ 1: Ovarian cancer–specific mortality (including primary peritoneal and fallopian tube cancer), all-cause mortality, cancer-related morbidity, and quality of life. KQ 2: Surgery rate, rates of false-positive screening results, complications of diagnostic surgical procedures, and health and psychological effects of screening tests
Settings | Primary care settings, including obstetrics/gynecology practices | Specialty practice settings, such as oncology
Study designs | Randomized, controlled trials | Cohort studies, case-controls, case reports, case series, and decision analyses
Study quality | Good and fair quality according to USPSTF criteria and supplemented quality measures | Poor quality according to USPSTF criteria and supplemental quality measures
Language | English | Non–English language studies

Abbreviations: KQ = key question; USPSTF = United States Preventive Services Task Force

Appendix A Table 2 Quality Assessment Criteria of Randomized Controlled Trials

USPSTF quality rating criteria^120^
- Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered; - Intention-to-treat analysis

Abbreviations: KQ = key question; USPSTF = United States Preventive Services Task Force