# References

1 Cobb J. Outline for the study of scoliosis. The American Academy of Orthopedic Surgeons Instructional Course Lectures. Ann Arbor, MI: Edwards; 1948.
2 McAlister WH, Shackelford GD. Classification of spinal curvatures. Radiol Clin North Am. 1975;13(1):93-112. PMID: 1129452.1129452
3 Goldstein LA, Waugh TR. Classification and terminology of scoliosis. Clin Orthop Relat Res. 1973(93):10-22. PMID: 4722939.4722939
4 Riseborough EJ, Wynne-Davies R. A genetic survey of idiopathic scoliosis in Boston, Massachusetts. J Bone Joint Surg Am. 1973;55(5):974-82. PMID: 4760104.4760104
5 Hresko MT. Clinical practice. Idiopathic scoliosis in adolescents. N Engl J Med. 2013;368(9):834-41. PMID: 23445094.23445094
6 Weinstein SL. Natural history. Spine (Phila Pa 1976). 1999;24(24):2592-600 9p. PMID: 10635522.10635522
7 Yawn BP, Yawn RA, Hodge D, . A population-based study of school scoliosis screening. JAMA. 1999;282(15):1427-32. PMID: 10535432.10535432
8 Wong HK, Hui JH, Rajan U, . Idiopathic scoliosis in Singapore schoolchildren: a prevalence study 15 years into the screening program. Spine (Phila Pa 1976). 2005;30(10):1188-96. PMID: 15897834.15897834
9 Daruwalla JS, Balasubramaniam P, Chay SO, . Idiopathic scoliosis. Prevalence and ethnic distribution in Singapore schoolchildren. J Bone Joint Surg Br. 1985;67(2):182-4. PMID: 3980521.3980521
10 Miller NH. Cause and natural history of adolescent idiopathic scoliosis. Orthop Clin North Am. 1999;30(3):343-52, vii. PMID: 10393760.10393760
11 Gorman KF, Julien C, Moreau A. The genetic epidemiology of idiopathic scoliosis. Eur Spine J. 2012;21(10):1905-19. PMID: 22695700.22695700
12 Inoue M, Minami S, Kitahara H, . Idiopathic scoliosis in twins studied by DNA fingerprinting: the incidence and type of scoliosis. J Bone Joint Surg Br. 1998;80(2):212-7. PMID: 9546446.9546446
13 Wynne-Davies R. Familial (idiopathic) scoliosis. A family survey. J Bone Joint Surg Br. 1968;50(1):24-30. PMID: 5641594.5641594
14 Ward K, Ogilvie J, Argyle V, . Polygenic inheritance of adolescent idiopathic scoliosis: a study of extended families in Utah. Am J Med Genet A. 2010;152A(5):1178-88. PMID: 20425822.20425822
15 Axenovich TI, Zaidman AM, Zorkoltseva IV, . Segregation analysis of idiopathic scoliosis: demonstration of a major gene effect. Am J Med Genet. 1999;86(4):389-94. PMID: 10494097.10494097
16 Justice CM, Miller NH, Marosy B, . Familial idiopathic scoliosis: evidence of an X-linked susceptibility locus. Spine (Phila Pa 1976). 2003;28(6):589-94. PMID: 12642767.12642767
17 Salehi LB, Mangino M, De Serio S, . Assignment of a locus for autosomal dominant idiopathic scoliosis (IS) to human chromosome 17p11. Hum Genet. 2002;111(4-5):401-4. PMID: 12384783.12384783
18 Chan V, Fong GC, Luk KD, . A genetic locus for adolescent idiopathic scoliosis linked to chromosome 19p13.3. Am J Hum Genet. 2002;71(2):401-6. PMID: 12094330.12094330
19 Sharma S, Gao X, Londono D, . Genome-wide association studies of adolescent idiopathic scoliosis suggest candidate susceptibility genes. Hum Mol Genet. 2011;20(7):1456-66. PMID: 21216876.21216876
20 Gao X, Gordon D, Zhang D, . CHD7 gene polymorphisms are associated with susceptibility to idiopathic scoliosis. Am J Hum Genet. 2007;80(5):957-65. PMID: 17436250.17436250
21 Kouwenhoven JW, Castelein RM. The pathogenesis of adolescent idiopathic scoliosis: review of the literature. Spine (Phila Pa 1976). 2008;33(26):2898-908. PMID: 19092622.19092622
22 Richards BS, Bernstein RM, D'Amato CR, . Standardization of criteria for adolescent idiopathic scoliosis brace studies: SRS Committee on Bracing and Nonoperative Management. Spine (Phila Pa 1976). 2005;30(18):2068-75; discussion 76-7. PMID: 16166897.16166897
23 Bunnell WP. The natural history of idiopathic scoliosis before skeletal maturity. Spine (Phila Pa 1976). 1986;11(8):773-6. PMID: 3810290.3810290
24 Lonstein JE, Carlson JM. The prediction of curve progression in untreated idiopathic scoliosis during growth. J Bone Joint Surg Am. 1984;66(7):1061-71. PMID: 6480635.6480635
25 Ponseti IV, Friedman B. Prognosis in idiopathic scoliosis. J Bone Joint Surg Am. 1950;32A(2):381-95. PMID: 15412180.15412180
26 Collis DK, Ponseti IV. Long-term follow-up of patients with idiopathic scoliosis not treated surgically. J Bone Joint Surg Am. 1969;51(3):425-45. PMID: 4238082.4238082
27 Weinstein SL, Zavala DC, Ponseti IV. Idiopathic scoliosis: long-term follow-up and prognosis in untreated patients. J Bone Joint Surg Am. 1981;63(5):702-12. PMID: 6453874.6453874
28 Weinstein SL, Ponseti IV. Curve progression in idiopathic scoliosis. J Bone Joint Surg Am. 1983;65(4):447-55. PMID: 6833318.6833318
29 Weinstein SL. Idiopathic scoliosis. Natural history. Spine. 1986;11(8):780-3. PMID: 3810292.3810292
30 Weinstein SL, Dolan LA, Spratt KF, . Health and function of patients with untreated idiopathic scoliosis: a 50-year natural history study. JAMA. 2003;289(5):559-67. PMID: 12578488.12578488
31 Ascani E, Bartolozzi P, Logroscino CA, . Natural history of untreated idiopathic scoliosis after skeletal maturity. Spine (Phila Pa 1976). 1986;11(8):784-9. PMID: 3810293.3810293
32 Asher MA, Burton DC. Adolescent idiopathic scoliosis: natural history and long term treatment effects. Scoliosis. 2006;1(1):2. PMID: 16759428.16759428
33 Cordover AM, Betz RR, Clements DH, . Natural history of adolescent thoracolumbar and lumbar idiopathic scoliosis into adulthood. J Spinal Disord. 1997;10(3):193-6. PMID: 9213273.9213273
34 Clark EM, Tobias JH, Fairbank J. The Impact of Small Spinal Curves in Adolescents Who Have Not Presented to Secondary Care: A Population-Based Cohort Study. Spine (Phila Pa 1976). 2016;41(10):E611-7. PMID: 26583476.26583476
35 Mayo NE, Goldberg MS, Poitras B, . The Ste-Justine adolescent idiopathic scoliosis cohort study. Part III: back pain. Spine (Phila Pa 1976). 1994;19(14):1573-81 9p. PMID: 7939993.7939993
36 Grauers A, Topalis C, Moller H, . Prevalence of Back Problems in 1069 Adults With Idiopathic Scoliosis and 158 Adults Without Scoliosis. Spine (Phila Pa 1976). 2014. PMID: 24718070.24718070
37 Weinstein SL, Dolan LA, Cheng JC, . Adolescent idiopathic scoliosis. Lancet. 2008;371(9623):1527-37. PMID: 18456103.18456103
38 Danielsson AJ, Nachemson AL. Radiologic findings and curve progression 22 years after treatment for adolescent idiopathic scoliosis: comparison of brace and surgical treatment with matching control group of straight individuals. Spine (Phila Pa 1976). 2001;26(5):516-25. PMID: 11242379.11242379
39 Andersen MO, Christensen SB, Thomsen K. Outcome at 10 years after treatment for adolescent idiopathic scoliosis. Spine (Phila Pa 1976). 2006;31(3):350-4 5p. PMID: 106433029.16449910
40 Johnston CE, Richards BS, Sucato DJ, . Correlation of preoperative deformity magnitude and pulmonary function tests in adolescent idiopathic scoliosis. Spine (Phila Pa 1976). 2011;36(14):1096-102 7p. PMID: 104805951.21270699
41 Payne WK, III, Ogilvie JW, Resnick MD, . Does scoliosis have a psychological impact and does gender make a difference? Spine (Phila Pa 1976). 1997;22(12):1380-4 5p. PMID: 9201842.9201842
42 Goldberg MS, Mayo NE, Poitras B, . The Ste-Justine adolescent idiopathic scoliosis cohort study. Part II: perception of health, self and body image, and participation in physical activities. Spine (Phila Pa 1976). 1994;19(14):1562-72 11p. PMID: 7939992.7939992
43 Hresko MT, Talwalkar VR, Schwend RM. Position Statement - Screening for the Early Detection for Idiopathic Scoliosis in Adolescents. Scoliosis Research Society, American Academy of Orthopedic Surgeons, Pediatric Orthopedic Society of North America, American Academy of Pediatrics; 2015.
44 Deurloo JA, Verkerk PH. To screen or not to screen for adolescent idiopathic scoliosis? A review of the literature. Public Health. 2015;129(9):1267-72. PMID: 26296849.26296849
45 Cote P, Kreitz BG, Cassidy JD, . A study of the diagnostic accuracy and reliability of the Scoliometer and Adam's forward bend test… including commentary by Lonstein JE. Spine (Phila Pa 1976). 1998;23(7):796-803 8p. PMID: 107270316. Language: English. Entry Date: 19980701. Revision Date: 20150711. Publication Type: Journal Article.9563110
46 Fairbank J. Historical perspective: William Adams, the forward bending test, and the spine of Gideon Algernon Mantell. Spine (Phila Pa 1976). 2004;29(17):1953-5. PMID: 15534423.15534423
47 Adams W. Lectures on the Pathology and Treatment of Lateral and Other Forms of Curvature of the Spine. 2nd ed. London: J & A Churchill; 1882.
48 Fong DY, Lee CF, Cheung KM, . A meta-analysis of the clinical effectiveness of school scoliosis screening. Spine (Phila Pa 1976). 2010;35(10):1061-71. PMID: 20393399.20393399
49 Reamy BV, Slakey JB. Adolescent idiopathic scoliosis: review and current concepts. Am Fam Physician. 2001;64(1):111-6. PMID: 11456428.11456428
50 Roach JW. Adolescent idiopathic scoliosis. Orthop Clin North Am. 1999;30(3):353-65 13p. PMID: 10393761.10393761
51 Thulbourne T, Gillespie R. The rib hump in idiopathic scoliosis. Measurement, analysis and response to treatment. J Bone Joint Surg Br. 1976;58(1):64-71. PMID: 1270497.1270497
52 Karachalios T, Sofianos J, Roidis N, . Ten-year follow-up evaluation of a school screening program for scoliosis: is the forward-bending test an accurate diagnostic criterion for the screening of scoliosis? Spine (Phila Pa 1976). 1999;24(22):2318-24 7p. PMID: 10586455.10586455
53 Fortin C, Grunstein E, Labelle H, . Trunk imbalance in adolescent idiopathic scoliosis. Spine J. 2016;16(6):687-93. PMID: 26921627.26921627
54 Luk KD, Lee CF, Cheung KM, . Clinical effectiveness of school screening for adolescent idiopathic scoliosis: a large population-based retrospective cohort study. Spine (Phila Pa 1976). 2010;35(17):1607-14 8p. PMID: 20453727.20453727
55 Negrini S, Aulisa AG, Aulisa L, . 2011 SOSORT guidelines: Orthopaedic and Rehabilitation treatment of idiopathic scoliosis during growth. Scoliosis. 2012;7(1):1-35. PMID: 22264320.22251672
56 Johnson JP, Daniels AH, Grabel ZJ, . Referral for Adolescent Idiopathic Scoliosis by Pediatric Primary Care Providers. Clin Pediatr (Phila). 2016. PMID: 27412803.27412803
57 Tarrant RC, Queally JM, O'Loughlin PF, . Preoperative curves of greater magnitude (>70degree) in adolescent idiopathic scoliosis are associated with increased surgical complexity, higher cost of surgical treatment and a delayed return to function. Irish Journal of Medical Science. 2016;185(2):463-71. PMID: 26742534.26742534
58 Canavese F, Kaelin A. Adolescent idiopathic scoliosis: Indications and efficacy of nonoperative treatment. Indian J Orthop. 2011;45(1):7-14. PMID: 21221217.21221217
59 Negrini S, Minozzi S, Bettany-Saltikov J, . Braces for idiopathic scoliosis in adolescents. Cochrane Database Syst Rev. 2015;6:CD006850. PMID: 26086959.26086959
60 Zaina F, De Mauroy J, Grivas T, . Bracing for scoliosis in 2014: state of the art. Eur J Phys Rehabil Med. 2014;50(1):93-110. PMID: 24622051.24622051
61 Janicki JA, Poe-Kochert C, Armstrong DG, . A comparison of the thoracolumbosacral orthoses and providence orthosis in the treatment of adolescent idiopathic scoliosis: results using the new SRS inclusion and assessment criteria for bracing studies. J Pediatr Orthop. 2007;27(4):369-74. PMID: 17513954.17513954
62 Coillard C, Leroux MA, Zabjek KF, . SpineCor--a non-rigid brace for the treatment of idiopathic scoliosis: post-treatment results. Eur Spine J. 2003;12(2):141-8. PMID: 12709852.12709852
63 Blount WP, Schmidt AC, Keever ED, . The Milwaukee brace in the operative treatment of scoliosis. J Bone Joint Surg Am. 1958;40(3):511-25. PMID: 13539080.13539080
64 Maruyama T, Takeshita K, Kitagawa T. Milwaukee brace today. Disabil Rehabil Assist Technol. 2008;3(3):136-8 3p. PMID: 18465396.18465396
65 Sanders JO, Browne RH, McConnell SJ, . Maturity assessment and curve progression in girls with idiopathic scoliosis. J Bone Joint Surg Am. 2007;89-A(1):64-73 10p. PMID: 106006944. Language: English. Entry Date: 20080229. Revision Date: 20150711. Publication Type: Journal Article.
66 Hasler CC. A brief overview of 100 years of history of surgical treatment for adolescent idiopathic scoliosis. J Child Orthop. 2013;7(1):57-62. PMID: 24432060.24432060
67 Mohaideen A, Nagarkatti D, Banta JV, . Not all rods are Harrington - an overview of spinal instrumentation in scoliosis treatment. Pediatr Radiol. 2000;30(2):110-8. PMID: 10663523.10663523
68 Good CR. Evolution in the treatment of spinal deformity and spinal instrumentation. Journal of The Spinal Research Foundation. 2010;5(1):7.
69 Harrington PR, Dickson JH. An eleven-year clinical investigation of Harrington instrumentation. A preliminary report on 578 cases. Clin Orthop. 1973(93):113-30. PMID: 4581508.4581508
70 Padua R, Padua S, Aulisa L, . Patient outcomes after Harrington instrumentation for idiopathic scoliosis: a 15- to 28-year evaluation. Spine (Phila Pa 1976). 2001;26(11):1268-73 6p. PMID: 11389396.11389396
71 Kepler CK, Meredith DS, Green DW, . Long-term outcomes after posterior spine fusion for adolescent idiopathic scoliosis. Curr Opin Pediatr. 2012;24(1):68-75 8p. PMID: 108152851.22157365
72 Hicks JM, Singla A, Shen FH, . Complications of pedicle screw fixation in scoliosis surgery: a systematic review. Spine (Phila Pa 1976). 2010;35(11):E465-70. PMID: 20473117.20473117
73 Suk SI, Kim JH, Kim SS, . Pedicle screw instrumentation in adolescent idiopathic scoliosis (AIS). Eur Spine J. 2012;21(1):13-22. PMID: 21874625.21874625
74 Lykissas MG, Jain VV, Nathan ST, . Mid- to long-term outcomes in adolescent idiopathic scoliosis after instrumented posterior spinal fusion: a meta-analysis. Spine (Phila Pa 1976). 2013;38(2):E113-9. PMID: 23124268.23124268
75 Lehman RA, Jr., Kang DG, Lenke LG, . Return to sports after surgery to correct adolescent idiopathic scoliosis: a survey of the Spinal Deformity Study Group. Spine J. 2015;15(5):951-8. PMID: 24099682.24099682
76 American Academy of Orthopaedic Surgeons. Position Statement: School Screening Programs for the Early Detection of Scoliosis. Park Ridge, Ill: American Academy of Orthopaedic Surgeons; 1987.
77 American Academy of Pediatrics. Health Supervision Visits. Elk Grove Village, Ill: American Academy of Pediatrics; 1985.
78 Scoliosis Research Society. Scoliosis: A Handbook for Patients. Park Ridge, Ill: Scoliosis Research Society; 1986.
79 Asher M, Beringer GB, Orrick J, . The current status of scoliosis screening in North America, 1986. Results of a survey by mailed questionnaire. Spine (Phila Pa 1976). 1989;14(7):652-62. PMID: 2772711.2772711
80 British Orthopaedic Association and British Scoliosis Society. School screening for scoliosis. Br Med J (Clin Res Ed). 1983;287:2.
81 Canadian Task Force on the Periodic Health Examination. The periodic health examination, 2: 1984 update. Can Med Assoc J. 1984;130:4.
82 Screening for adolescent idiopathic scoliosis. Review article. US Preventive Services Task Force. JAMA. 1993;269(20):2667-72. PMID: 8487452.8487452
83 Screening for adolescent idiopathic scoliosis. Policy statement. US Preventive Services Task Force. JAMA. 1993;269(20):2664-6. PMID: 8487451.8487451
84 U.S. Preventive Services Task Force. Screening for idiopathic scoliosis in adolescents: recommendation statement. Rockville, MD: Agency for Healthcare Research and Quality; June 2004.
85 Labelle H, Richards SB, De Kleuver M, . Screening for adolescent idiopathic scoliosis: an information statement by the scoliosis research society international task force. Scoliosis. 2013;8:17. PMID: 24171910.24171910
86 Grivas TB, Wade MH, Negrini S, . SOSORT consensus paper: school screening for scoliosis. Where are we today? Scoliosis. 2007;2:17. PMID: 18039374.18039374
87 Screening for Idiopathic Scoliosis in Adolescents: A Brief Evidence Update for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2004.
88 United Nations Development Programme. Human Development Index: 2015 Rankings. United Nations Development Programme [2015]. http://hdr.undp.org/en/2015-report.
89 United States Preventive Services Task Force. US Preventive Services Task Force Procedure Manual. 2015.
90 Wells G, Shea B, O'connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000.
91 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014.
92 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589.15615589
93 Lee CF, Fong DY, Cheung KM, . Referral criteria for school scoliosis screening: assessment and recommendations based on a large longitudinally followed cohort. Spine (Phila Pa 1976). 2010;35(25):E1492-8 1p. PMID: 21102278.21102278
94 Goldberg CJ, Dowling FE, Fogarty EE, . School scoliosis screening and the United States Preventive Services Task Force. An examination of long-term results. Spine. 1995;20(12):1368-74. PMID: 7676334.7676334
95 Goldberg CJ, Dowling FE, Fogarty EE. Adolescent idiopathic scoliosis: is rising growth rate the triggering factor in progression? Eur Spine J. 1993;2(1):29-36. PMID: 20058445.20058445
96 Goldberg CJ, Dowling FE, Hall JE, . A statistical comparison between natural history of idiopathic scoliosis and brace treatment in skeletally immature adolescent girls. Spine (Phila Pa 1976). 1993;18(7):902-8. PMID: 8316891.8316891
97 Fong DY, Cheung KM, Wong YW, . A population-based cohort study of 394,401 children followed for 10 years exhibits sustained effectiveness of scoliosis screening. Spine J. 2015;15(5):825-33. PMID: 25615844.25615844
98 Soucacos PN, Soucacos PK, Zacharis KC, . School-screening for scoliosis. A prospective epidemiological study in northwestern and central Greece. J Bone Joint Surg Am. 1997;79(10):1498-503. PMID: 9378735.9378735
99 Soucacos PN, Zacharis K, Gelalis J, . Assessment of curve progression in idiopathic scoliosis. Eur Spine J. 1998;7(4):270-7. PMID: 9765033.9765033
100 Soucacos PN, Zacharis K, Soultanis K, . Risk factors for idiopathic scoliosis: review of a 6-year prospective study. Orthopedics. 2000;23(8):833-8 6p. PMID: 10952046.10952046
101 Adobor RD, Rimeslatten S, Steen H, . School screening and point prevalence of adolescent idiopathic scoliosis in 4000 Norwegian children aged 12 years. Scoliosis. 2011;6:23. PMID: 22024241.22024241
102 Coillard C, Circo A, Rivard C. A prospective randomized controlled trial of the natural history of idiopathic scoliosis versus treatment with the SpineCor brace. Sosort Award 2011 winner. Eur J Phys Rehabil Med. 2014;50(5):479-87. PMID: 25251736.25251736
103 Wiemann J, Shah S, Price C. Nighttime bracing versus observation for early adolescent idiopathic scoliosis. J Pediatr Orthop. 2014;34(6):603-6. PMID: 24840659.24840659
104 Weinstein SL, Dolan LA, Wright JG, . Effects of bracing in adolescents with idiopathic scoliosis. N Engl J Med. 2013;369(16):1512-21. PMID: 24047455.24047455
105 Weinstein SL, Dolan LA, Wright JG, . Design of the Bracing in Adolescent Idiopathic Scoliosis Trial (BrAIST). Spine (Phila Pa 1976). 2013;38(21):1832-41 10p. PMID: 24026162.24026162
106 Nachemson AL, Peterson LE. Effectiveness of treatment with a brace in girls who have adolescent idiopathic scoliosis. A prospective, controlled study based on data from the Brace Study of the Scoliosis Research Society. J Bone Joint Surg Am. 1995;77(6):815-22. PMID: 7782353.7782353
107 Peterson LE, Nachemson AL. Prediction of progression of the curve in girls who have adolescent idiopathic scoliosis of moderate severity. Logistic regression analysis based on data from The Brace Study of the Scoliosis Research Society. J Bone Joint Surg Am. 1995;77(6):823-7. PMID: 7782354.7782354
108 Emans JB, Kaelin A, Bancel P, . The Boston bracing system for idiopathic scoliosis. Follow-up results in 295 patients. Spine (Phila Pa 1976). 1986;11(8):792-801. PMID: 3810295.3810295
109 Monticone M, Ambrosini E, Cazzaniga D, . Active self-correction and task-oriented exercises reduce spinal deformity and improve quality of life in subjects with mild adolescent idiopathic scoliosis. Results of a randomised controlled trial. Eur Spine J. 2014;23(6):1204-14. PMID: 24682356.24682356
110 Negrini S, Zaina F, Romano M, . Specific exercises reduce brace prescription in adolescent idiopathic scoliosis: a prospective controlled cohort study with worst-case analysis. J Rehabil Med. 2008;40(6):451-5. PMID: 18509560.18509560
111 Danielsson AJ, Hasserius R, Ohlin A, . Health-Related Quality of Life in Untreated Versus Brace-Treated Patients With Adolescent Idiopathic Scoliosis: A Long-term Follow-up. Spine (Phila Pa 1976). 2010;35(2):199-205 7p. PMID: 20038869.20038869
112 Danielsson AJ, Hasserius R, Ohlin A, . Body appearance and quality of life in adult patients with adolescent idiopathic scoliosis treated with a brace or under observation alone during adolescence. Spine (Phila Pa 1976). 2012;37(9):755-62 8p. PMID: 22037522.22037522
113 Danielsson A, Wiklund I, Pehrsson K, . Health-related quality of life in patients with adolescent idiopathic scoliosis: a matched follow-up at least 20 years after treatment with brace or surgery. Eur Spine J. 2001;10(4):278-88. PMID: 11563612.11563612
114 Danielsson AJ, Nachemson AL. Childbearing, curve progression, and sexual function in women 22 years after treatment for adolescent idiopathic scoliosis: a case-control study. Spine (Phila Pa 1976). 2001;26(13):1449-56 8p. PMID: 11458150.11458150
115 Pehrsson K, Danielsson A, Nachemson A. Pulmonary function in adolescent idiopathic scoliosis: a 25 year follow up after surgery or start of brace treatment. Thorax. 2001;56:388-93. PMID: 11312408.11312408
116 Asher M, Min Lai S, Burton D, . The reliability and concurrent validity of the scoliosis research society-22 patient questionnaire for idiopathic scoliosis. Spine. 2003;28(1):63-9. PMID: 12544958.12544958
117 Ware JE, Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-83. PMID: 1593914.1593914
118 Sanders JO, Harrast JJ, Kuklo TR, . The Spinal Appearance Questionnaire: results of reliability, validity, and responsiveness testing in patients with idiopathic scoliosis. Spine (Phila Pa 1976). 2007;32(24):2719-22. PMID: 18007251.18007251
119 Levy AR, Goldberg MS, Mayo NE, . Reducing the lifetime risk of cancer from spinal radiographs among people with adolescent idiopathic scoliosis. Spine (Phila Pa 1976). 1996;21(13):1540-8 9p. PMID: 8817782.8817782
120 Doody MM, Lonstein JE, Stovall M, . Breast cancer mortality after diagnostic radiography: findings from the U.S. Scoliosis Cohort Study. Spine (Phila Pa 1976). 2000;25(16):2052-63 12p. PMID: 10954636.10954636
121 Nash CL, Jr., Gregg EC, Brown RH, . Risks of exposure to x-rays in patients undergoing long-term treatment for scoliosis. J Bone Joint Surg Am. 1979;61(3):371-4. PMID: 429405.429405
122 Himmetoglu S, Guven MF, Bilsel N, . DNA damage in children with scoliosis following x-ray exposure. Minerva Pediatr. 2015;67(3):245-9. PMID: 25941131.25941131
123 Porto F, Gurgel JL, Russomano T, . Moire topography: characteristics and clinical application. Gait Posture. 2010;32(3):422-4. PMID: 20643549.20643549
124 Torell G, Nordwall A, Nachemson A. The changing pattern of scoliosis treatment due to effective screening. Journal of Bone & Joint Surgery - American Volume. 1981;63(3):337-41. PMID: 7204428.7204428
125 Levy AR, Goldberg MS, Hanley JA, . Projecting the lifetime risk of cancer from exposure to diagnostic ionizing radiation for adolescent idiopathic scoliosis. Health Phys. 1994;66(6):621-33. PMID: 8181937.8181937
126 Nachemson A, Lonstein J, Weinstein S Report of the prevalence and natural history committee of the Scoliosis Research Society. Denver, CO: Annual Meeting of the Scoliosis Research Society; 1982.
127 Mordecai SC, Dabke HV. Efficacy of exercise therapy for the treatment of adolescent idiopathic scoliosis: a review of the literature. Eur Spine J. 2012;21(3):382-9. PMID: 22065168.22065168
128 Multicenter Schroth Exercise Trial for Scoliosis (MultiSETS). Bethesda (MD): National Library of Medicine (US) [2016 August 26]. https://clinicaltrials.gov/ct2/show/record/NCT01610908.
129 Karol LA, Virostek D, Felton K, . The Effect of the Risser Stage on Bracing Outcome in Adolescent Idiopathic Scoliosis. Journal of Bone & Joint Surgery - American Volume. 2016;98(15):1253-9. PMID: 27489315.27489315
130 Katz DE, Herring JA, Browne RH, . Brace wear control of curve progression in adolescent idiopathic scoliosis. J Bone Joint Surg Am. 2010;92-A(6):1343-52 10p. PMID: 105019521. Language: English. Entry Date: 20100723. Revision Date: 20150711. Publication Type: Journal Article.
131 Sanders JO, Newton PO, Browne RH, . Bracing for idiopathic scoliosis: how many patients require treatment to prevent one surgery? J Bone Joint Surg Am. 2014;96(8):649-53 5p. PMID: 103930949. Language: English. Entry Date: 20140606. Revision Date: 20150710. Publication Type: Journal Article.24740661
132 Bettany-Saltikov J, Weiss HR, Chockalingam N, . Surgical versus non-surgical interventions in people with adolescent idiopathic scoliosis. Cochrane Database Syst Rev. 2015;4:CD010663. PMID: 25908428.25908428
133 Reames DL, Smith JS, Fu KM, . Complications in the surgical treatment of 19,360 cases of pediatric scoliosis: a review of the Scoliosis Research Society Morbidity and Mortality database. Spine (Phila Pa 1976). 2011;36(18):1484-91 8p. PMID: 21037528.21037528
134 McMaster MJ. Luque rod instrumentation in the treatment of adolescent idiopathic scoliosis. A comparative study with Harrington instrumentation. J Bone Joint Surg Br. 1991;73(6):982-9. PMID: 1955449.1955449
135 Tsirikos AI, Subramanian AS. Posterior spinal arthrodesis for adolescent idiopathic scoliosis using pedicle screw instrumentation: does a bilateral or unilateral screw technique affect surgical outcome? J Bone Joint Surg Br. 2012;94(12):1670-7. PMID: 23188910.23188910
136 Bjerkreim I, Steen H, Brox JI. Idiopathic scoliosis treated with Cotrel-Dubousset instrumentation: evaluation 10 years after surgery. Spine (Phila Pa 1976). 2007;32(19):2103-10. PMID: 17762812.17762812
137 Sieberg CB, Simons LE, Edelstein MR, . Pain prevalence and trajectories following pediatric spinal fusion surgery. J Pain. 2013;14(12):1694-702. PMID: 24290449.24290449
138 Coe JD, Arlet V, Donaldson W, . Complications in spinal fusion for adolescent idiopathic scoliosis in the new millennium. A report of the Scoliosis Research Society Morbidity and Mortality Committee. Spine (Phila Pa 1976). 2006;31(3):345-9. PMID: 16449909.16449909
139 De la Garza Ramos R, Goodwin CR, Abu-Bonsrah N, . Patient and operative factors associated with complications following adolescent idiopathic scoliosis surgery: an analysis of 36,335 patients from the Nationwide Inpatient Sample. J Neurosurg. 2016;Pediatrics..1-7. PMID: 27564784.27564784
140 de Mendonca RG, Sawyer JR, Kelly DM. Complications After Surgical Treatment of Adolescent Idiopathic Scoliosis. Orthop Clin North Am. 2016;47(2):395-403. PMID: 26772948.26772948
141 Sanders AE, Andras LM, Choi PD, . Lateral Femoral Cutaneous Nerve Palsy After Spinal Fusion for Adolescent Idiopathic Scoliosis (AIS). Spine. 2016;41(19):E1164-7. PMID: 27010998.27010998
142 Pruijs JE, van der Meer R, Hageman MA, . The benefits of school screening for scoliosis in the central part of The Netherlands. Eur Spine J. 1996;5(6):374-9. PMID: 8988379.8988379
143 Bunge E, Koning H. Bracing patients with idiopathic scoliosis: design of the Dutch randomized controlled treatment trial. BMC musculoskeletal disorders [serial on the Internet]. 2008; 9: Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/222/CN-00648222/frame.html.18215332
144 Bunge EM, Habbema JDF, de Koning HJ. A randomised controlled trial on the effectiveness of bracing patients with idiopathic scoliosis: failure to include patients and lessons to be learnt. Eur Spine J. 2010;19(5):747-53. PMID: 20195651.20195651
145 Cuddihy L, Danielsson AJ, Cahill PJ, . Vertebral Body Stapling versus Bracing for Patients with High-Risk Moderate Idiopathic Scoliosis. BioMed Research International. 2015;2015:438452. PMID: 26618169.26618169
146 Goodbody CM, Asztalos IB, Sankar WN, . It's not just the big kids: both high and low BMI impact bracing success for adolescent idiopathic scoliosis. J Child Orthop. 2016;10(5):395-404. PMID: 27501808.27501808
147 Liu S, Schwab F, Smith JS, . Likelihood of reaching minimal clinically important difference in adult spinal deformity: a comparison of operative and nonoperative treatment. Ochsner J. 2014;14(1):67-77. PMID: 24688336.24688336
148 Bago J, Perez-Grueso FJ, Les E, . Minimal important differences of the SRS-22 Patient Questionnaire following surgical treatment of idiopathic scoliosis. Eur Spine J. 2009;18(12):1898-904. PMID: 19533179.19533179
149 Monticone M. Answer to the letter to the editor of S. Negrini et al. concerning “active self-correction and task-oriented exercises reduce spinal deformity and improve quality of life in subjects with mild adolescent idiopathic scoliosis. Results of a randomised controlled trial” by Monticone M, Ambrosini E, Cazzaniga D, Rocca B, Ferrante S (2014) Eur Spine J; DOI 10.1007/s00586-014-3241-y. Eur Spine J. 2014;23(10):2221-2. PMID: 25052210.25052210
150 Westrick ER, Ward WT. Adolescent idiopathic scoliosis: 5-year to 20-year evidence-based surgical results. J Pediatr Orthop. 2011;31(1 Suppl):S61-8. PMID: 21173621.21173621