# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris R. Mabry-Hernandez, MD, MPH, for project oversight on behalf of AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Wally Krengel, MD, for expert consultation; Todd Hannon, MLS, and Smyth Lai, MLS, for creating and conducting the literature searches; Marie Beauséjour, PhD, M. Timothy Hresko, MD, Stefano Negrini, MD, and Stuart Weinstein, MD, for expert feedback on the draft report; the National Institute of Arthritis and Musculoskeletal and Skin Diseases and the National Institute of Child Health and Human Development for expert review of this report; and Gabrielle Gundersen, MPH, Vina Graham, Sharon Hwee, and Robert Arao, MPH.