# Chapter 4 Discussion

## Summary of Evidence

### Screening

As was the case for both the 1993 and 2004 USPSTF reviews on this subject, we found no direct evidence for a benefit of universal AIS screening of adolescents on long-term health outcomes. No prospective randomized trials of screening have been conducted, and there are no well-conducted cohort studies that compare health outcomes in screened and unscreened groups.

We included data on the accuracy of screening from seven different programs, but the heterogeneity of screening modalities, screeners, and referral criteria makes it challenging to compare across studies. It is clearly possible to detect children with AIS through screening, although the sensitivity and positive predictive value of screening programs appears to vary depending on whether a single mode or multiple modes of screening are used, and on the threshold used to define a positive screening result. The FBT with scoliometer measurement—the screening modality recommended by organizations advocating screening^43^—had estimated predictive values of 29 to 54 percent for detecting scoliosis curves of 10° or greater in the studies included in this review. One study found that sensitivity and predictive value estimates are higher when a measurement of ATR (e.g., scoliometer) is combined with intermediate Moiré topography assessment;^54, 93, 97^ however, Moiré topography is used infrequently in the United States and its feasibility as a population- or school-based screening modality may be limited where access to specialized equipment is unavailable.^123^

A low threshold for a positive screening result may increase the likelihood of detecting children with severe AIS who could benefit from immediate intervention; an analysis of patients referred to the single scoliosis referral center in the western district of Sweden during the 10-year period in which a systematic screening program for AIS was introduced demonstrated declines in the most severe curves detected each year and in the number of persons who required surgical treatment.^124^ However, it also may identify screen-positive persons who will never require treatment. Luk and colleagues^54^ noted that although 2.5 percent of the adolescents in their survey population of more than 150,000 fit the diagnostic criteria for scoliosis (curve of ≥10°), only a little more than half of these persons had curves of 20° or more (approaching the threshold at which brace treatment is often instituted), and only 0.2 percent of adolescents had curves of 40° or greater (approaching the threshold for surgical treatment). Using a higher cutoff point to designate a positive screening test (e.g., curve of ≥20°) would be a possible alternative approach; however, this may preclude the ability to identify and monitor or pre-emptively treat persons with mild curves that may progress. As noted above, it is difficult to accurately predict which persons with AIS will be most likely to have their curves progress during adolescence. There is a greater likelihood of curve progression associated with female sex, greater severity of curve, significant remaining growth potential, and certain curve types.^23, 107^ However, sex is the only one of these factors that can be known at the time of screening, and because the majority of females with AIS will not have significant progression of curve, the predictive value of sex for risk stratification may be limited. Sex-based approaches to screening have been endorsed by several organizations,^43^ but no studies of sex-targeted screening approaches met our inclusion criteria. In the studies included in this review, females comprised between 68 and 82 percent of detected cases of scoliosis with curves of 10° or greater, which is consistent with previously reported averages.^6^ There currently are insufficient data on the association of other physical findings or genetic markers with progression of disease to enable identification of high-risk and low-risk populations in whom targeted screening approaches may be beneficial. Finally, it must be emphasized that the value of screening for AIS—of any severity, and in in any population—ultimately depends on whether potential interventions are effective.

No studies on harms of screening met our inclusion criteria. False-positive rates ranged from 0.8 to 21.5 percent, but the harms associated with these rates are unclear. It is conceivable that there are psychosocial harms associated with screening, especially with a false-positive result, and radiation exposure to the chest during childhood may also be associated with harms. Several studies have suggested that radiation exposure over the course of management and surveillance for scoliosis is associated with increased cancer risk in adulthood,^119-122, 125^ but the impact of screening-only exposure was not reported in any studies.

### Treatment

Several new treatment studies have been published since the previous evidence reviews for the USPSTF. The mode of treatment recommended by scoliosis treatment guidelines varies according to curve severity, with observation or conservative interventions (e.g., exercise) for curves less than 20°, brace treatment for curves of 20° to 30° or greater, and surgical treatment for curves of 40° to 50°. Remaining growth until skeletal maturity also informs treatment decisions, and algorithms for treatment decisions based on multiple categories of curve severity and skeletal maturity have been proposed.^55^ Bracing is generally not indicated for curves of less than 20° based on data suggesting lower likelihood of curve progression during adolescence for curves of this severity.^23, 126^

Exercise therapy has long been advocated outside of the United States for cases of milder scoliosis (Cobb angle of 10°–20°); however, good-quality evidence in support of this was lacking until very recently.^127^ We found one good-quality RCT that suggests the use of physiotherapeutic scoliosis-specific exercises in adolescents with curves of 10° to 25° may prevent progression of the curve, and may even reverse the major curve in some cases.^109^ An earlier fair-quality study of exercise treatment in a similar population also suggests possible benefit, albeit of small magnitude. Both studies were performed exclusively in otherwise untreated persons, and therefore the utility of exercise as an adjunct to other treatment is unknown. Nonetheless, the clinical importance of limiting progression of mild curves may be significant, as curves of less than 20° to 30° at skeletal maturity are much less likely to continue to progress in adulthood than are curves of greater magnitude.^6, 31^ No other studies of other exercise treatments for AIS met our inclusion criteria; however, a multicenter randomized trial of the Schroth Method for treatment of AIS is currently underway, with estimated completion in 2017.^128^ If future good-quality studies of exercise therapy confirm the efficacy and relative safety of exercise treatment for milder AIS, this could have potential implications for the utility of population-based screening for persons with mild scoliosis.

The 1993 USPSTF review found insufficient evidence to determine whether brace treatment limited the natural progression of scoliosis in a significant percentage of cases; this finding was not reassessed as part of the limited 2004 evidence update. Our review includes five studies published since that time.^96, 102-104, 106^ Four of these are prospective controlled studies (including one RCT), all of which provide evidence for some benefit of bracing treatment, although they assess slightly different outcomes that precluded meta-analysis or pooling. The fifth study, a small retrospective study,^96^ showed nonsignificant differences between groups, but was not sufficiently powered. Three studies demonstrated that brace treatment until skeletal maturity was associated with a decreased likelihood of curve progression of more than 5° to 6°.^102, 103, 106^ In most studies, progression of 5° or more is considered equivalent to absence of progression; therefore, these results were thought to indicate that bracing could successfully arrest progression of the scoliosis curve, resulting in a curve of smaller magnitude at the end of growth that would be less likely to progress during adulthood. However, two small studies that included data on slightly larger degrees of progression did not show a significant difference between braced and control participants.^96, 103^ A prospective controlled trial^104^ showed a marked difference (odds ratio, 1.9) between braced and control subjects with regard to preventing progression of curve past 50°, at which point brace treatment is generally considered to have failed and surgical treatment is considered. This trial was ended early by the trial's data safety and monitoring board because of strong evidence of benefit in the bracing arm. This trial also showed a dose-response relationship between hours per day of brace wear and decreased likelihood of curve progression, a finding that is reflected in other studies that demonstrate an inverse association between hours per day of brace wear and likelihood of curve progression or surgical intervention.^129-131^ Three other studies provided data on subjects who passed a threshold in this range; however, none were powered to detect a difference of the magnitude seen.

Harms of bracing were reported in only one study;^104^ these were relatively benign and limited to skin problems on the trunk (under the brace) and nonback body pains that were reported more frequently in braced participants than in controls (none of these events were deemed serious). One of the 146 braced participants reported a serious adverse event (anxiety and depression requiring hospitalization). Two other studies on long-term followup of persons with AIS reported outcome findings that may suggest possible adverse consequences of brace treatment. One study administered the SAQ to a cohort of adults with AIS at least 11 years after skeletal maturity, and found that those who had been braced in adolescence felt their body appearance was more distorted than those who were not treated,^112^ despite equivalent curves in adulthood. A second study contacted a cohort of adults at least 20 years following treatment of AIS and asked about their impressions of their treatment period; a significantly higher percentage of brace-treated adults experienced a negative effect on their life compared to those treated surgically, despite the fact that curve magnitude at followup was nearly identical in both groups and significantly higher in the surgical group prior to treatment.^113^

No studies on effectiveness or harms of surgical treatment met our inclusion criteria, largely because of our population of interest (adolescents with scoliosis of <50° at diagnosis); this is consistent with other reviews.^132^ This is due in part to the fact that few studies of surgical treatment provided data on whether included subjects were initially identified through a screening program or on the severity of scoliosis at the time of diagnosis. However, it is also due in large part to the lack of a nonsurgical comparison group with AIS (e.g., those treated with bracing, exercise, or observation) in most studies, which is in turn a function of the fact that the populations for which each of these interventions is recommended has little or no overlap with the population for whom surgery is recommended in current published guidelines.^43, 55^ Although surgical techniques and outcomes have improved since the era when Harrington rod placement was the standard of care for severe AIS,^74^ the surgical procedures typically used to treat scoliosis are invasive and not without complications.^133^ As a result, surgery has in practice been reserved for treatment of those in whom bracing has failed; in some bracing studies, avoidance of surgery is actually used as the primary outcome.

As with all major surgeries, spinal fusion for AIS involves short- and long-term risks. Estimates of blood loss during AIS surgery vary (averaging 1,200 to 2,455 mL, depending on the procedure).^134-136^ Pain following AIS surgery is fairly common, with 30 (16%) of 190 patients in a prospective cohort study reporting moderate to severe pain at 1 year postoperation.^137^ Other complications of AIS surgery include death, infection, pseudoarthrosis, and neurologic deficits (Table 24). About 6 to 7 percent of patients experience complications from surgery for AIS,^133, 138, 139^ and very few patients (0.03%) die of those complications.^138^ Some of the more common complications are pulmonary (1% to 4%) and implant-related complications (1.1% to 1.5%).^133, 139^ Neurologic complications—such as nerve root damage and spinal cord injuries—occur in about 0.6 to 0.8 percent of AIS surgery patients,^139, 140^ most of whom experience complete or partial recovery.^140, 141^ As noted earlier, some research suggests that surgical treatment of persons with high degree of curvature (Cobb angle >70°) is more complex and associated with a higher likelihood of short-term risks (such as increased surgical duration, blood loss, and need for transfusion).^57^

Table 24 Estimated Complication Rates From Surgery for AIS

| Type of Surgery or Instrumentation | Estimated Rate in AIS Patients | Source
Infection | Harrington rod Cotrel-Dubousset Pedicle screws | 6.5% 4.3% 1.0% | Systematic review (5 studies; n=849)^150^ Systematic review (6 studies; n=271)^74^ Systematic review (12 studies; n=1,045)^72^
Pseudoarthrosis (failed spinal fusion) | Harrington rod Cotrel-Dubousset Pedicle screws | 3.6% 1.7% 0.5% | Systematic review (10 studies; n=1,484)^150^ Systematic review (6 studies; n=177)^74^ Systematic review (5 studies; n=192)^72^
Neurologic complications | Harrington rod Cotrel-Dubousset Pedicle screws | 0% 0.7% 0.06% | Systematic review (5 studies; n=577)^74^ Systematic review (7 studies; n=305)^74^ Systematic review (21 studies; n=1,666)^72^
Implant failure or removal | Harrington rod Cotrel-Dubousset Pedicle screws | 15.8% 5% 7.1% | Systematic review (8 studies; n=1,278)^150^ Prospective cohort (n=100)^136^ Systematic review (1 study; n=14)^150^
Reoperation | Harrington rod Cotrel-Dubousset Pedicle screws | 11.9% 1% 10.83% | Systematic review (8 studies; n=1,251)^150^ Prospective cohort (n=100)^136^ Systematic review (16 studies; n=1,436)^72^

Abbreviation: AIS=adolescent idiopathic scoliosis.

Table 25 Summary of Evidence

KQ | No. of Studies (k), No. of Observations (n) Study Designs | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Overall Quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence | Applicability
KQ 1 | No studies | NA | NA | NA | NA | NA | NA | NA
KQ 2 | K=7, n=447,243 Observational studies of screening programs (6/7 school-based) | FBT±S (4 studies) Sensitivity (1 study): 71.1% Specificity (1 study): 97.1% PPV (4 studies): 29.3%–54.1% FBT+S+M (1 study) Sensitivity: 93.8% Specificity: 99.2% PPV: 81.0% Single modality (1 study) Sensitivity: 84.4%–100% Specificity: 78.5%–95.2% PPV: 5.0%–17.3% | Inconsistent Imprecise | Undetected | 7 Fair | Limited/ad hoc to no followup of screen-negative children; heterogeneity of screening modality and screening procedures; limited description of screening populations and subgroups | Low | Moiré topography and surgeon-conducted screening may not be feasible in U.S. school-based screening programs
KQ 3 bracing | K=3 n=347 RCT/CCT K=2 n=304 observational | Curve progression: 4 prospective studies (1 RCT), suggest a benefit to bracing Dose-response: Evidence for dose-response relationship between hours of brace wear and curve progression in 1 study Quality of life: Similar at baseline and followup in IG and CG | Reasonably consistent Imprecise | Undetected | 3 Fair 2 Good | Higher-quality studies show benefit of bracing; smaller studies not powered to look at curve outcomes found nonsignificant results. Very limited data on QOL associated with bracing. | Moderate | Likely applicable to U.S. settings; brace types in included studies all available in U.S.
KQ 3 exercise | K=2 n=184 RCT/CCT | Curve progression: In 1 good-quality RCT, intervention group had a favorable reduction in Cobb angle of 4.9° vs. an unfavorable 2.8° progression in control group. A smaller, fair-quality CCT published earlier found similar results. Quality of life: Improved pain, function, self-image, and mental health; lack of improvement in control group | Reasonably consistent Imprecise | Undetected | 1 Good 1 Fair | Only 2 included studies; blinding of treatment allocation not possible | Low | Likely applicable to U.S. setting given access to trained physiotherapist
KQ 3 surgery | No studies | NA | NA | NA | NA | NA | NA | NA
KQ 4 | K=2 n=339 | No direct evidence on association between curve at skeletal maturity and adult outcomes. However, quality of life, pulmonary, and pregnancy outcomes were similar for adults who had received observation, bracing, and surgery in adolescence. | Reasonably consistent Imprecise | Undetected | 2 Fair | Small body of evidence, studies not designed to answer current KQ | Low | Limited; some obsolete treatments were included
KQ 5 | No studies | NA | NA | NA | NA | NA | NA | NA
KQ 6 bracing | K=1 n=242 CCT | 1/146 anxiety/depression requiring hospitalization in braced group vs. 0/96 in control group; 3/146 anxiety/depression in IG vs. 1/96 in CG Skin problems on trunk more likely in braced group (12/146) than controls (0/96); higher rate of nonback pain in braced vs. controls (12/146 vs. 2/96). Similar rates of abnormal breast development, neurologic symptoms, and GI or respiratory symptoms in braced vs. controls | NA (1 study) | Undetected | 1 Good | One study | Low | Likely applicable in U.S. primary care setting
KQ 6 surgery | No studies | NA | NA | NA | NA | NA | NA | NA
KQ 6 exercise | No studies | NA | NA | NA | NA | NA | NA | NA

Abbreviations: KQ=key question; NA=not applicable; IG=intervention group; CG=control group; RCT=randomized, controlled trial; CCT=controlled clinical trial; PPV=positive predictive value; ATR=angle of trunk rotation; GI=gastrointestinal; FBT=forward bend test; S=scoliometer; M=Moiré topography.

In summary, there is a developing body of evidence suggesting that the progression of mild and moderate AIS curves during adolescence can be interrupted or slowed with nonsurgical intervention. Whether this is beneficial to persons with AIS over the life course, however, depends on whether the curve at the end of growth is associated with improved outcomes in adulthood.

### Health Outcomes in Adulthood

The 1993 USPSTF review discussed the limited information available on long-term health outcomes in persons with AIS, but the evidence base was limited to uncontrolled studies, not restricted to subjects with AIS, and the USPSTF arrived at a statement of insufficient evidence for long-term health outcomes.

For the current review, two studies on long-term health outcomes met our inclusion criteria. Both studies assessed adult outcomes (1 to 2 decades or more after skeletal maturity) in persons with mild-to-moderate AIS who were treated or observed in adolescence.^111-115^ However, results were stratified by treatment group in adolescence rather than by magnitude of curve at skeletal maturity, which significantly limits the ability to draw conclusions about the utility of limiting curve progression with brace or exercise treatment during adolescence. At followup, braced participants felt their body appearance was more distorted than did untreated participants,^112^ and also recalled experiencing a negative effect on their life during the treatment period compared to those treated surgically.^113^ No other significant differences between observed, braced, and surgically-treated groups were reported for various measures of quality of life, and no significant difference in certain pulmonary outcomes or childbearing and pregnancy outcomes were reported in adulthood for either the braced or surgically-treated participants.^114, 115^

## Limitations of the Review

Among the most important limitations of this review is its scope, which was intentionally limited to evaluation of persons with mild-to-moderate AIS (major curve <50°) at diagnosis. This was done to ensure that the evidence reviewed would be pertinent to the population that would be identified through universal clinic-based or school-based screening programs. The proportion of adolescents who have curves of a greater magnitude is small (the prevalence of AIS with a curve >40° in the general population is <0.1%),^6^ and many of these persons will be identified even in the absence of screening programs.^142^ In addition, their expected clinical course (continued curve progression throughout adolescence and adulthood) is quite different than for those with curves of lesser severity. Conversely, for the majority of screen-positive persons, AIS will be a benign condition; however, a proportion of those who cannot readily be identified at the outset will have a more progressive course. It was therefore felt to be most important to limit our focus to the evidence on this group, as those with larger curves at presentation are likely to have a vastly different clinical course.

AIS is a challenging condition to treat and to study, in large part because many characteristics of the condition (e.g., age of onset, type of curve, severity of curve, likelihood of progression, rapidity of progression, likelihood of continued progression in adulthood, treatment response) vary greatly and are further modified by sex and developmental maturity—all of which makes the results of trials with heterogeneous study populations difficult to interpret. There is a large body of literature that informs our overall clinical understanding of treatment and long-term prognosis of AIS; however, much of this research is not designed to specifically address a screening population rather than those AIS cases that would be picked up clinically as the curve progressed.

Studies without valid comparison groups and studies of surgical intervention without data on curve progression before surgery were excluded. Also excluded were a large number of studies with no comparison group, comparative effectiveness studies, longitudinal studies that did not report health outcomes in adulthood, studies in which screening was conducted by a single practitioner, and studies in which screening results were not objectively measured. Quality rating of studies, some of which were published as far back as 1966, further limited the body of evidence, as many were conducted before currently accepted quality measures and reporting standards were established. The decision to not pool or perform meta-analysis on results based on heterogeneity of the included outcomes limited interpretation of single estimates of harm or benefit.

The literature itself has several limitations. We found no published studies that met our inclusion criteria for several KQs in this review. There is no direct evidence for the impact of screening for AIS on long-term health outcomes, and no high-quality evidence on the harms associated with screening. The evidence base for treatment of AIS that is less than 50° at diagnosis has improved since the last review, but still has significant deficits (e.g., we found relatively few prospective controlled trials of treatment during our literature search, and there is an absence of high-quality studies on surgical procedures that include a comparison group of nonsurgically treated patients with AIS). Unfortunately, these gaps in the literature may not be easy to fill; for example, the difficulty in recruitment that occurred in the multisite BrAIST trial (which was converted from an RCT to a patient-preference controlled trial) and in a Dutch RCT (which was not completed due to insufficient enrollment)^143, 144^ demonstrate that families of children with AIS are often reluctant to allow treatment decisions to occur as a result of randomization. Studies of surgical treatment in persons with mild-to-moderate AIS may also not be feasible, as bracing is often recommended as a first-line treatment to avoid an invasive spinal surgery (although newer surgical techniques intended for treatment of moderate AIS curves have been developed).^145^ Perhaps most significant, the lack of long-term outcomes data stratified by degree of curve at skeletal maturity significantly impedes our ability to draw a strong conclusion about whether the ability to limit curve progression during adolescence is in fact an important endpoint.

## Future Research Needs

A number of observational cohorts of persons with AIS have been identified; however, the utility of data from these cohorts is often limited by lack of a control group (e.g., a prospectively-identified comparison group of unscreened or untreated persons) or by lack of pertinent baseline information (e.g., degree of curvature at diagnosis and at skeletal maturity, developmental maturity at diagnosis). The body of evidence on population-based screening for AIS would therefore be most significantly strengthened by prospective identification of cohorts at the time of diagnosis (e.g., from areas with and without routine AIS screening) or treatment (e.g., treated and observed cohorts) for the purpose of long-term followup.

Also needed are screening studies with a prospective controlled study design, for comparison of screened and nonscreened populations, different screening settings (e.g., school vs. clinic), screening personnel (e.g., school staff vs. general health care personnel vs. medical specialist), and screening procedures (i.e., trunk rotation with or without other physical findings, such as shoulder asymmetry). Data on screening results should be reported in subgroups, including females and children with a family history of scoliosis. Prospective, systematic collection of data on the potential harms of screening—including psychosocial effects and radiation exposure estimates for screened (as opposed to treated) populations— is also needed.

The utility of screening is ultimately determined by whether any treatment prescribed to those persons identified through screening programs is effective at improving long-term health outcomes. Therefore, the body of evidence in support of screening would be strengthened by good-quality studies of treatment, such as additional prospective controlled studies on exercise and brace treatment (including prospectively identified untreated control groups), and studies on surgical treatment, including—if appropriate—true prospectively-identified control groups that receive nonsurgical treatment. Although the evidence on effectiveness of bracing compared to observation has improved, additional studies to help determine whether individual characteristics may influence response to treatment would be beneficial (e.g., there is recent research to suggest that high or low body mass index may affect response to bracing).^146^ Whenever possible, treatment studies should include assessments of physical and psychological adverse events, and have a provision for long-term followup. Studies on long-term outcomes should have stratification of outcome results by degree of curvature at diagnosis and at skeletal maturity, for the purpose of better understanding the long-term outcomes for identifiable subgroups of persons with AIS.

## Conclusion

We found no direct evidence for a benefit of universal AIS screening of adolescents on long-term health outcomes. There is evidence that demonstrates that AIS can be identified with the most commonly used screening test for AIS (FBT with scoliometer, followed by referral for diagnostic imaging), although estimates of predictive value and sensitivity are variable, and the majority of persons identified through screening will never require treatment. Theoretical harms of universal screening have been proposed, but high-quality evidence is lacking. A growing body of evidence suggests that brace treatment can interrupt or slow progression of scoliosis curves before skeletal maturity; and limited evidence suggests that curves of smaller magnitude may respond similarly to physiotherapeutic scoliosis-specific exercise treatment. Surgical treatment remains the standard of care for curves that progress to greater than 40° to 50°; however, there are no controlled studies of surgical versus nonsurgical treatment in persons with lower degrees of curvature at AIS detection, which would represent a likely screening population. Although long-term observational studies suggest that continued curve progression in adulthood is less likely if the magnitude of the curve at skeletal maturity is smaller, and that very high degrees of curvature may be associated with pathology in later adulthood, direct evidence on the association between magnitude of curve at skeletal maturity and adult quality of life outcomes is lacking.