# Chapter 3 Results

## Literature Search

We reviewed 8,230 unique abstracts and 1,088 full-text articles (Appendix A Figure 1). We included 26 unique articles. We included seven studies (13 articles) on screening accuracy (KQ 2), seven studies (nine articles) on the effectiveness of treatment (KQ 3), one study (two articles) on the harms of treatment (KQ 6), and two studies (five articles) on long-term outcomes (KQ 4). No studies met our inclusion criteria on the effect of AIS screening on long-term health outcomes (KQ 1) or the harms of screening (KQ 5).

Of 179 full-text articles reviewed for eligibility for KQ 2, seven fair-quality screening programs (13 articles) including 447,243 adolescents met our inclusion criteria. Articles were most commonly excluded for ineligible or inadequately described screening programs or for lack of relevant outcomes.

Of the 733 full-text articles reviewed for eligibility for KQ 3, seven studies (nine articles) of 835 persons with AIS met our inclusion criteria, including two studies of physiotherapeutic scoliosis-specific exercise treatment (one of fair quality and one of good quality) and five studies of bracing treatment (three of fair quality and two of good quality). No studies of surgery or other treatments met our inclusion criteria. Most common reasons for exclusion were ineligible study design and ineligible outcomes, most commonly for incomplete data to inform the question. Among the six studies excluded based on quality, the most common reasons for exclusion were inadequate information on the study population and imprecise selection of control groups.

Of the 263 full-text articles reviewed for KQ 4, two fair-quality studies (five articles) of 339 persons with AIS met our inclusion criteria. Most common reasons for exclusion were ineligible study design and ineligible outcomes, most commonly for lack of adult health outcomes reported.

Of the 733 full-text articles reviewed for eligibility for KQ 6, one good-quality observational study (two articles) of 242 persons with AIS met our inclusion criteria.

## Results of Included Studies

### KQ 1 Does Screening for AIS Improve: a) Health Outcomes, and b) the Degree of Abnormal Spinal Curvature in Childhood or Adulthood?

We found no RCTs or controlled clinical trials (CCTs) that evaluated the impact of screening for AIS on severity of curve or adult health outcomes compared to no screening.

### KQ 2 What Is the Accuracy of Screening for AIS?

#### Summary of Results

Seven fair-quality screening programs (13 articles) of 447,243 adolescents met our inclusion criteria. Three of the seven studies included some followup data on children who screened negative. Accuracy increased with the number of screening tests used. Sensitivity and specificity (93.8% and 99.2%) and predictive value (81.0%) were highest and false-positive rates were lowest (0.8% [6.2% false-negative rate]) in a Hong Kong clinic-based screening program using FBT with scoliometer followed by intermediate Moiré topography screening in suspected cases, a screening approach that may have limited practical applicability in U.S. settings. A retrospective review of a U.S. school-based screening program that initially used FBT alone and added scoliometer partway through the study period found a sensitivity of 71.1 percent (95% CI, 54.1 to 84.6), a specificity of 97.1 percent (95% CI, 96.3 to 97.7), and a false-negative rate of 28.9 percent (2.9% false-positive rate). The lower sensitivity of the U.S. screening program may be due to the absence of Moiré topography screening and absence of scoliometer use for part of the program.^93^ Estimates of positive predictive value for FBT plus scoliometer ranged from 29.3^7^ to 54.1 percent.^94-96^ Predictive values were lowest for single modalities, from 5.0 percent for rib hump measurement to 17.3 percent for FBT alone.^52^ Detected curves were 10° to 20° at screening for 40.7 to 87.4 percent of true-positive children, and greater than 40° for 0.8 to 22.2 percent of true-positive children.

#### Detailed Results

##### Description of Included Studies

Screening programs ranged from 2,242^7^ to 306,082 children screened^54, 93, 97^ (Table 3 and Table 4). The Hong Kong screening program was conducted in regional clinics; all other screening programs were conducted in school settings. Children screened ranged from ages 8 to 16 years, though precise ages were inconsistently reported across studies, sometimes using grade levels or age ranges. One of the seven programs, which had the smallest study population, took place in the United States.

Table 3 Description of Included Screening Programs That Provide Data on Screen-Negative Children (KQ 2)

Screening Program | Population | Screening Test | Screening Procedure | Referral Criteria | Diagnostic Test | Diagnostic Criteria | Followup of Screen Negatives
Rochester, MN^7^ USA School Fair | Screened n=2,242 Age: NR (US grades 5–9) % Female: NR Race: NR All children entering public/private schools K (1979–1981) or 1st grade (1980–1982) and screened ≥3 times | FBT alone (1984–85) FBT with scoliometer (1986–91) Annual screenings over multiple years 1984–91 Followup to 1994 | Public health nurse supervised by orthopedic surgeon during PE class Repeat screening at 2–4 weeks for ATR >6° or obvious curve on FBT | >6° ATR on scoliometer or obvious curve on FBT | X-ray Standing full-spine Dose NR Operator NR | Cobb angle >10° | Rochester Epidemiology Project Diagnostic Index searched for all diagnoses of “scoliosis” or “rule out scoliosis”
Hong Kong^54,93,97^ Regional clinics Fair | Screened n=306,082^*^ Age: NR (Hong Kong 5th grade or age ≥10 years) % Female: NR Race: NR 5th graders screened at least once before age 19 | FBT with scoliometer, then Moiré (≥5° to <15° ATR only) Screenings biennially or more frequently 1995–2000 Followup 10 years or to age 19 | Physicians and registered nurses | ≥15° ATR on scoliometer -or- ≥2 Moiré lines difference -or- significant clinical signs | X-ray Standing posteroanterior Read by orthopedists | Cobb angle ≥10° | Department of Health and two scoliosis specialist hospitals on all visits of 5th grade students during screening period
Greece (Samos island)^52^ School Fair | Screened n=2,700 Age range: 8–16 years % Female: NR Race: NR Inclusion: School children age ≥8 years in local schools | Clinical exam, FBT, humpometer, scoliometer, and Moiré topography Single screening: 1987 Followup 10 years | Teams of 2 orthopedic surgeons; medical, nursing and paramedical staff Students assessed for all screening methods by two independent evaluations | Positive FBT -or- Positive Moiré (NR) -or- Humpometer: >5 mm -or- Scoliometer: ATR >0° | X-ray Conventional standing anteroposterior (for scoliosis) or low-dose long chest x-ray (for lung disease) Operator: NR | Cobb angle ≥10° | All students received low-dose long chest x-ray

* Does not include 62 students diagnosed with nonidiopathic scoliosis by age 19 years.

Abbreviations: KQ=key question; NR=not reported; FBT=forward bend test; PE=physical education; ATR=angle of trunk rotation.

Table 4 Description of Screening Programs With No Information on Screen-Negative Children for Detection of Scoliosis of >10° (KQ 2)

Screening Program | Population | Screening Test and Followup | Screening Procedure | Referral Criteria | Diagnostic Test | Diagnostic Criteria
Ireland (Dublin)^94-96^ School Fair | Screened n=8,669^*^ Age (mean, 12.9 [SD, 1.4]) % Female: 100% Race: NR Primary and postprimary school girls receiving first screening | FBT with scoliometer Single screening 1986–1987 Followup 1–4 years | School doctors (primary); PE teachers or school nurses (postprimary). Findings confirmed by medical staff and at hospital-based clinic. | Premenarche: Thoracic hump 8° or loin hump 10° Postmenarche: Thoracic hump 10° or loin hump 15° | X-ray Standing posteroanterior Operator: NR | Cobb angle >10°
Singapore^8^ School Fair | Screened n=40,649^†^ Age: 9–10: 16,755 (41.2%)^†^ 11–12: 18,101 (44.5%)^†^ 13–14: 5,793 (14.3%)^†^ % Female: 50.3%^†^ Race: NR Primary and secondary schools | FBT with scoliometer Single screening (1997) Followup: NR | Nurse during PE class Scoliometer findings confirmed by medical officer | ATR ≥5° on scoliometer | X-ray Standing posteroanterior Read by 2 orthopedic surgeons | Cobb angle ≥10°
Norway^101^ School Fair | Screened n=4,000 Age: 12–13 % Female: NR^‡^ Race: NR Health Region South (Norway) | FBT with scoliometer Single screening (year NR) Followup: NR | Public health/community nurses and physical therapists | ATR >7° on scoliometer | X-ray Standing, at local hospitals and mailed to university hospital | Cobb angle >10°
Greece (Northwestern and Central)^98-100^ School Fair | Screened n=82,901 Mean age: 12.4 (range, 9–14) % Female: 49.4% Race: NR Schoolchildren ages 9–14 years | FBT with level plane and ruler Single screening 1993 –1994 Followup: NR | Teams of orthopedic residents, medical students, and senior orthopedic surgeons. Repeat screen same-day for suspected scoliosis. | >5 mm difference at thoracic or thoracolumbar -or- significant clinical signs | X-ray Standing posteroanterior at local hospital Operator: NR | Cobb angle ≥10°

Note: Italicized values were not provided in the article(s) and were calculated.

* Does not include 17 participants who did not show up for a re-examination and were excluded.

† Excludes ages 6–7 years (n=32,050).

‡ Article reports there was “a similar distribution of girls and boys.”

Abbreviations: KQ=key question; SD=standard deviation; NR=not reported; FBT=forward bend test; PE=physical education; ATR=angle of trunk rotation.

All studies used the FBT with some quantitative measurement of trunk rotation; six of seven studies used a scoliometer, and one used a level plane and ruler.^98-100^ A screening program conducted in Samos Island, Greece also screened children with Moiré topography and measurement with a humpometer; however, estimates were not provided for any combinations of screening modalities, such as FBT plus scoliometer.^52^ The large screening program from Hong Kong also included an intermediate post-FBT Moiré topography screening for children with an ATR between 5° and 15° on scoliometer.^54, 93, 97^ Screenings were conducted by nurses, physical therapists, or school physicians; in two screening programs, both conducted in Greece, orthopedic surgeons conducted the screenings.^52, 98-100^ Referral criteria to x-ray varied from any trunk rotation^52^ to trunk rotation of 15° or greater;^54, 93, 97^ many programs referred to x-ray based on one of multiple criteria, including subjective judgment of the screener. All studies used a Cobb angle of either 10° or greater of the major curve as criteria for a diagnosis of scoliosis. Five of seven studies reported results of a single screening episode;^8, 52, 94-96, 98-101^ two reported cumulative results of multiple years of repeated screening.^7, 54, 93, 97^

Three of the seven screening programs reported data on 311,086 children who had screened negative at initial screening using a case definition of a Cobb angle greater than 10°^7^ or 10° and greater^52, 54, 93, 97^ (Table 3). In the U.S.-based study, a regional epidemiologic index was used to identify all cases of AIS in the region where the screening program had been conducted, thus enabling the detection of the eventual development of scoliosis in someone who had screened negative.^7^ In Hong Kong, data from the regional health department and two specialist hospitals were reviewed to identify scoliosis cases diagnosed until age 19 years.^54, 93, 97^ It is worth noting that in both of these programs, significant time could have elapsed between screening and eventual detection of AIS. In Samos Island, Greece, a companion study of screening for lung disease allowed x-ray screening of all children regardless of their scoliosis screening results.^52^ Although incomplete data are provided for each screening modality explored, accuracy measures can be calculated from the numbers provided.

In the Ireland screening program, screen-negative children were rescreened after 1 to 4 years; however, data are only provided for cases with a Cobb angle of 40° or greater.^94-96^

##### Study Results: Screening Accuracy

Three of the seven screening programs reported data on 311,086 children who had screened negative at initial screening, allowing estimation of sensitivity, specificity, false-positive rate, false-negative rate, and predictive value. The remaining four studies did not report followup data on screen-negative children; for these studies only, positive predictive values are reported (Table 5).

Table 5 Results on Accuracy of Scoliosis Screening (KQ 2)

Screening Programs With Followup of Screen-Negative Children | Screening Test | Number of Screenings | N Screened | PPV (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | False- Positive Rate | False- Negative Rate | Prevalence of AIS >10° Cobb Angle^*^
Rochester, USA^7^ Fair | FBT±S^†^ | Annual over multiple years | 2,242 | 29.3% ^ ‡ ^ (20.3–39.8) | 71.1% (54.1–84.6) | 97.1% ^ ‡ ^ (96.3–97.7) | 2.9% ^ ‡ ^ | 28.9% | 1.7%
Hong Kong^54, 93, 97^ Fair | FBT+S±M | Biennial or more often | 306,082 ^ § ^ | 81.0%^‡^ (80.3–81.7) | 93.8% (93.3–94.3) | 99.2% ^ ‡ ^ (99.2–99.2) | 0.8% ^ ‡ ^ | 6.2% | 3.5% ^ ‡ ^
Greece (Samos Island)^52^ Fair | FBT | One-time | 2,700 | 17.3% (11.7–24.2) | 84.4% (67.2–94.7) | 95.2% (94.3–95.9) | 4.8% | 15.6% | 1.2%
Greece (Samos Island)^52^ Fair | S | One-time | 2,700 | 5.3% (3.6–7.6) | 90.6% (75.0–98.0) | 80.7% (79.1–82.1) | 19.3% | 9.4% | 1.2%
Greece (Samos Island)^52^ Fair | M | One-time | 2,700 | 7.6% (5.3–10.6) | 100.0% (84.2–100) | 85.4% (84.0–86.7) | 14.6% | 0.0% | 1.2%
Greece (Samos Island)^52^ Fair | H | One-time | 2,700 | 5.0% (3.4–7.0) | 93.8% (79.2–99.2) | 78.5% (76.9–80.0) | 21.5% | 6.3% | 1.2%
Screening Programs With No Followup of Screen-Negative Children | Screening Test | Number of Screenings | N Screened | PPV (95% CI) | Sensitivity | Specificity | False- Positive Rate | False- Negative Rate | Screening Yield of AIS >10° Cobb Angle^*,*^
Ireland^94-96^ Fair | FBT+S | One-time | 8,669^††^ | 54.1% (40.8–66.9) | NR | NR | NR | NR | 0.4%
Singapore^8^ Fair | FBT+S | One-time | 40,649 ^ ‡‡ ^ | 41.2% ^ ‡‡ ^ (37.4–45.1) | NR | NR | NR | NR | 0.7% ^ ‡‡ ^
Norway^101^ Fair | FBT+S | One-time | 4,000 | 36.7% (24.6–50.1) | NR | NR | NR | NR | 0.6%
Greece (NWC)^98-100^ Fair | FBT+PL | One-time | 82,901 | 34.3% (32.9–35.8) | NR | NR | NR | NR | 1.7%

Note: Italicized values were not provided in the article(s) and were calculated.

* Calculated as number of disease positives (true-positives + false-negatives) divided by the total number screened.

† Rochester screening program used FBT only (1984–85) before FBT plus scoliometer (1986–91).

‡ Assumes those lost to followup are false-positives.

§ Does not include 62 students diagnosed with nonidiopathic scoliosis by age 19 years.

** Calculated as number of true-positives divided by the total number screened.

†† Does not include 17 participants who did not show up for a re-examination and were excluded.

‡‡ Excludes ages 6–7 years (n=32,050).

Abbreviations: KQ=key question; AIS=adolescent idiopathic scoliosis; NWC=northwestern and central; FBT=forward bend test; S=scoliometer; M=Moiré topography; H=humpometer; PL=plane/level; NR=not reported; PPV=positive predictive value; CI=confidence interval.

Sensitivity/specificity. Sensitivity was 71.1 percent (95% CI, 54.1 to 84.6) and specificity was 97.1 percent (95% CI, 96.3 to 97.7) for FBT with scoliometer over multiple years of screening.^7^ For FBT with scoliometer plus intermediate Moiré topography screening before x-ray confirmation, sensitivity was 93.8 percent (95% CI, 93.3 to 94.3) and specificity was 99.2 percent (95% CI, 99.2 to 99.2).^54, 93, 97^ For one-time screening with FBT alone, sensitivity was 84.4 percent (95% CI, 67.2 to 94.7) and specificity was 95.2 percent (95% CI, 94.3 to 95.9).^52^ Estimates for other single modality, one-time screening included rib hump measure (sensitivity, 93.8% [95% CI, 79.2 to 99.2]; specificity, 78.5% [95% CI, 76.9 to 80.0]);^52^ scoliometer alone (sensitivity, 90.6% [95% CI, 75.0 to 98.0]; specificity, 80.7% [95% CI, 79.1 to 82.1]); and Moiré topography (sensitivity, 100% [95% CI, 84.2 to 100]; specificity, 85.4% [95% CI, 84.0 to 86.7]).^52^ The variation in reported sensitivity may be due to the heterogeneity of screening modalities used; one analysis of the cohort screened with FBT, scoliometer, and Moiré topography demonstrated that the sensitivity would drop substantially if Moiré topography was excluded from the program.^93^ Another analysis of this cohort also demonstrated that accuracy of screening (defined as sensitivity + positive predictive value) was directly related to the number of screening tests used in combination, being highest when three tests (ATR + Moiré + clinical signs) were employed, lower with various combinations of two tests, and lowest when a single test (ATR) was used alone.

False-positive and false-negative rates. The lowest false-negative and false-positive rates were for FBT with scoliometer followed by Moiré topography for suspected cases before x-ray confirmation (0.8% false-positive, 6.2% false-negative). A U.S.-based study of FBT with scoliometer found 2.9 percent false-positive and 28.9 percent false-negative results.^7^ FBT alone had a 4.8 percent false-positive rate (15.6% false-negative) in one study. Other single modalities were associated with the highest false-positive rates: 19.3 percent (9.4% false- negative) for scoliometer alone; 14.6 percent (0% false-negative) for Moiré topography alone; and 21.5 percent (6.3% false-negative) for rib hump measure alone.^52^

Predictive value. Estimates of positive predictive value were available in all seven studies; estimates for FBT plus scoliometer ranged from 29.3 percent^7^ (95% CI, 20.3 to 39.8) to 54.1 percent (95% CI, 40.8 to 66.9).^94-96^ The highest predictive value was 81.0 percent (95% CI, 80.3 to 81.7) for FBT with scoliometer and Moiré topography.^54, 93, 97^ The lowest estimates were for single modalities, ranging from 5.0 percent (95% CI, 3.4 to 7.0) for rib hump measurement to 17.3 percent (95% CI, 11.7 to 24.2) for FBT alone.^52^

##### Study Results: Curve at Screen Detection

Two of seven studies provided data comparing the degree of curvature in children with screen-positive and false-negative screening results and eventual scoliosis diagnosis.^7, 54, 93, 97^ In the U.S.-based study, distributions of curve were similar for children detected through school-based screening compared to those who were detected clinically^7^ (Table 6). However, in the Hong Kong-based multitiered screening program, curve distributions in screen-detected cases tended to be a lower degree of curvature (curves of 10°–19° comprised 50.9% of the screen-detected vs. 26.2% of the false-negative population).^54, 93, 97^

Table 6 Characteristics of Screen-Detected AIS and False-Negative Populations (KQ 2)

Screening Programs With Followup of Screen-Negative Children | N | Test | True Positives (n) | Curve Description (Cobb Angle) of Screen-Detected AIS | False Negatives (N) | Curve Description of AIS False Negatives
Rochester, USA^7^ Fair | 2,242 | FBT±S^*^ | 27 | 11°–19°: 40.7% 20°–39°: 37.0% ≥40°: 22.2% | 11 | Cobb 11°–19°: 45.5% Cobb 20°–39°: 36.4% Cobb ≥40°: 18.2%
Hong Kong^54, 93, 97^ Fair | 306,082 ^ † ^ | FBT+S±M | 10,160 | 10°–19°: 50.9% 20°–39°: 43.4% ≥40°: 5.6% | 671 | Cobb 10°–19°: 26.2% Cobb 20°–39°: 49.2% Cobb ≥40°: 24.6%
Greece (Samos Island)^52^ Fair | 2,700 | FBT, S, M, H | 27 (FBT), 29 (S), 32 (M), 30 (H) | 10°–15°: 68.8%^‡^ 15°–20°: 21.9%^‡^ >20°: 9.4%^‡^ | 5 (FBT), 3 (S), 0 (M), 2 (H) | NR
Screening Programs With No Followup of Screen-Negative Children | N | Test | True Positives (n) | Curve Description (Cobb Angle) of Screen-Detected AIS | False Negatives (n) | Curve Description of AIS False Negatives
Ireland^94-96^ Fair | 8,669^§^ | FBT+S | 33 | 10°–39°: 93.9% ≥40°: 6.1% | NR | NR
Singapore^8^ Fair | 40,649^**^ | FBT+S | 267^**^ | 10°–19°: 59.6%^**^ 20°–29°: 26.2%^**^ ≥30°: 14.2%^**^ | NR | NR
Norway^101^ Fair | 4,000 | FBT+S | 22 | 10°–20°: 77.3% >20°: 22.7% | NR | NR
Greece (NWC)^98-100^ Fair | 82,901 | FBT+PL | 1,436 | 10°–19°: 87.4% 20°–29°: 10.0% 30°–39°: 1.8% ≥40°: 0.8% | NR | NR

Note: Italicized values were not provided in the article(s) and were calculated.

* Rochester screening program used FBT only (1984–85) before FBT plus scoliometer (1986–91).

† Represents 306,144 screened minus 62 students diagnosed with nonidiopathic scoliosis by age 19 years.

‡ Refers to Cobb angles for disease-positive AIS (true-positives plus false-negatives).

§ Does not include 17 participants who did not show up for a re-examination and were excluded.

** Excludes ages 6–7 years (n=32,050).

Abbreviations: KQ=key question; AIS=adolescent idiopathic scoliosis; FBT=forward bend test; S=scoliometer; M=Moiré topography; H=humpometer; PL=plane/level; NR=not reported; NWC=northwestern and central.

In the five studies with data on screen-detected cases only, the majority of cases detected were at a Cobb angle of less than 20° (Table 6), a level at which expectant management may be the most common treatment. All studies reported different categories of curvature. Four studies reported proportions of children with curves greater than 40° at detection (a degree that may warrant surgical intervention) of 0.8 percent,^98-100^ 5.6 percent,^54, 93, 97^ 6.1 percent,^94-96^ and an especially high 22.2 percent in the U.S.-based study.^7^ This study also found the lowest reported sensitivity with use of either FBT alone or FBT plus scoliometer. Curves of milder magnitude would be less likely to be identified by less-sensitive screening regimens, especially FBT alone. Two studies reported proportion of screen-detected cases with curves at 30° (where bracing may be recommended); 4.2 percent^8^ of cases were 30° or greater and 1.8 percent were 30° to 39°.^98-100^

#### Limitations

All studies were fair-quality observational studies with heterogeneity of screening modality, screeners, and screening procedures. The single U.S.-based study began with FBT alone and progressed to FBT with scoliometer during the study period, which may attenuate estimates of screening accuracy. In addition, the only study that prospectively conducted gold-standard x-ray on all children regardless of screening result screened children as young as age 8 years, which is outside the accepted definition of AIS (ages 10–18 years).^52^ Further, the accuracy of combinations of screening modalities, such as FBT plus scoliometer, are not reported and thus may not completely reflect current clinical practice. This heterogeneity precluded direct comparison across studies, and resulted in significant variation in reported screening sensitivity and in the percentage of persons with higher degree of curvature at diagnosis. The single study that had very high accuracy was clinic-based, conducted by physicians and nurses, and used a unique multitiered screening procedure in which children with suspected AIS were screened with Moiré topography before referral to x-ray confirmation. Screening populations and disease-positive populations were generally not described in detail, and no subgroup analyses were reported, limiting assessment of population characteristics and their potential contributions to the heterogeneous accuracy estimates.

### KQ 3 Does Treatment of AIS That Has a Cobb Angle of Less Than 50° at Diagnosis Improve: a) Health Outcomes, and b) the Degree of Spinal Curvature in Childhood or Adulthood?

#### Summary of Results

Five studies (seven articles) of bracing (n=651) and two studies (two articles) of exercise treatment (n=184) met our inclusion criteria. No studies of surgery met our criteria.

Of the bracing studies, four of five prospective controlled studies (including one RCT) provide evidence for benefit of bracing treatment on curve progression compared to observed controls, either in favorable proportions of children with 5° to 6° of progression (three of five studies) or in curve progression to a degree considered bracing failure (one study). Two included trials were terminated early because of evidence of benefit favoring bracing. Quality of life outcomes associated with bracing were reported in one study and were similar between treatment arms.

The two studies of exercise treatment (one RCT, one CCT) compared an intervention group treated with a tailored, physiotherapeutic scoliosis-specific exercise regimen to a generic exercise control group. Different exercise regimens were assessed in each study; both are based on active self-correction principles. In both studies, the intervention group experienced a favorable reduction in Cobb angle at 12-month followup (RCT) or at the end of the 12-month treatment period (CCT) compared to an unfavorable increase in Cobb angle in the control group. The RCT included measures of quality of life; all of these were notable for steadily improving values at 12 months in the intervention group compared to stable or slightly improving measures in the control group.

#### Detailed Results

##### Description of Included Studies

Brace treatment. The five studies of bracing effectiveness included one fair-quality RCT,^102^ one fair- and one good-quality prospective CCT,^103-105^ one good-quality prospective observational study,^106, 107^ and one fair-quality retrospective observational study.^96^ The one good-quality prospective CCT began as an RCT but was later converted to a patient-preference controlled trial. All studies included a comparison group that was not initially treated with bracing; however, the studies prespecified a clinical threshold beyond which treatment (bracing or surgery) would be initiated. Sample sizes ranged from 37^103^ to 242^104, 105^ participants (Table 7).

Table 7 Description of Included Bracing Studies (KQ 3)

Study | Study Design Study Years | Setting | N | Type of Brace (IG) | Hours/Day of Brace Wear | Comparison Group | Study Endpoint Additional Treatment | Mean Duration of Treatment (IG) or Followup (CG), Years | Outcomes Reported
Coillard 2014^*,102^ Canada Fair | RCT 1998–2007 | 1 university hospital | 68 IG: 32 CG: 36 | Spine-Cor | 20 | Observation | IG: 5 years CG: 5 years or progression of ≥6°. If progression, offered treatment but not removed from CG. | IG: 2.1 (range, 1.5–3) CG: NR | Curve progression
Wiemann 2014^103^ USA Fair | CCT NR | 2 pediatric orthopedic specialty practices | 37 IG: 21 CG: 16 | Charleston bending | Nights only | Observation | IG+CG: Skeletal maturity. Surgery offered in IG+CG at discretion of treating surgeon if curves progressed to >50° IG: Daytime TLSO brace added if curves progressed past 25° CG: Full-time TLSO brace added if curve progressed to 25° or increased by >5° | IG: 3.3 CG: 2.8 | Curve progression
BrAIST^*,104,105^ Weinstein 2013 USA, Canada Good | CCT 2007–2013 | 25 hospital- and/or university-based centers | 242^†^ IG: 146 CG: 96 | Rigid TLSO (various) | 18 | Observation | IG+CG: Skeletal maturity or Cobb angle ≥50° | IG: 2.0 CG: 1.8 | Curve progression Quality of life Back pain
SRS Bracing Study^‡,106, 107^ Nachemson 1995 Sweden, USA, UK, Canada Good | Prospective observational 1985–1989 | 8 centers | 240 IG: 111 CG: 129 | Boston^§^ | >16 | Observation | IG+CG: Skeletal maturity | NR | Curve progression
Goldberg 1993^96^ USA, Ireland Fair | Retrospective observational 1971–1981 | IG: Hospital-based clinic CG: School screening program databank | 64 IG: 32 CG: 32 | Boston | 23 | Observation | IG+CG: Skeletal maturity IG: Weaning to parttime bracing at skeletal maturity CG: Bracing recommended if curve progressed to 35° before menarche | NR | Curve progression

* Recruitment in Coillard 2014 and BrAIST were terminated early because of evidence of benefit favoring bracing.

† 47.9% of population from RCT.

‡ Study reports severity of major curve at inclusion, not treatment initiation.

§ Bracing system also involves a coordinated exercise program.

Abbreviations: KQ=key question; RCT=randomized, controlled trial; CCT=controlled clinical trial; IG=intervention group; CG=control group; NR=not reported; TLSO=thoracolumbosacral orthotic; BrAIST=Bracing in Adolescent Idiopathic Scoliosis Trial; SRS=Scoliosis Research Society.

Bracing effectiveness studies were conducted at 38 clinical sites in five countries. One study (the Scoliosis Research Society's multicenter bracing trial, or the SRS bracing cohort) included participants from Canada, Sweden, the United Kingdom, and the United States;^106, 107^ one included participants from both Ireland and the United States;^96, 108^ one from Canada and the United States;^104, 105^ one from Canada only;^102^ and one exclusively from the United States.^103^ Participants were drawn from populations referred to specialty orthopedic centers in the four prospective studies.^102-107^ Participants in the retrospective study^96^ were drawn from two sources: braced adolescents were identified from an earlier treatment study of girls referred to a specialty orthopedic center in Boston;^108^ the observation group was identified from a school scoliosis screening program in Dublin, Ireland (Table 8).^94-96^

Table 8 Study Populations: Included Bracing Studies (KQ 3)

Study | N | Female | Age (years), Mean (SD) | Premenarchal | Risser Sign | Curve Types | Cobb Angle at Baseline
Coillard 2014^*,102^ Canada Fair RCT | 68 IG: 32 CG: 36 | IG: 85%^†^ CG: 86%^†^ | IG: 12.0 (2) CG: 12.0 (2) | NR | Risser 0–2 IG: 100% CG: 100% | NR | IG: 22° (4.9) CG: 20° (4.1)
Wiemann 2014^103^ USA Fair CCT | 37 IG: 21 CG: 16 | 100% | IG: 12.0 (1.3) CG: 11.9 (1.2) | IG: 100% CG: 100% | Risser 0 IG: 100% CG: 100% | NR | IG: 19° (3.6) CG: 19° (2.6)
BrAIST^*,104, 105^ Weinstein 2013 USA, Canada Good CCT | 242^‡^ IG: 146 CG: 96 | IG: 92% CG: 90% | IG: 12.7 (1.0) CG: 12.7 (1.2) | NR | Risser 0–2 IG: 97% CG: 97% | IG:; - Thoracic: 26%; - Thoracolumbar: 13%; - Lumbar: 3%; - Multiple: 58%; CG:; - Thoracic: 22%; - Thoracolumbar: 14%; - Lumbar: 4%; - Multiple: 60% | IG: 30.5° (5.8) CG: 30.3° (6.5)
SRS Bracing Study^§106, 107^ Nachemson 1995 Sweden, USA, UK, Canada Good Prospective observational | 240 IG: 111 CG: 129 | 100% | Mean: NR Range: 10–15 | IG: 59% CG: 43% | Risser 0–1 IG: 73.9% CG: 54.3% | IG:; - Thoracic: 68%; - Thoracolumbar: 32%; CG:; - Thoracic: 81%; - Thoracolumbar: 19% | IG: 25°–29°: 35.1% 30°–35°: 64.9% CG: 25°–29°: 58.1% 30°–35°: 41.9%
Goldberg 1993^96^ USA, Ireland Fair Retrospective observational | 64 IG: 32 CG: 32 | 100% | IG: 13.1 (0.8) CG: 13.1 (0.8) | IG: 37.5%^**^ CG: 75% | Risser 0 IG: 100% CG: NR^††^ | IG:; - Thoracic: 41%; - Thoracolumbar: 25%; - Lumbar: 19%; - Double: 16%; CG:; - Thoracic: 50%; - Thoracolumbar: 28%; - Lumbar: 16%; - Double: 6% | IG: 22.2° (4.5) CG: 20.6° (5.0)

* Recruitment in Coillard 2014 and BrAIST were terminated early because of evidence of benefit favoring bracing.

† Represents percentage female of those who completed study (n=47).

‡ 47.9% of population from RCT.

§ Study reports severity of major curve at inclusion, not treatment initiation.

** Menarchal status NR for 28.1% of IG subjects.

†† Selected to match Risser stage of intervention group.

Abbreviations: KQ=key question; SD=standard deviation; IG=intervention group; CG=control group; NR=not reported; BrAIST=Bracing in Adolescent Idiopathic Scoliosis Trial; SRS=Scoliosis Research Society.

Average age at enrollment varied from 11.9 to 13.1 years in the four studies that reported this;^96, 102-105, 108^ the fifth study reported that participants were between ages 10 and 15 years.^106, 107^ Three studies included female participants only,^96, 103, 106, 107^ and more than 90 percent of participants in another study^104, 105^ were female as well. The remaining study^102^ reported that about 85 percent of those who completed the study were female. Race was reported in one included study;^104, 105^ in that trial, 78 percent of subjects were white, 9 percent were black, and 13 percent were another race or unknown. Three studies^102-105^ specified that enrollment was limited to persons who had not previously received treatment for scoliosis; the other two studies did not comment on any previous treatment.

All studies included adolescents with different types of scoliotic curves. One study included only subjects with single major curves;^106, 107^ two studies included subjects with both single major and double major curves;^96, 104, 105^ and two studies provided no information on curve type.^102, 103^ Of the 546 adolescents for which such data are available, 397 (73%) had a single major curve, with nearly all of these (377) being single thoracic or thoracolumbar major curves.

All studies provided data on the major curve. Four studies reported the severity of curve at treatment initiation;^102-107^ one reported severity of curve at diagnosis.^96^ Average curve severity varied from near 20°^96, 102, 103^ to close to 30°.^104-107^

Overall, 85 percent of adolescents (554/649) in the five included studies were skeletally immature (Risser sign, 0 to 2). History of menarche, another marker of maturity, at the time of enrollment was reported in three studies and ranged from 0 percent (0/37)^103^ to 35 percent (19/55)^96^ to 50 percent (119/240).^106, 107^ In the randomized trial, a Risser sign of 0, 1, or 2 was an inclusion criteria for study entry, but the baseline distribution of the enrolled population was not reported.^102^

Two studies examined the Boston brace (the most commonly used brace in the United States^60^) as the brace of interest,^96, 106, 107^ one study predominately used the Boston brace (68%) along with multiple types of rigid thoracolumbosacral orthoses,^104, 105^ one study used the Charleston bending brace,^103^ and one study used the Spine-Cor brace.^102^ Persons in the intervention group were advised to wear the brace 23 hours per day,^96, 108^ 20 hours per day,^102^ 18 hours per day,^104, 105^ at least 16 hours per day,^106, 107^ or only at nighttime.^103^ Most adolescents were braced until they reached skeletal maturity or until they had curve progression significant enough to warrant surgical intervention.

Three studies reported average duration of bracing treatment, which ranged from around 2 years^102, 104, 105^ to around 3 years.^103^ Three studies ended bracing and assessed outcomes at skeletal maturity,^96, 103, 106, 107^ and another study ended bracing and assessed outcomes at either skeletal maturity or treatment failure (Cobb angle progression to ≥50°).^104, 105^ One study ended bracing at skeletal maturity, and then assessed outcomes at 5 years postrandomization (at which point all patients were at least 2 years postskeletal maturity).^102^

Exercise treatment. Two studies of physiotherapeutic scoliosis-specific exercise met our inclusion criteria; one good-quality RCT^109^ and one fair-quality CCT^110^ (Table 9). Both studies were conducted in Italy, and used control groups whose participants were assigned a general exercise regimen (not designed to treat scoliosis).

Table 9 Study and Population Characteristics: Included Trials of Exercise for Treatment of Scoliosis (KQ 3)

Study | N | Intervention and Control Group Activities | Population Characteristics | Skeletal Maturity at Baseline | Curve Type | Curve at Baseline | Length of Treatment, months Mean (SD) | Data Collection Points | Outcomes Assessed
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: Active self-correction: exercises tailored to type of curve; task oriented exercises; education CG: General balance and walking exercises, spinal mobilization; spinal stretching/strength IG+CG: 60-minute outpatient sessions with physiotherapist once per week; advice to continue exercises 30 minutes twice a week at home | Age, mean (SD) IG: 12.5 (1.1) CG: 12.4 (1.1) Female IG: 70.9% CG: 74.5% Family history of scoliosis IG: 61.8% CG: 65.5% | Risser Sign 0 IG: 45.5% CG: 45.5% Risser Sign 1 IG: 54.5% CG: 54.5% Menarche yes IG: 71.8% CG: 70.7% | Thoracic IG: 14.5% CG: 14.5% Lumbar IG: 23.6% CG: 25.5% Thoracolumbar IG: 38.2% CG: 36.4% S-shaped IG: 23.6% CG: 23.6% | Cobb angle, mean (SD) IG: 19.3 (3.9) CG: 19.2 (2.5) ATR, mean (SD) IG: 7.1 (1.4) CG: 6.9 (1.3) | IG: 42.8 (9.1) CG: 42.4 (7.7) (Treatment until skeletal maturity) | Baseline: Feb 2007–Dec 2008 (recruitment) Post-treatment 12 months after end of treatment | Primary Spinal curve ATR Secondary Pain Function Self-image Mental health
Negrini 2008^110^ Italy Fair CCT | 74 IG: 35 CG: 39 | IG: Active self-correction (SEAS), 1.5-hour tailored sessions every 2 to 3 months evaluated by PT; 40-minute session twice a week, and 5-minute exercise at home CG: Different exercise protocol (PT preference) in group setting 45 to 90 minutes, 2 to 3 times per week, some repeat at home | Age, mean (SD) IG: 12.7 (2.2) CG: 12.1 (2.1) Female IG: 71.4% CG: 69.2% | Risser Sign 0–3 IG: 100% CG: 100% Menarche yes NR | NR | Cobb angle, mean (SD) Total^*^: 15 (6) ATR, mean (SD) Total^*^: 7 (2) | 12 months | Baseline 6 months^†^ 12 months | Primary Cobb angle ATR Secondary Avoidance of bracing

* Not reported by treatment group.

† Only ATR reported at 6 months.

Abbreviations: RCT=randomized, controlled trial; CCT=controlled clinical trial; IG=intervention group; CG=control group; SD=standard deviation; ATR=angle of trunk rotation; SEAS=Scientific Exercises Approach to Scoliosis; PT=physical therapist.

The RCT included 110 adolescents with AIS who were randomized to receive either an active self-correction physical therapy program focused on scoliosis and tailored to each patient's curve, or a general exercise program. Participants received one 60-minute session per week, with instructions for home exercise, from study enrollment to skeletal maturity. Outcomes were assessed at baseline, at the end of treatment, and at 12 months. The primary outcome of the study was spinal curve described with Cobb angle on x-ray. Secondary outcomes were measures of trunk rotation assessed via scoliometer and health-related quality of life outcomes assessed by self-administered paper survey using the SRS-22 Patient Questionnaire, Italian version.

Inclusion criteria included AIS patients with a major curve with a Cobb angle of 10° to 25°, skeletally immature (Risser sign, 0 or 1), and older than age 10 years. Persons with nonidiopathic scoliosis or other serious illness, leg-length discrepancy greater than 1 cm, lower limb deformities, cardiac or respiratory dysfunction, previous spinal surgery, or cognitive impairment were excluded. To recruit the participants, the authors assessed 209 consecutively seen patients of a specialist rehabilitation clinic for eligibility. Of these, 110 were found eligible, 18 refused consent to participate, and 81 were ineligible. Patients were blinded to the study hypothesis but were not blinded to their treatment assignment group. Physical therapists and physiatrists could not be blinded to treatment assignment, but the principal investigator and biostatistician were both blinded.

Analyses were conducted using intention-to-treat methods and included all participants lost to followup at both the end of treatment and at 12-month followup. Complete followup data was available on 90.9 percent of the intervention group (50/55) and 87.3 percent of the control group (48/55). Treatment fidelity was assessed by a physical therapist at each session. Adherence to home advice was assessed by patient diary, but results were not reported. Program completion was 94.5 percent in the intervention group (52/55) and 92.7 percent in the control group (51/55).

The CCT included 74 participants (mean age, 12 years; 70.3% female) who were assigned based on patient preference to either a physiotherapeutic scoliosis-specific exercise regimen (Scientific Exercises Approach to Scoliosis) or to a general exercise program. Intervention group participants received one 90-minute session at the Italian Scientific Spine Institute every 2 to 3 months, which included evaluation by a physiotherapist and instruction in an individually-adapted exercise protocol, plus twice-weekly 40-minute sessions at a rehabilitation facility near their home and instructions to perform one daily exercise at home. Control group participants performed various different exercise protocols at a local facility 2 to 3 times per week. The primary outcome measures included progression of Cobb angle and ATR; authors also reported on the number of participants in each group who required additional treatment with bracing. Outcomes were reported after 12 months of treatment.

Study enrollees included 74 consecutive new AIS patients who fit inclusion criteria seen at a specialty referral center for management of scoliosis. Included participants had AIS without previous treatment and were considered “at risk of bracing,” defined as either proven radiographic progression; Cobb angle greater than 15° or ATR greater than 7° with first signs of puberty, premenarchal status, and Risser sign of 0 or 1; or Cobb angle greater than 20° and Risser sign of 2 or 3. Persons with secondary scoliosis, conditions known to be possible causes of scoliosis, neurological deficits, leg-length discrepancy greater than 10 mm, Risser sign greater than 3, or previous treatment for scoliosis were excluded.

As noted above, participants were assigned to intervention or control groups based on personal preference. Treating physicians and physiotherapists were not blinded to the treatment of each subject but were unaware of the study being performed. Clinical evaluation occurred every 6 months; radiographic measurement was repeated after 12 months of treatment, when the study ended. The overall compliance rate was reported as 95 percent; no statistically significant difference was found between the two groups. Completion rates were 94 percent (33/35) in the intervention group and 92 percent (36/39) in the control group.

##### Study Results: Bracing Studies

Curve progression in adolescence. All three controlled studies^103-107^ and the one RCT^102^ showed evidence supporting the effectiveness of bracing in reducing curve progression. The one included retrospective study did not demonstrate an effect of bracing on curve progression^96^ (Table 10).

Table 10 Bracing Effectiveness Studies: Results of Included Studies (KQ 3)

Study | N | Brace, Duration of Treatment (months) | Study Endpoint | Major Curve at Beginning of Treatment, Mean Cobb Angle (SD) | Major Curve at End of Treatment, Mean Cobb Angle (SD) | Curve Progressed ≤5° During Study Period | Curve Progressed >5° During Study Period | Curve Progressed >10° During Study Period | Curve Progressed to >50°
Coillard 2014^*,102^ Canada Fair RCT | 68 IG: 32 CG: 36 | Spine-Cor Mean 25 (range, 18–36) | 5 years (patients were ≥2 years post stopping treatment) | IG: 22° (4.9) CG: 20° (4.1) | NR | IG: 65.6% CG: 25.0% p=NR | Progressed ≥6° IG: 34.4% CG: 75.0% p=0.0008 | NR | Curve ≥45°^†^ IG: 11.5% CG: 14.3% p=NR
Wiemann 2014^103^ USA Fair CCT | 37 IG: 21 CG: 16 | Charleston bending Mean (SD) IG: 39 (15) CG: 34 (10) | Skeletal maturity | IG: 19° (3.6) CG: 19° (2.6) | NR | Progressed <5° IG: 28.6% CG: 0% p=0.023 | IG: 71.4% CG: 100.0% p=NR | IG: 52.4% CG: 50.0% p=NR | IG: 19.0% CG: 12.5% NS (p=0.472)
BrAIST^*,104, 105^ Weinstein 2013 USA, Canada Good CCT | 242^‡^ IG: 146 CG: 96 | Rigid TLSO (various) Mean IG: 24.2 CG: 21.3 | Skeletal maturity -or- Cobb angle ≥50° | IG: 30.5° (5.8) CG: 30.3° (6.5) | NR | NR | NR | NR | IG: 28% CG: 52% p=NR
SRS Bracing Study^106, 107‡^ Nachemson 1995 Sweden, USA, UK, Canada Good Prospective observational | 240 IG: 111 CG: 129 | Boston^§^ NR | Skeletal maturity | 25°–35° (range) | IG: 26.2 (5.8) CG: 29.8 (6.5) | Progressed ≤6° IG: 64.0% CG: 48.1% p=NR | Progressed ≥6° IG: 36.0%^**^ CG: 51.9%^**^ p=NR | NR | NR
Goldberg 1993^96^ USA, Ireland Fair Retrospective observational | 64 IG: 32 CG: 32 | Boston NR | Skeletal maturity | IG: 22.2° (4.5) CG: 20.6° (5.0) | NR | Progressed ≤5° IG: 81.3% CG: 56.3% Progressed 0° IG: 12.5% CG: 12.5% Progressed <0° IG: 40.6% CG: 25.0% p=NR | NR | IG: 18.8% CG: 28.1% NS (p=NR) | Curve ≥45° IG: 3.1% CG: 6.3% NS (p=NR)

* Recruitment in Coillard 2014 and BrAIST were terminated early because of evidence of benefit favoring bracing.

† Reported only for those who completed study (n=47).

‡ 47.9% of population from RCT.

§ Bracing system also involves a coordinated exercise program.

** Assumes those who were lost to followup (n=23 for intervention group; n=9 for control group) were treatment failures (progressed ≥6°).

Abbreviations: KQ=key question; SD=standard deviation; IG=intervention group; CG=control group; TLSO=thoracolumbosacral orthotic; NR=not reported; BrAIST=Bracing in Adolescent Idiopathic Scoliosis Trial; SRS=Scoliosis Research Society.

All bracing studies reported measures of scoliotic curve progression assessed by x-ray and reported as Cobb angle in degrees, although the specific criteria used to define meaningful progression varied. Measures included either the absolute increase in curvature^96, 102, 103, 106, 107^ or curve progression to a threshold at which bracing treatment was felt to have failed, typically to a Cobb angle of 45° to 50°, when surgery may be considered.^96, 102-105^ Only one study presented dose-response data on the association between daily hours of brace wear and curve progression.^104, 105^ The different endpoints reported provide information on different aspects of treatment effect but preclude pooling of results and direct comparison between studies. In addition, any possible effect associated with different braces, different curves, or different populations cannot adequately be assessed with the data available.

Association between bracing and curve progression of a defined number of degrees. The four studies that evaluated number of degrees of increase in curvature in braced versus observed populations reported mixed results. Three controlled prospective studies^102, 103, 106, 107^ suggested a benefit to bracing in slowing curve progression of 5° or 6°; one prospective study^103^ and one retrospective study^96^ showed limited differences in progression of 10° or more between braced and observed groups.

Three studies that evaluated relatively small amounts of curve progression (5° and 6°) showed significantly less progression in the braced versus control group.^102, 103, 106, 107^ In the randomized trial of SpineCor bracing, progression of 6° or more over the 5-year study period occurred less frequently in the intervention group than in the control group (34.4% vs. 75%; p=0.0008).^102^ In this trial, the control group was halted early (after the recruitment of 68 patients) because of evidence of benefit in the braced group. One study of nighttime only bracing^103^ was performed exclusively in 37 premenarchal girls with a Risser sign of 0 (average age, 12 years); results showed that after about 3 years of treatment, curve progression of 5° or more was less likely in the braced group compared to the control group (15/21 intervention vs. 16/16 control; p=0.023). A study in which 240 subjects ages 10 to 15 years were braced at least 16 hours per day and followed until skeletal maturity for up to 4 years^106, 107^ found that 17 of 111 braced subjects had a curve progression of 6° or more compared with 58 of 129 control subjects (does not include 23/111 braced subjects and 9/129 control subjects who were lost to followup). A worst-case analysis—which assumed the 23 braced subjects who were lost to followup were treatment failures—found that brace treatment was successful at preventing curve progression of 6° or more compared with the control group (p=0.0005).

Conversely, one study of full-time bracing (23 hours per day) did not show a significant difference in curve progression between braced and control subjects. The retrospective study followed 64 girls with a Risser sign of 0 from brace initiation up to the point of weaning to parttime bracing,^96^ and it demonstrated progression of at least 10° in 18.8 percent (6/32) of intervention subjects versus 28.1 percent (9/32) of observed subjects, and a mean change in Cobb angle of 1.6° (standard deviation [SD], 8.2) in intervention subjects compared to 4.9° (SD, 10.2) in control subjects. However, neither of these differences were statistically significant, and it should be noted that this study was not adequately powered to address this question.

Association between bracing and curve progression past a “failure” threshold. Four studies evaluated the progression of curvature past an absolute threshold at which bracing treatment was considered failed.^96, 102-105^ The largest of these demonstrated a significant benefit associated with bracing; the randomized trial suggested lesser progression in the braced group but significance was not reported, and two smaller studies found similar results between braced and control populations.

One international prospective CCT (Bracing in Adolescent Idiopathic Scoliosis Trial [BrAIST]) assessed the effectiveness of bracing 18 hours per day at preventing progression of Cobb angle past 50°.^104, 105^ The study planned to follow participants through skeletal maturity. However, as with the SpineCor bracing trial, the BrAIST study was terminated early by the safety monitoring board due to a marked treatment benefit in favor of bracing. In the full as-treated analysis (which included both randomized and preference cohorts), 28 percent (41/146) of braced subjects had progression of Cobb angle past 50° compared to 52 percent (50/96) of untreated subjects. The odds ratio for the study's definition of a successful outcome (skeletal maturity without progression past 50°) was 1.93 (95% CI, 1.08 to 3.46), adjusted for propensity score quintile and duration of followup. Data from the intention-to-treat analysis (RCT cohort) likewise showed a statistically significant effect of bracing, with progression past 50° in 25 percent of braced subjects and 58 percent of untreated subjects (the odds ratio for a successful outcome was 4.11 [95% CI, 1.85 to 9.16], unadjusted). The number needed to treat in order to prevent one case of curve progression past 50° was 3.0 (95% CI, 2.0 to 6.2), and the reduction in relative risk with bracing was 56 percent (95% CI, 26 to 82).

In the randomized trial of SpineCor bracing, more participants progressed to a curve of 45° or more (3/26 in the intervention vs. 3/21 in the control group; significance not reported).^102^ One prospective study of 37 girls with a Risser sign of 0 examined the effect of nighttime only bracing on prevention of progression of Cobb angle past 50°.^103^ Adolescents were followed for about 3 years; during that time, 19 percent (4/21) of braced subjects and 12 percent (2/16) of control subjects had curves that progressed past 50°, which was not statistically significant (p=0.472). A second retrospective study of 64 girls with a Risser sign of 0 examined data on braced subjects from treatment initiation up to the point of weaning to parttime bracing or progression of curve past 45°; control subjects were drawn from a different cohort, and selected for matching age, Cobb angle, maturity, and length of followup.^96, 108^ The study found that 3.1 percent (1/32) of braced subjects and 6.3 percent (2/32) of control subjects had progression of Cobb angle to 45° or more (reported as not significant; no p-value provided).

Association between daily hours of brace wear and curve progression past a defined number of degrees. The single included study that assessed the association between daily hours of brace wear and degree of increase of curvature^104, 105^ demonstrated a benefit associated with increased hours of brace wear. This study (BrAIST, discussed previously in this section) included 116 subjects for whom data on daily duration of brace use was available. Results demonstrated a significant inverse correlation between quartile of daily duration of brace wear (measured by heat sensors) and the likelihood of progression of curve to 50° or more. Average brace wear of 0 to 6 hours per day was associated with a 59 percent likelihood of progression to 50° or more, while brace wear of 12.9 or more hours per day was associated with a 7 to 10 percent likelihood of progression to 50° or more (p<0.001).

Curve progression in adulthood. Cobb angle in adulthood was assessed in one included study, which suggested little progression in adulthood in either treated or observed persons with curves of moderate magnitude. Of the original 106 girls who had been enrolled at two of the centers in the SRS bracing cohort, 77 were re-evaluated an average of 16 years after skeletal maturity (average age, 32 years).^111, 112^ Average Cobb angles at maturity in this cohort were similar in both observed and braced groups (30.6° in observed participants vs. 27.7° in braced participants; p=0.067). Between skeletal maturity and adult followup, average Cobb angle had increased by an average of 4.4° (SD, 4.1) in observed patients and by an average of 6.4° (SD, 5.8) in braced patients. Only 7.5 percent (3/40) of observed participants and 5.4 percent (2/37) of braced participants had progression of the curve past 45° at the time of followup (p>0.99).

Other health outcomes. One included study of bracing effectiveness collected data on quality of life and back pain.^104, 105^ Quality of life data were collected using the Pediatric Quality of Life Inventory (PedsQL). Data on specific questions were not provided; however, the authors stated that average PedsQL scores did not differ between intervention and control groups at baseline (braced subjects, 83.8 vs. observed subjects, 83.3; p=0.80) or at the final followup assessment (braced subjects, 82.0 vs. observed subjects, 81.9; p=0.97). There also was no significant difference in reported back pain between intervention and control groups at baseline (p=0.32) or at final followup (p=0.29) (Table 11 and Appendix D).

Table 11 Bracing Effectiveness Studies: Other Outcomes (KQ 3)

Study | N | Quality of Life Assessment^‡^ | Mean Score at Baseline (SD)^**^ | Mean Score at Final Followup (SD)^**^ | Back Pain Assessment | Back Pain Prevalence at Baseline^**^ | Back Pain Prevalence At Final Followup^**^ | Back Pain Reported During Study
BrAIST^*,104, 105^ Weinstein 2013 USA, Canada Good CCT | 242^†^ IG: 146 CG: 96 | Pediatric Quality of Life Inventory^§^ | IG: 83.8 (14.1) CG: 83.3 (13.3) p=0.80 | IG: 82.0 (17.0) CG: 81.9 (14.1) p=0.97 | Self-report at 6 month intervals during study visit | IG: 38% CG: 32% p=0.32 | IG: NR CG: NR p=0.29 | Total reports^††^ IG: 33 CG: 30 Reports related to bracing or scoliosis^‡‡^ IG: 32 CG: 22

Note: No other bracing effectiveness study reported quality of life measures. No significant differences between groups.

* Recruitment in BrAIST was terminated early because of evidence of benefit favoring bracing.

† 47.9% of population from RCT.

‡ Child Health Questionnaire, Self-Image Questionnaire for young adults, and Spinal Appearance Questionnaire were also administered; however, results were not reported.

§ Scores range from 0 to 100; higher scores indicate higher quality of life.

** All results are from as-treated analysis; authors report that results of intention-to-treat analysis were also not significant.

†† Back pain events were all considered “not serious”; number of events are reported, not number of participants.

‡‡ Events were considered related based on the judgement of the investigator.

Abbreviations: KQ=key question; SD=standard deviation; BrAIST=Bracing in Adolescent Idiopathic Scoliosis Trial; IG=intervention group; CG=control group; NR=not reported.

##### Study Results: Exercise Treatment

Curve progression. Both included studies reported outcomes that favored the active self-correction intervention group at statistically significant levels.

In the RCT,^109^ the intervention group experienced a mean improvement in Cobb angle of 4.9° at 12-month followup compared to the control group's increase of 2.8° (p<0.001). Similar trends were seen in ATR measured on scoliometer, with a mean improvement of 3.7° in the intervention group compared with a 0.4° improvement in the control group (p<0.001) (Table 12). The control group had a higher rate of progressing 5° or more at the end of treatment (8% vs. 0%; no test of significance reported). Conversely, the intervention group saw a higher rate of improvement of 5° or less at the end of treatment (62% vs. 0%; no test of significance reported) (Table 13).

Table 12 Results of Trials of Active Self-Correction vs Generic Exercise for Treatment of Scoliosis (KQ 3)

Study | N | Age, Mean (SD) | Length of Treatment in Months, Mean (SD) | Outcome | Baseline, Mean (SD) | End of Treatment, Mean (SD) | 12 Month Followup, Mean (SD) | Change From Baseline to 12-Month Followup, Mean (SE)^*^ | P-Value (Group Effect)
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: 12.5 (1.1) CG: 12.4 (1.1) | IG: 42.8 (9.1) CG: 42.4 (7.7) | Cobb angle | IG: 19.3 (3.9) CG: 19.2 (2.5) | IG: 14.0 (2.4) CG: 20.9 (2.2) | IG: 14.3 (2.3) CG: 22.0 (1.6) | IG: -4.9 (0.4) CG: 2.8 (0.4) | <0.001
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: 12.5 (1.1) CG: 12.4 (1.1) | IG: 42.8 (9.1) CG: 42.4 (7.7) | ATR | IG: 7.1 (1.4) CG: 6.9 (1.3) | IG: 3.6 (1.1) CG: 6.6 (1.2) | IG: 3.3 (1.1) CG: 6.5 (1.1) | IG: -3.7 (0.2) CG: -0.4 (0.1) | <0.001
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: 12.5 (1.1) CG: 12.4 (1.1) | IG: 42.8 (9.1) CG: 42.4 (7.7) | Function^†^ | IG: 3.8 (0.5) CG: 3.9 (0.5) | IG: 4.7 (0.2) CG: 4.0 (0.4) | IG: 4.8 (0.2) CG: 3.9 (0.4) | IG: 1.0 (0.07) CG: 0.01 (0.04) | <0.001
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: 12.5 (1.1) CG: 12.4 (1.1) | IG: 42.8 (9.1) CG: 42.4 (7.7) | Pain^†^ | IG: 3.8 (0.4) CG: 3.9 (0.5) | IG: 4.6 (0.3) CG: 4.3 (0.3) | IG: 4.7 (0.2) CG: 4.2 (0.4) | IG: 0.89 (0.06) CG: 0.33 (0.06) | <0.001
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: 12.5 (1.1) CG: 12.4 (1.1) | IG: 42.8 (9.1) CG: 42.4 (7.7) | Self- image^†^ | IG: 3.6 (0.6) CG: 3.4 (0.6) | IG: 4.4 (0.3) CG: 3.7 (0.5) | IG: 4.6 (0.3) CG: 3.6 (0.4) | IG: 1.0 (0.08) CG: 0.21 (0.04) | <0.001
Monticone 2014^109^ Italy Good RCT | 110 IG: 55 CG: 55 | IG: 12.5 (1.1) CG: 12.4 (1.1) | IG: 42.8 (9.1) CG: 42.4 (7.7) | Mental health^†^ | IG: 3.8 (0.6) CG: 3.9 (0.6) | IG: 4.5 (0.3) CG: 3.9 (0.5) | IG: 4.7 (0.2) CG: 3.8 (0.4) | IG: 0.95 (0.08) CG: -0.01 (0.04) | <0.001
Negrini 2008^110^ Italy Fair CCT | 74 IG: 35 CG: 39 | IG: 12.7 (2.2) CG: 12.1 (2.1) | 12 | Change in Cobb angle of max curve | NR | IG: -0.33 CG: +1.12 | NA | NA | NR, NS
Negrini 2008^110^ Italy Fair CCT | 74 IG: 35 CG: 39 | IG: 12.7 (2.2) CG: 12.1 (2.1) | 12 | Change of Cobb angle of all curves | NR | IG: -0.67 CG: +1.38 | NA | NA | p<0.05
Negrini 2008^110^ Italy Fair CCT | 74 IG: 35 CG: 39 | IG: 12.7 (2.2) CG: 12.1 (2.1) | 12 | Change in ATR of max curve | NR | IG: -0.33 CG: +0.15 | NA | NA | NR, NS
Negrini 2008^110^ Italy Fair CCT | 74 IG: 35 CG: 39 | IG: 12.7 (2.2) CG: 12.1 (2.1) | 12 | Change in ATR of all curves | NR | IG: +0.12 CG: +0.52 | NA | NA | NR, NS

* For SRS-22 domains, minimal clinically important differences reported for populations with adult spinal deformity and AIS were 0.4 to 0.6 (function); 0.6 to 0.8 (pain); 0.5 to 0.8 (self-image); and 0.4 (mental health).^147, 148^

† SRS-22 (Italian): scores range from 1 (worst) to 5 (best).

Abbreviations: KQ=key question; RCT=randomized, controlled trial; CCT=controlled clinical trial; IG=intervention group; CG=control group; SD=standard deviation; SE=standard error; ATR=angle of trunk rotation; NR=not reported; NS=not significant.

Table 13 Results of Trials of Exercise for Treatment of Scoliosis: Progression of 5° at End of Treatment (KQ 3)

Study | N | End of Treatment N (%)
Study | N | Progressing (Cobb Angle Change ≥5°) | Stable (Cobb Angle Change of -5° to 5°) | Improved (Cobb Angle Change ≤-5°)
Monticone 2014^109^ Italy Good RCT | Total (n=103) IG: 52; CG: 51 | IG: 0 (0%)^*^ CG: 4 (8%)^*^ | IG: 20 (38%) CG: 47 (92%) | IG: 32 (62%)^*^ CG: 0 (0%)^*^
Monticone 2014^109^ Italy Good RCT | | Progressing (Cobb Angle Change >3°) | Stable (Cobb Angle Change of -3° to 3°) | Improved (Cobb Angle Change <-3°)
Monticone 2014^109^ Italy Good RCT | Age <13 years at admission (n=63) | IG: 3 (9.7%) CG: 10 (31.2%) | IG: 6 (19.3%) CG: 19 (59.4%) | IG: 22 (71.0%) CG: 3 (9.4%)
Monticone 2014^109^ Italy Good RCT | Age ≥13 years at admission (n=40) | IG: 1 (4.8%) CG: 10 (52.6%) | IG: 6 (28.5%) CG: 9 (47.4%) | IG: 14 (66.7%) CG: 0 (0%)
Monticone 2014^109^ Italy Good RCT | | Worsened | Stable | Improved (Cobb Angle Decreased)
Negrini 2008^110^ Italy Fair CCT | 74 IG: 35 CG: 39 | Cobb angle: IG: 11.8% CG: 13.9% ATR: IG: 15.1% CG: 27.8% | Cobb angle: IG: 64.7% CG: 75.0% ATR: IG: 75.8% CG: 69.4% | Cobb angle: IG: 23.5% CG: 11.1% ATR: IG: 9.1% CG: 2.8%

* Data comes from Monticone 2014 response to letter to editor.^149^

Abbreviations: KQ=key question; RCT=randomized, controlled trial; CCT=controlled clinical trial; IG=intervention group; CG=control group; SD=standard deviation; ATR=angle of trunk rotation; NR=not reported.

In the CCT,^110^ the average magnitude of all curves (reported as Cobb angle) for each person decreased by 0.67° at 12-month followup in the intervention group and increased by 1.38° in the control group (p<0.05) (Table 12). Changes in ATR and in the magnitude of the major curve alone were also reported; results showed a similar pattern but were not statistically significant.

Quality of life. Quality of life outcomes reported in the RCT were measured with the SRS-22 Italian version. All measures suggested generally stable to slightly improving self-reported measures of pain, function, self-image, and mental health in the control group compared to steadily improving assessment of each of these in the intervention group. All trends were statistically significant between groups (Table 12).

#### Limitations

For studies of brace treatment, heterogeneity in the type of braces and outcome measures used—especially of curve progression reported—limits our ability to make direct comparisons across studies and to accurately assess the magnitude of treatment effect. Only one study reported long-term followup data that described a limited subset of the study population. Information on quality of life and other health outcomes was also available in only one bracing study. As noted above, two included trials were terminated early because of evidence of benefit favoring bracing.

The evidence base for the other two categories of treatment for AIS (exercise and surgery) is hampered by a lack of evidence pertinent to a screening-relevant population (i.e., curves of <50° at diagnosis). Only two studies of exercise treatment met our inclusion criteria. A large body of literature on surgical treatment of AIS exists, but studies that include any comparison group are sparse. We found none that include a comparison group of nonsurgically treated participants, not surprising given that surgery is generally reserved for more severe curves. However, we found no data on surgical outcomes in children with screen-detected AIS, and no data on the course of progression or treatments used presurgery.

### KQ 4 What Is the Association Between Severity of Spinal Curvature in Adolescence and Health Outcomes in Adulthood?

#### Summary of Results

Two fair-quality studies (five articles) of 339 persons with AIS followed up in adulthood met our inclusion criteria. Both included studies were retrospective observational long-term followup analyses of persons with AIS diagnosed during adolescence. One study^111, 112^ evaluated a cohort of 77 adults who were either braced or observed during adolescence as part of a bracing study; the other^113-115^ included various subsets of a cohort of 283 persons with AIS who had been consecutively referred to a regional center for bracing or surgical treatment during adolescence, 262 of whom were assessed in adulthood. Followup occurred at least 11 years after skeletal maturity in the smaller cohort, and at least 20 years posttreatment in the larger cohort.

No included studies reported health outcomes data stratified by degree of curvature at skeletal maturity, and therefore no included studies directly address this question as worded. The included studies provide insight into adult health outcomes stratified by treatment regimen during adolescence. Both general and scoliosis-specific quality of life measures (36-Item Short-Form Survey [SF-36] and SRS-22) were similar between observed and braced participants at adult followup in one study.^111, 112^ Oswestry Disability Index scores, general well-being, self-esteem, social activity, pulmonary outcomes, and childbearing and pregnancy outcomes were similar in adulthood in those braced or surgically treated in adolescence.^113-115^

Braced participants rated their body appearance as more distorted than did untreated participants.^112^ Braced participants also recalled experiencing a negative effect on their life during the treatment period compared to those treated surgically.^113^

#### Detailed Results

##### Description of Included Studies

Treatment in adolescence. Both included studies were conducted in Sweden. One study comprised 100 adults with AIS who originally had participated in the SRS bracing cohort^106^ as adolescents, and had been enrolled at one of the two Swedish centers in the study; 77 of these participants enrolled in the followup study.^111, 112^ The other cohort consisted of 283 adults with AIS (referred to here as the “Göteborg cohort”) who as adolescents had been consecutively referred to Sahlgrenska University Hospital in Göteborg, Sweden, for bracing or surgical treatment between 1968 and 1977.^113-115^ The largest followup study on this cohort enrolled 262 participants.^113^

The average age of participants in the SRS bracing cohort was 32 years at the time of followup, and all were evaluated between 11 and 18 years after skeletal maturity (mean, 16 years).^111, 112^ Participants in the Göteborg cohort were an average age of 39 years at followup and were at least 20 years posttreatment (average, 22–23 years) (Table 14).^113-115^ The SRS bracing cohort consisted of females only, and more than 90 percent of the Göteborg cohort were female. No other demographic data were reported (Table 15).

Table 14 Characteristics of Studies on Health Outcomes in Adulthood (KQ 4)

Study | N | Study Design | Country, Setting, Years of Treatment and Followup | Mean Age at Start of Treatment, years | Mean Age at Followup, years | Lost to Followup From Adolescence | Mean Length of Followup After Skeletal Maturity, years | Adult Outcomes
Danielsson 2010,^111^ 2012^112^ SRS bracing cohort Fair Sweden | n=77 OBS: 40 BT: 37 | Observational Long-term followup of AIS cohort treated in adolescence | Sweden 2 medical centers Treatment: 1985–1989 Followup: ≥11 years postmaturity | OBS: 14.0 (SD, 0.9) BT: 13.4 (SD, 1.2) p=0.0077 | OBS: 32.2 (SD, 1.2) BT: 32.4 (SD, 1.8) p=0.54 | n=100 assessed in adolescence; 77% assessed in adulthood | OBS: 16.0 (SD, 1.2); range, 13.3–18.4 BT: 16.0 (SD, 1.6); range, 11.4–18.6 (p=0.91) | SRS-22 SF-36 Spinal Appearance Questionnaire
Danielsson 2001a,^113^ 2001b^114^ Pehrsson 2001^115^ Göteborg cohort Fair Sweden | n=262 ST: 146 BT: 116 | Observational Long-term followup of AIS cohort treated in adolescence | Sweden University Hospital Treatment: 1968–1977 Followup: ≥20 years posttreatment | BT: 14.4 (SD, 1.4) ST: 15.0 (SD, 1.8) p=0.012 | BT: 39.3 (SD, 2.2) ST: 39.7 (SD, 2.5) p=0.31 | n=283 assessed in adolescence; 93% assessed in adulthood | BT: 22.3 (SD, 1.9); range, 19.4–28.3 ST: 23.3 (SD, 1.6); range, 20.3–26.6 p=0.0001 | SF-36 PGWB ODI Childbearing and pregnancy outcomes (n=247) Pulmonary outcomes (n=251)

Abbreviations: KQ=key question; AIS=adolescent idiopathic scoliosis; SD=standard deviation; SRS=Scoliosis Research Society; OBS=observation group; BT=brace-treated group; ST=surgically treated group; SRS-22=Scoliosis Research Society 22-item questionnaire; SF-36=36-Item Short-Form Survey; PGWB=Psychological General Well-Being Index; ODI=Oswestry Disability Index.

Table 15 Population Characteristics of Studies on Health Outcomes in Adulthood (KQ 4)

Study | N | % Female | AIS Treatment Received in Adolescence | Mean Cobb Angle at Inclusion (Pretreatment) | Mean Cobb Angle at Skeletal Maturity/End of Treatment | Mean Cobb Angle at Followup (In Adulthood)
Danielsson 2010,^111^ 2012^112^ SRS bracing cohort Fair Sweden | n=77 OBS: 40 BT: 37 | OBS: 100% BT: 100% | OBS: Observation only BT: Boston brace (22–24 hours/day until skeletal maturity)^*^ | OBS: 29.2 (SD, 3.0); range, 23–35 BT: 30.5 (SD, 3.2); range, 25–38 p=0.11 | OBS: 30.6 (SD, 4.9); range, 21–42 BT: 27.7 (SD, 6.8); range, 14–42 p=0.067 | OBS: 35.0 (SD, 6.5); range, 21–48 BT: 34.1 (SD, 7.7); range, 19–48 p=0.75
Danielsson 2001a,^113^ 2001b^114^ Pehrsson 2001^115^ Göteborg cohort Fair Sweden | n=262 ST: 146 BT: 116 | BT: 95.7% ST: 93.1% | BT^†^: Boston or Milwaukee brace 22–24 hours/day until skeletal maturity ST^‡^: Surgical treatment with Harrington distraction and fusion, followed by bracing for 6–12 months | ST: 61.8 (SD, 13.2); range, 38–122 BT: 33.2 (SD, 9.6); range, 12–60 p=0.0001 | ST: 33.1 (SD, 9.4); range, 12–65 BT: 29.7 (SD, 11.2); range, 0–58 p<0.05^§^ | ST: 36.5 (SD, 9.7); range, 14–66 BT: 37.6 (SD, 14.7); range, 5–71 p=0.48

* 26 participants braced at time of enrollment, 11 braced after progression >6° with significant growth remaining.

† Participants with curves 24°–50° (thoracic, thoracolumbar or double primary curves) or <60° (lumbar curves).

‡ Participants with curves >50° (thoracic, thoracolumbar or double primary curves) or >60° (lumbar curves).

§ Reported in Danielsson 2001 article^38^ with n=248 (ST=139; BT=109).

Abbreviations: KQ=key question; AIS=adolescent idiopathic scoliosis; SD=standard deviation; OBS=observation group; BT=brace-treated group; ST=surgically treated group; SRS=Scoliosis Research Society.

Degree of curvature at diagnosis and at skeletal maturity was similar in the braced and observation groups in the SRS followup study. Mean Cobb angle of the largest curve was similar in the two groups at baseline (30.5° in the braced group vs. 29.2° in the observation group) and at skeletal maturity (27.7° and 30.6°, respectively).^111, 112^ Consistent with treatment recommendations for bracing and surgery, Cobb angle at diagnosis differed between braced and surgical groups in the Göteborg cohort (33.2° in the braced group vs. 61.8° in the surgery group) but was similar at the end of treatment (29.7° in the braced group vs. 33.1° in the surgery group; p<0.05)^38, 113^ (Table 15). Type of curve at diagnosis was reported in one study; in the Göteborg cohort, 60 percent of braced participants and 76 percent of surgically treated participants had single thoracic or thoracolumbar curves.^112^

Twenty-six adolescents in the SRS bracing cohort were treated with a Boston brace for 22 to 24 hours daily until skeletal maturity; none of these had curve progression that required surgical treatment in adolescence. Sixty-five adolescents in the observed cohort were untreated unless their major curve increased by 6° or more before skeletal maturity; these participants were braced if the curve reached 30° to 40° (13 participants, 11 of whom enrolled in the followup study) or treated surgically if the Cobb angle reached greater than 40° (6 participants, none of whom enrolled in the followup study).^111, 112^ All participants in the Göteborg cohort received either brace treatment for curves of 24° to 50° until skeletal maturity. Curves greater than 50° (and lumbar curves >60°) were treated surgically with Harrington distraction and fusion, followed by postoperative bracing for 6 to 12 months.^113^

Followup in adulthood. Long-term followup of 77 of the original 100 who had participated in the SRS bracing cohort was performed an average of 16 years after skeletal maturity, when participants were an average age of 32 years.^111, 112^ Between skeletal maturity and adult followup, Cobb angles had increased by an average of 4.4° (SD, 4.1) in observed patients and by an average of 6.4° (SD, 5.8) in braced patients. Quality of life assessments were also conducted using the SRS-22, SF-36, and Spinal Appearance Questionnaire (SAQ).

In the Göteborg cohort, adult outcomes were assessed in 262 of the 283 original study cohort at an average of 22 to 23 years after completion of treatment, when participants were an average age of 39 years.^113-115^ Average Cobb angle at adult followup was 37.6° (SD, 14.7) for braced participants and 36.5° (SD, 9.7) for surgically-treated participants (this study did not meet inclusion criteria for KQ 3). Quality of life assessments were done at adult followup using SF-36, the Oswestry Disability Index, and the Psychological General Well-Being (PGWB) Index.

Pulmonary function was assessed in 251 participants from the Göteborg cohort.^115^ Total lung capacity, forced expiratory volume in the first second (FEV1), and vital capacity (VC) were measured in the 141 surgically treated and 110 brace-treated participants before the beginning of treatment, 1.4 years after surgery (for the subset of surgically-treated participants), and at followup.^115^ In addition, pregnancy outcomes were assessed by self-report in 247 participants from the Göteborg cohort.^114^

##### Study Results: Quality of Life Outcomes

No data were provided in either included study on the association between curve at skeletal maturity and adult quality of life outcomes. However, both included studies presented adult outcomes based on treatment received in adolescence. The SRS-22, SF-36, and Oswestry Disability Index are all widely validated measures used in research; several other measures are also reported.

SRS-22. The SRS-22 is a scoliosis-specific measure of quality of life and function for scoliosis patients; it contains 22 items that are categorized into pain, self-image, function, and mental health domains, scored from 1 (worst) to 5 (best); a total score is also calculated with or without satisfaction with management.^116^ One study measured SRS-22 in adulthood^111^ but did not provide measures of association with curvature at skeletal maturity. Adult scores on all SRS-22 domains were similar and not statistically significant between those braced and observed in adolescence (Table 16).

Table 16 SRS-22 Scores^*^ in Adulthood (KQ 4)

Study | N | Mean Cobb Angle at Skeletal Maturity/End of Treatment | Function | Pain | Self-Image/Appearance | Mental Health | Total Score^†^
Danielsson 2010,^111^ 2012^112^ SRS bracing cohort Fair Sweden | n=77 OBS: 40 BT: 37 | OBS: 30.6 (SD, 4.9); range, 21–42 BT: 27.7 (SD, 6.8); range, 14–42 p=0.067 | OBS: 4.5 (SD, 0.5); range, 2.8–5.0 BT: 4.5 (SD, 0.5); range, 3.0–5.0 p=0.60 | OBS: 4.3 (SD, 0.7); range, 1.4–5.0 BT: 4.4 (SD, 0.6); range, 3.2–5.0 p=0.94 | OBS: 3.9 (SD, 0.8); range, 1.2–5.0 BT: 3.9 (SD, 0.7); range, 2.4–5.0 p=0.98 | OBS: 4.1 (SD, 0.7); range, 2.0–5.0 BT: 4.1 (SD, 0.7); range, 2.6–5.0 p=0.93 | OBS: 4.2 (SD, 0.5); range, 2.7–5.0 BT: 4.2 (SD, 0.4); range, 3.0–5.0 p=0.74

* Possible scores: 1 (worst) to 5 (best).

† Total score excluding “satisfaction with management.”

Abbreviations: KQ=key question; SRS=Scoliosis Research Society; SD=standard deviation; OBS=observation group; BT=brace-treated group; SRS-22=Scoliosis Research Society 22-item questionnaire.

SF-36. The SF-36 is a global, not disease-specific, measure of health-related quality of life. It contains 36 items that are scored into eight domains of physical or mental health, scored from 0 (worst) to 100 (best), calibrated to a population norm of 50.^117^ SF-36 questionnaire results were reported in both cohorts; both studies found no statistically significant differences between groups (braced vs. observed or braced vs. surgically treated) on any domains (Table 17).^111, 113^

Table 17 SF-36 Scores^*^ in Adulthood (KQ 4)

Study | N | Physical Functioning, Mean (95% CI) | Role Physical, Mean (95% CI) | Bodily Pain, Mean (95% CI) | General Health, Mean (95% CI) | Vitality, Mean (95% CI) | Social Functioning, Mean (95% CI) | Role Emotional, Mean (95% CI) | Mental Health, Mean (95% CI)
Danielsson 2010,^111^ 2012^112^ SRS bracing cohort Fair Sweden | n=77 OBS: 40 BT: 37 | OBS: 94.5 (91.9–97.1) BT: 94.9 (92.1–97.1) p=0.80 | OBS: 93.1 (87.3–98.9) BT: 91.9 (84.8–97.7) p=0.94 | OBS: 75.0 (67.4–82.5) BT: 68.1 (60.2–74.5) p=0.19 | OBS: 83.7 (74.6–88.2) BT: 79.8 (75.1–83.6) p=0.15 | OBS: 69.9 (63.3–76.1) BT: 68.2 (61.6–73.7) p=0.78 | OBS: 91.9 (86.7–97.0) BT: 89.5 (83.3–94.6) p=0.34 | OBS: 90.0 (82.5–97.5) BT: 86.5 (76.5–94.6) p=0.79 | OBS: 83.5 (78.9–88.1) BT: 81.3 (76.2–85.4) p=0.51
Danielsson 2001a^113^ Göteborg cohort Fair Sweden | n=262 ST: 146 BT: 116 | ST: 85.8 (83.1–88.5) BT: 88.2 (85.5–90.9) p=0.22 | ST: 86.8 (81.9–91.7) BT: 82.8 (76.7–88.9) p=NR | ST: 70.8 (66.5–75.1) BT: 71.5 (66.6–76.4) p=0.73 | ST: 75.1 (71.8–78.4) BT: 77.6 (74.3–80.9) p=0.49 | ST: 68.4 (65.1–71.7) BT: 63.1 (59.2–67.0) p=NR | ST: 90.7 (87.8–93.6) BT: 90.0 (86.7–93.3) p=NR | ST: 88.1 (83.6–92.6) BT: 89.1 (84.6–94.4) p=NR | ST: 81.0 (78.5–83.5) BT: 80.8 (77.7–83.9) p=NR

* Possible scores 0 (worst) to 100 (best), scaled to population norm=50.

Abbreviations: KQ=key question; SRS=Scoliosis Research Society; OBS=observation group; CI=confidence interval; BT=brace-treated group; ST=surgically treated group; SF-36=36-Item Short-Form Survey; NR=not reported.

In the Göteborg cohort followup, the authors report no correlation between curve size after treatment and scores on the physical functioning, general health, and mental health subscales of the SF-36, but numeric data were not provided.^113^ There also was no difference between participants with curves of greater than 50° at followup and those with curves of less than 50° on the physical functioning, general health, and mental health subscales, or between brace-treated participants whose major curve had increased by greater than 20° or less than 20° since the end of treatment. ATR at followup was also found not to be correlated with the Mental Component Summary or Physical Component Summary scores on the SF-36.

Oswestry Disability Index and back pain. The Göteborg cohort study assessed the Oswestry Disability Index and sick leave due to back pain.^113^ There was no significant difference between brace-treated and surgically-treated participants on either measure (Table 18).

Table 18 Oswestry Disability Index Scores in Adulthood (KQ 4)

Study | N | Mean Cobb Angle at End of Treatment | Mean ODI Score^*^ | Sick Leave Ever Due to Back Problems, n (%)
Danielsson 2001a^113^ Göteborg cohort Fair Sweden | n=262 ST: 146 BT: 116 | ST: 33.1 (SD, 9.4); range, 12–65 BT: 29.7 (SD, 11.2); range, 0–58 p<0.05^†^ | ST: 8.3 (SD, 10), range, 0–50 BT: 7.6 (SD, 9.0), range, 0–36 p=0.49 | ST: 63 (43.2%) BT: 44 (37.9%) p=0.45

* Possible scores 0 (best) to 100 (worst)

† Reported in Danielsson 2001 article^38^ with n=248 (ST=139; BT=109).

Abbreviations: KQ=key question; ODI=Oswestry Disability Index; SD=standard deviation; BT=brace-treated group; ST=surgically treated group.

Other quality of life assessments. The SAQ was assessed in the SRS bracing cohort.^112^ The SAQ consists of a set of seven sketches representing visible aspects of spinal deformity, each showing five levels of spinal asymmetry. The patient selects their perception of their own appearance; scores are added and scored from 7 (least distorted appearance) to 35 (most distorted appearance).^118^ Subjectively perceived body asymmetry was correlated with major curve size for braced, observed, and all participants (p=0.0004), though whether the curve was at last followup or during treatment is not described. Participants who had been braced reported a more distorted appearance than those who had not been braced (average SAQ score, 15.0 for braced participants vs. 12.9 for observed participants; p=0.028) (Table 19).

Table 19 SAQ Results (KQ 4)

Study | N | Mean Cobb Angle at Skeletal Maturity/End of Treatment | Mean SAQ^*,†^ Score
Danielsson 2012^112^ SRS bracing cohort Fair Sweden | n=77 OBS: 40 BT: 37 | OBS: 30.6 (SD, 4.9); range, 21–42 BT: 27.7 (SD, 6.8); range, 14–42 p=0.067 | Overall: 13.9 (SD, 4.6); range, 7–29 OBS: 12.9 (SD, 4.4); range, 7–25 BT: 15.0 (SD, 4.6); range, 7–29 p=0.028

Note: no baseline reported for SAQ.

* SAQ measures patient perceptions of spinal deformity and is scored on a scale from 7 (least distorted) to 35 (most distorted).

† SAQ scores were correlated with major curve size for all participants, with Spearman rank correlation r s = 0.40 (p=0.0004).

Abbreviations: KQ=key question; SAQ=Spinal Appearance Questionnaire; SD=standard deviation; OBS=observation group; BT=brace-treated group; SRS=Scoliosis Research Society.

The PGWB Index was assessed in the Göteborg cohort.^113^ No correlation was reported between curve size at the end of treatment and PGWB scores, though numeric data were not provided. There was also no difference in PGWB scores between participants with curves of greater than 50° at the time of followup and those with curves of less than 50°, or between brace-treated participants whose major curve had increased by greater than 20° or less than 20° since the end of treatment. ATR at followup was not correlated with PGWB scores.

A self-esteem and social activity questionnaire was also administered to this group.^113^ Results were not stratified based on ATR at the end of treatment; however, the authors report that there was no correlation between ATR at followup and how participants self-rated their appearance in a bathing suit or whether they had social limitations related to their appearance. The braced and surgically-treated groups in this cohort did differ with regard to the recollection of their experience of the treatment period, with those in the braced group significantly more likely to recall that the treatment had a negative rather than positive effect on their life (p<0.0001) (Table 20).

Table 20 Experience of the Treatment Period (KQ 4)

Study | N | Mean Cobb Angle at Skeletal Maturity | Mean Cobb Angle at Followup | How Did You Experience the Treatment Period?^*^ N (%) | How Did the Treatment Affect You During the Treatment Time?^*^ N (%)
Danielsson 2001^113^ Göteborg cohort Fair Sweden | 262 ST: 146 BT: 116 | ST: 33.1 (SD, 9.4); range, 12–65 BT: 29.7 (SD, 11.2); range, 0–58 p<0.05^†^ | ST: 36.5 (SD, 9.7); range, 14–66 BT: 37.6 (SD, 14.7); range, 5–71 p=0.48 | Major positive; - ST: 37 (25.3%); - BT: 6 (5.1%); Minor positive; - ST: 33 (22.6%); - BT: 8 (15.5%); Not affected; - ST: 18 (12.3%); - BT: 17 (14.6%); Minor negative; - ST: 37 (25.3%); - BT: 43 (37.1%); Major negative; - ST: 21 (14.4%); - BT: 32 (27.6%); p<0.0001 | Very often depressed or sad (p=0.41); - ST: 37 (25.3%); - BT: 35 (30.2%); More noticeable and helped (p=0.0027); - ST: 106 (72.6%); - BT: 63 (54.3%); People were sympathetic (p=0.0007); - ST: 96 (65.7%); - BT: 52 (44.8%); Often teased (p=0.027); - ST: 18 (12.3%); - BT: 5 (4.3%); Intentionally ignored (p=0.99); - ST: 15 (10.3%); - BT: 11 (9.5%); Kept to myself (n=0.64); - ST: 31 (21.2%); - BT: 21 (18.1%); Stopped spare time activities (p=0.60); - ST: 52 (35.6%); - BT: 37 (31.9%); Conflicts at home (p=0.99); - ST: 6 (4.1%); - BT: 5 (4.3%); Treatment ruined my teenage period (p=0.57); - ST: 34 (23.3%); - BT: 31 (26.7%); Treatment did not bother me much (p=0.61); - ST: 53 (36.3%); - BT: 46 (39.6%); Limited contact with opposite sex (p=0.99); - ST: 62 (42.5%); - BT: 50 (43.1%); Treatment made me independent/mature sooner (p=0.80); - ST: 73 (50.0%); - BT: 45 (38.8%)

Note: ST had shorter treatment period (1.4 years) than BT (2.7 years).

* Questions are from a scoliosis treatment-specific questionnaire developed by the authors prior to the development of the Scoliosis Research Society's 22-item questionnaire (SRS-22). Healthy controls did not answer the questionnaire.

† Reported in Danielsson 2001 paper^38^ with N=248 (ST=139; BT=109).

Abbreviations: KQ=key question; SD=standard deviation; ST=surgically treated group; BT=brace-treated group.

##### Study Results: Pulmonary Outcomes

In surgically-treated participants, there was a correlation between curve size and both percentage-predicted VC and FEV1 prior to surgery (p<0.001). However, at followup there was no correlation between curve size after treatment and VC or FEV1 (numeric data not provided)^115^ (Table 21).

Table 21 Pulmonary Outcomes in Adulthood (KQ 4)

Study | N | Mean Cobb Angle at End of Treatment | Smoking Status in Adulthood (From British MRC)^†,‡^ | Lung Function at Mean 25-Year Followup^‡^ | Self-Reported Pulmonary Symptoms (From British MRC),^†,‡^ N (%) | Self-Reported Disease Outcomes^‡,§§^
Danielsson 2001a^113^ Pehrsson 2001^115^ Göteborg cohort Fair Sweden | n=251 ST: 141 BT: 110 | ST: 33.1 (SD, 9.4); range, 12–65 BT: 29.7 (SD, 11.2); range, 0–58 p<0.05^*^ | Never smokers; n (%) ST: NR (55%) BT: NR (56%) Mean (SD) pack-years (current smokers and ex-smokers only) ST: 11.6 (7.3) BT: 8.3 (5.6) | Total lung capacity^§^ ST: 5.0 (SD, 0.9); range, 3.2–9.4 BT: 5.1 (SD, 0.9); range, 3.3–7.4 Vital capacity (VC)^**^ ST: 84 (SD, 13); range, 47–123 BT: 89 (SD, 13); range, 56–127 FEV1^††^ ST: 84 (SD, 14); range, 52–122 BT: 91 (SD, 16); range, 32–135 | Dyspnoea score >3^‡‡^ ST: 3 (% NR) BT: 1 (% NR) Wheezing ST: NR (33%) BT: NR (30%) | Pulmonary disease ST: 8 BT: 6 Coronary heart disease ST: 5 BT: 5 Neoplasms ST: 7 BT: 4

* Reported in Danielsson 2001 paper^38^ with n=248 (ST=139; BT=109).

† Values reported as available (unable to determine whether all participants completed questionnaire).

‡ P-values not reported for differences between ST and BT.

§ Values reported for n=246 (ST=138; BT=108).

** VC % predicted mean values are corrected for age and for loss of height due to scoliosis.

†† FEV1 % predicted mean values corrected for age and for loss of height due to scoliosis.

‡‡ Dyspnoea was graded on a scale of 1 to 5, where 3 = breathlessness when walking with someone else of similar age on level ground.

§§ Values reported for n=262 (ST=146; BT=116). Article^113^ reports that the frequency of pulmonary disease, coronary heart disease, and neoplasms was not significantly different between the patient groups (BT and ST) and the healthy controls.

Abbreviations: KQ=key question; SD=standard deviation; BT=brace-treated group; ST=surgically treated group; NR=not reported; MRC=Medical Research Council; FEV1=forced expiratory volume at one second.

##### Study Results: Childbearing and Pregnancy Outcomes

One study analyzed pregnancy and childbirth outcomes in the 247 females in the Göteborg cohort.^114^ Results were not stratified based on degree of curve at skeletal maturity. There was no significant difference in Cobb angle at completion of treatment between women who had children and those who did not. There were no significant differences between braced or surgically-treated women in marital status, number of children, birth weight, or pregnancy complications (Table 22).

Table 22 Childbearing and Pregnancy Outcomes in Adults With AIS (KQ 4)

Study | N | Mean Cobb Angle at End of Treatment | Mean Number of Children per Person^†^ | Mean Age at First Delivery^†^ | Mean Birth Weight, g^†^ | Pregnancy Complications: First Delivery,^†^ N (%) | Pregnancy Complications: All Births,^†^ N (%)
Danielsson 2001b^114^ Göteborg cohort Fair Sweden | n=247 ST: 136 BT: 111 | ST: 33.1 (SD, 9.4); range, 12–65 BT: 29.7 (SD, 11.2); range, 0–58 p<0.05^*^ | ST: 1.8 (SD, 1.1) BT: 1.9 (SD, 1.1) p=NR | ST: 26.6 BT: 28 p=0.094^†^ | ST: 3,488 (SD, 600); range, 1,470–4,890 BT: 3,573 (SD, 522); range, 1,880–5,120 p=NR | Number of deliveries^‡^; - ST: 111; - BT: 95; Low back pain during pregnancy^‡^; - ST: 39 (35.1%); - BT: 41 (43.1%); Vacuum extraction; - ST: 18 (16.2%); - BT: 8 (8.4%); - p=0.14; Caesarean deliveries^‡^; - ST: 21 (18.9%); - BT: 13 (13.7%) | Number of deliveries^‡^; - ST: 243; - BT: 207; Low back pain during pregnancy^‡^; - ST: 88 (36.2%); - BT: 96 (46.4%); Vacuum extraction^‡^; - ST: 26 (10.7%); - BT: 10 (4.8%); Caesarean deliveries^‡^; - ST: 37 (15.2%); - BT: 25 (12.1%)

* Reported in Danielsson 2001 paper^38^ with n=248 (ST=139; BT=109).

† Values reported for women who had ≥1 children (ST=111; BT=95).

‡ P-values not reported.

Abbreviations: KQ=key question; AIS=adolescent idiopathic scoliosis; SD=standard deviation; BT=brace-treated group; ST=surgically treated group; NR=not reported.

#### Limitations

Only two studies met our criteria, both of fair quality. Most data were presented according to treatment received in adolescence, rather than stratified by curve magnitude at skeletal maturity; therefore, data that directly informs the KQ as worded (“what is the association between severity of spinal curvature in adolescence and health outcomes in adulthood?”) are lacking. Reporting bias may be an issue since multiple measures were assessed in both studies, but this was difficult to assess. One of the included studies has data from several individuals who were treated with methods that have now been superseded (e.g., Harrington rod placement, Milwaukee brace); however, newer treatment methods are thought to have fewer adverse effects, so inclusion of these data may overestimate treatment harms.

### KQ 5 What Are the Harms of Screening for AIS?

No studies on harms of screening met our inclusion criteria. False-positive rates ranged from 0.8 percent for clinic-based FBT with scoliometer and Moiré topography to 21.5 percent for hump assessment alone (reported in KQ 2), though the harms associated with false-positive screening results are unclear. There are potential psychosocial harms associated with a false-positive screening result, and radiation exposure to the chest during childhood is also a potential harm. Several studies have suggested that radiation exposure over the course of management and surveillance for scoliosis is associated with increased cancer risk in adulthood,^119-122^ but the impact of screening-only exposure was not reported in any studies.

### KQ 6 What Are the Harms of Treatment of AIS That Has a Cobb Angle of Less Than 50° at Diagnosis?

#### Summary of Results

Harms of bracing were reported in one good-quality study (two articles; n=242).^104^ These harms were relatively benign and limited to skin problems on the trunk (under the brace) and nonback body pains that were more frequently reported in braced participants than in controls (none of these events were deemed serious). One of the 146 braced participants reported a serious adverse event (anxiety and depression requiring hospitalization).

#### Detailed Results

##### Description of Included Study

The included study is a prospective CCT^104, 105^ of 242 subjects with AIS, 116 of whom were randomly assigned to bracing or observation, and 126 of whom were assigned based on patient preference. In total, 146 subjects were braced and 96 were assigned to the observation group. This study included subjects drawn from populations referred to specialty orthopedic centers at 25 sites in Canada and the United States. Average age of participants was 12.7 years. Ninety-one percent of subjects were female, 78 percent were white, 9 percent were black, and 13 percent were another race or unknown. Enrollment was limited to persons who had not previously received treatment for scoliosis (Table 23).

Table 23 Harms of Bracing: Included Study and Harms Reported (KQ 6)

Study | Study Design | Intervention | Study Population | How Adverse Events Were Assessed | Adverse (Psychological) % (Number of/Total Participants) | Adverse (Physical) % (Number of/Total Participants)
BrAIST Weinstein 2013^104, 105^ USA, Canada Good | Prospective CCT 2007–2013 | IG: Rigid TLSO (18 hours/day) CG: Observation Mean length of treatment/followup (years): IG: 2.0 (NR) CG: 1.8 (NR) | Female % IG: 92% CG: 90% Age, mean IG: 12.7 CG: 12.7 | Adverse events and quality of life scores were monitored at each followup assessment (every 6 months) and reported to the data and safety monitoring board | Anxiety/depression requiring hospitalization: IG: 0.7% (1/146) CG: 0% (0/96) Anxiety, depression: IG: 2.1% (3/146) CG: 1.0% (1/96) | Skin problems on trunk (bruising, laceration, ulcers, pressure sores, rash) IG: 8.2% (12/146) CG: 0% (0/96) Abnormal breast development IG: 0% (0/146) CG: 1.0% (1/96) Body pain (other than back pain)^*^ IG: 8.2% (12/146) CG: 2.1% (2/96) Neurologic symptoms^*^ IG: 4.8% (7/146) CG: 2.1% (2/96) GI and respiratory^*^ IG: 1.4% (2/146) CG: 0% (0/96) Self-reported psychological^*^ IG: 1.4% (2/146) CG: 0% (0/96)

Note: study also included for KQ 3.

* Values and percentages were calculated based on data provided in Appendix of Weinstein 2013.^104^

Abbreviations: KQ=key question; BrAIST=Bracing in Adolescent Idiopathic Scoliosis Trial; CCT=controlled clinical trial; TLSO=thoracolumbosacral orthosis (various types); IG=intervention group; CG=control group; GI=gastrointestinal.

Subjects with different types of scoliotic curves, as well as subjects with both single-major and multiple-major curves, were included in this study. Magnitude of the largest curve at initiation of treatment (reported as Cobb angle) averaged 30.5° (SD, 5.8) in braced subjects. Skeletal maturity of subjects was assessed by Risser sign; 96 percent had a Risser sign of 0 to 2 at enrollment.

This multicenter study allowed participating centers to prescribe “the type of brace used in their normal clinical practice,” but specified that this must be a rigid thoracolumbosacral orthosis; 68 percent of subjects were treated with a Boston brace. Intervention group subjects were braced until skeletal maturity or until Cobb angle of the largest scoliotic curve surpassed 50°. Subjects were observed for an average of 2 years (intervention group) or 1.8 years (control group); the study was stopped early by the data and safety monitoring board due to evidence of significant treatment effect in favor of bracing.

##### Study Results

Adverse events assessed as part of this trial included skin problems on the trunk (e.g., bruising, lacerations, ulcers, pressure sores, rash), abnormal breast development, anxiety, depression, and several other self-reported adverse events which can be broadly categorized as nonback body pain (e.g., leg or neck pain), neurologic symptoms (e.g., headache, numbness/tingling in limbs), and other isolated complaints (e.g., gastrointestinal symptoms, asthma exacerbation). Overall, 39 adverse events that were deemed “related” to the study (based on the judgment of the investigator or research coordinator) were reported in the 146 braced subjects compared to six such events that were reported in the 96 control subjects (Appendix D).

Only one serious adverse event was reported during the study period (hospitalization for anxiety and depression in a braced subject). The most frequently reported nonserious adverse events were those involving the skin under the brace; there were 12 reports of such symptoms in the 146 braced subjects compared to zero reports in the 96 observed subjects. There were 12 reports of various types of body pain (other than back pain) from braced subjects compared to two such reports in observed subjects. There was no significant difference between groups with regard to the frequency of reporting other nonserious adverse events.

#### Limitations

Although the included study was of good quality, the lack of additional studies for comparison precludes our ability to determine the true consistency and magnitude of the findings reported here. Among the four studies excluded based on quality, the most common reasons for a poor quality rating were excessive loss to followup, lack of an untreated control group with AIS, and poor comparability of baseline characteristics of compared groups.