# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence review to update the 2004 recommendation regarding effectiveness of screening for AIS. This review addresses the benefits and harms associated with screening and treatment of screen-detected cases of AIS.

## Analytic Framework and Key Questions

We developed an analytic framework with five Key Questions (KQs) based on the previous review and a scan of the research conducted since the previous review (Figure 1). The analytic framework and KQs are more comprehensive than the previous evidence review, which had two questions designed to identify new evidence about whether 1) screening asymptomatic adolescents leads to improved health outcomes, and 2) the rate at which minor scoliosis progresses to a clinically significant form that causes health problems later in life.^87^

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts the six Key Questions (KQs) described in the Methods section. Specifically, it illustrates the following questions: whether screening for adolescent idiopathic scoliosis (AIS) improves health outcomes and the degree of abnormal spinal curvature in childhood or adulthood (KQ1), the accuracy of screening for AIS (KQ2), whether treatment of AIS that has a Cobb angle of less than 50 degrees at diagnosis improves health outcomes and the degree of spinal curvature in childhood or adulthood (KQ3), the association between severity of spinal curvature in adolescence and health outcomes in adulthood (KQ4), the harms of screening for AIS (KQ5), and the harms of treatment of AIS that has a Cobb angle of less than 50 degrees at diagnosis (KQ6).

### KQs

1. Does screening for AIS improve: a) health outcomes, and b) the degree of abnormal spinal curvature in childhood or adulthood?
2. What is the accuracy of screening for AIS?
3. Does treatment of AIS that has a Cobb angle of less than 50° at diagnosis improve: a) health outcomes, and b) the degree of spinal curvature in childhood or adulthood?
4. What is the association between severity of spinal curvature in adolescence and health outcomes in adulthood?
5. What are the harms of screening for AIS?
6. What are the harms of treatment of AIS that has a Cobb angle of less than 50° at diagnosis?

## Data Sources and Searches

We conducted an initial literature search for existing systematic reviews and guidelines on the topic of idiopathic scoliosis in adolescent and pediatric populations. The search was limited to English-language articles published between 2004 and May 2015. We searched in the Canadian Agency for Drugs and Technologies in Health, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects (Centre for Reviews and Dissemination), DynaMed, First Consult, Health Technology Assessment (Centre for Reviews and Dissemination), National Institute for Health and Clinical Excellence, Ovid MEDLINE, and PubMed (publisher-supplied). These studies helped clarify our KQs.

We worked with a research librarian to develop our search strategy for this evidence review. The search strategy was peer reviewed by a second research librarian. We searched Cochrane Central Register of Controlled Trials, Ovid MEDLINE, ERIC (Eric.ed.gov), PubMed (publisher-supplied), and the Cumulative Index to Nursing and Allied Health Literature. Results of the literature search were imported into EndNote and duplicates were removed. We searched for articles published from January 1966 to October 31, 2015. The search strategies for existing systematic reviews and our comprehensive evidence review are included in Appendix A. We supplemented our database searches by reviewing reference lists from recent and relevant systematic reviews. We also searched ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform for relevant ongoing trials (Appendix B). We updated our search on October 20, 2016.

## Study Selection

Two reviewers independently reviewed 8,230 titles and abstracts using an online platform (Abstrackr^91^) and 1,088 articles (Appendix A Figure 1) against specified inclusion criteria (Appendix A Table 1). We resolved discrepancies through consensus and consultation with a third investigator. We excluded articles that did not meet inclusion criteria or those we rated as poor quality. Appendix C lists all excluded trials.

For screening questions (KQs 1, 2, and 5), the screening population of interest was asymptomatic children ages 10 to 18 years. We included screening studies in primary care–referable settings or school-based screening programs using FBT with or without a scoliometer, as well as surface topography (Moiré). No screening tests were excluded. For KQs 1 through 4, we included randomized trials, controlled trials, and cohort studies; for KQs 5 and 6 (harms) we also included case series and case-control studies. Studies of poor quality, case reports, qualitative studies, and cost-effectiveness studies were excluded. Screening accuracy studies had to include x-ray confirmation; we excluded screening studies in which screening was done by a single person or the screening practitioner was not well described. We excluded studies in which the referral criteria were not quantitatively described (e.g., referral to x-ray “at 5° or higher trunk rotation on scoliometer” would be included, while referral to x-ray based “on any asymmetry in appearance” would be excluded). We also excluded studies in which the flow of participants was incompletely described and studies in which less than 60 percent of those who screened positive received x-ray. For screening effectiveness (KQ 1), we included studies that reported curve severity or any health outcomes, quality of life, pain or functional outcomes, and mortality. For screening accuracy (KQ 2), we defined scoliosis as a Cobb angle of 10° or greater. For harms of screening (KQ 5), we included studies that reported any direct harm of screening procedures persisting 6 months after screening.

For treatment questions (KQs 3 and 6), we included studies of children and adolescents ages 10 to 18 years diagnosed with AIS with a Cobb angle of 10° to 50° at detection. We excluded populations with infantile- or juvenile-onset scoliosis and scoliosis of other known etiology. Since children with a curve greater than 45° to 50° are likely to present clinically and therefore are not likely to be candidates for screening, we required included studies to contain some data on a screening population of children with a curve between 10° and 50°, which we operationalized as curve data reported before the curve has reached 50°. We included studies with a comparison of observation or usual care, and excluded comparative effectiveness studies and studies in which the comparison group was determined post hoc or represented stratified results, such as compliant and noncompliant with brace wear. Studies of surgical and nonsurgical treatments were eligible, but we excluded studies that exclusively evaluated out of date treatments (Harrington rod instrumentation, Milwaukee brace, and electrical surface stimulation) and studies in which treatment was conducted by a single practitioner (e.g., a single surgeon, therapist, or bracer). For treatment effectiveness (KQ 3), we included studies that reported adult health outcomes pertaining to morbidity, quality of life, functional outcomes, or mortality. We included treatment harms (KQ 6) persisting 6 months or more after treatment initiation. We considered pain and functional outcomes as health outcomes for KQ 3 (e.g., quality of life, pain, morbidity).

For the natural history question (KQ 4), we included randomized, controlled trials (RCTs), controlled trials, cohort studies, and large registry-based observational studies of screen-detected children and adolescents ages 10 to 18 years diagnosed with AIS that has a Cobb angle of 10° or greater. We included studies of any treatment type (including Harrington rod or Milwaukee brace). We excluded healthy controls from analysis.

For applicability to U.S. practice, we focused on studies conducted in countries deemed “very high” development according to the United Nations' Human Development Index.^88^ We only included studies published in English. We excluded studies rated as poor quality, case reports, cross-sectional studies, and cost-effectiveness studies.

## Quality Assessment and Data Abstraction

At least two reviewers critically appraised all articles that met the inclusion criteria based on the USPSTF's design-specific quality criteria (Appendix A Table 2).^89^ We supplemented these criteria with the Newcastle Ottawa scales for cohort and case-control studies.^90^ We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria. A fair-quality study did not meet, or it was unclear if it met, at least one criterion but had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. The most common fatal flaws for screening studies included unclear referral criteria for the screening examination or unclear diagnostic threshold. We excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, in consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into standardized evidence tables in Microsoft Excel® (Microsoft Corp., Redmond, WA). A second reviewer checked the data for accuracy. Evidence tables were tailored to each KQ and to specific study designs. Tables generally included details on study design and quality, setting and population (e.g., country, inclusion criteria, age, sex, race/ethnicity, maturity of population), screening and treatment details, reference standard or comparator details (if applicable), length of followup, and outcomes (e.g., accuracy, effectiveness, harms).

## Data Synthesis and Analysis

Because of the limited number of studies and the heterogeneity of outcomes assessed, interventions used, and presentation of results (such as category of scoliosis curve), we provided a narrative synthesis of results and used summary tables to compare results across different studies. For KQ 2 (accuracy), we calculated values from data provided where possible.

We used a standardized summary of evidence table to summarize the overall strength of evidence for each KQ. This table included the number and design of included studies, summary of findings by outcome, consistency or precision of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of the findings.

### Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^91^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^92^ Our method explicitly addresses four of the five required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and inclusion criteria was available for public comment in October 2015. We made only minor changes to our scope and review methods based on the comments received.

A draft version of this report was reviewed by invited content experts and federal partners listed in the acknowledgements. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and, subsequently, addressed in this version of the report.

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues regarding the scope for the final evidence synthesis. This research was funded by the Agency for Healthcare Research and Quality under a contract to support the work of the USPSTF. Agency staff provided oversight for the project, assisted in external review of the draft report, and reviewed the draft report.