# Appendix D Adverse Events Reported in BrAIST Trial

Appendix D Table 1 Adverse Events in Primary Analysis Population (As-Treated) of BrAIST Trial

| | Skin Bruising/Lacerations (on the Trunk) | Ulcers/Pressure Sores (on the Trunk) | Rash (on the Trunk) | Back Pain | Abnormal Breast Development | Anxiety | Depression | Other^‡^
Braced group (n=146)Number of events=9 | Nonserious (related)^*^ | 4 (4) | 3 (3) | 5 (5) | 33 (32) | -- | 2 (2) | 1 (1) | 30 (24)
Braced group (n=146)Number of events=9 | Serious^†^ (related)^*^ | -- | -- | -- | -- | -- | -- | -- | 1 (1)
Observed group (n=96)Number of events=41 | Nonserious (related)^*^ | -- | -- | -- | 30 (22) | 1 (1) | -- | 1 (0) | 9 (4)
Observed group (n=96)Number of events=41 | Serious (related)^*^ | -- | -- | -- | -- | -- | -- | -- | --

Source: Appendix of Weinstein 2013.^1^

* The number in parentheses indicates the number of events related to BrAIST or AIS. Events were considered “related” based on the judgment of the investigator or research coordinator.

† Events were considered “serious” if the event was related to the protocol and resulted in any of the following: intervention required to prevent permanent impairment or damage, hospitalization, persistent disability, life-threatening experience or death.

‡ “Other” events listed on next page.

## “Other” Adverse Events: Brace (n=31)

### Serious Adverse Event

# Anxiety and depression

### Nonserious Adverse Event

# Gastric discomfort/nausea after eating

# Asymmetrical patellar reflex.

# Right scapular pain.

# Self-reported depression, patient no longer participates in usual activities because of his insecurity regarding his back/appearance.

# Numbness in left shoulder blade area of back.

# Sharp, shooting pain down right arm from shoulder to elbow, numbness in forearm.

# Hip pain

# Midback pain

# Shoulder pain

# Knee pain

# Neck Pain

# Brace causing a lot of hip pain. Rubbing rubs off layer of skin so limits brace wear.

# Shoulder and under arm pain after adjustments were made to brace

# Pain near the inferior aspect of the right scapula radiating to the axillary region. Area has mild redness. Pt believes the pain is related to brace wear

# Right hip goes numb when standing or walking for a long length of time

# Asthma flair up

# Occasional numbness in arms and legs and occasional spasms in arms only.

# Tingling, poking sensation on right rib area where temperature monitor in brace.

# Right arm/shoulder pain

# Participant is having back pain all the time and is no longer wearing a brace.

# Headaches while wearing the brace

# Pt. reports having suicidal thoughts

# Numbness/ tingling or weakness of arms or legs, limits activity.

# Side pain, limits activity

Vasovagal response and fainting during a school field trip

Numbness occasionally in arms and legs

Salter-Harris I fracture distal phalanx of the right great toe

Abdominal pain

Injured ankle - small fracture to growth plate lateral side

Dislocated patella

## “Other” Adverse Events: Observed (n=9)

# Buttock, hip and thigh pain

# Hand & feet numbness

# Numbness/tingling in fingers

# Shoulder pain

Hip pain from gymnastics

Fracture right great toe

Mild pain in right foot most likely due to clubfeet

Right heel pain due to motor vehicle accident

Uneven shoulders, pain (ache)

# Events were considered “related” based on the judgment of the investigator or research coordinator.

## References

1 Weinstein SL, Dolan LA, Wright JG, . Effects of bracing in adolescents with idiopathic scoliosis. N Engl J Med. 2013;369(16):1512-21. PMID: 24047455.24047455