# Appendix C Excluded Studies

Exclusion codes

Code | Reason for Exclusion
E1 | Not English
E2 | Not original research in a peer-reviewed journal
E3 | Publication date
E4 | Ineligible SETTING
E5 | Ineligible POPULATION
E6 | Ineligible OUTCOMES
E7 | Ineligible SCREENING
E8 | Ineligible TREATMENT
E9 | Ineligible STUDY DESIGN
E10 | Study rated as poor quality
E11 | Overlapping populations
E12 | Non-applicable
E14 | Irretrievable

1 [Commentary on] Spinal range of motion, muscle endurance and back pain and function at least 20 years after fusion, or brace treatment for adolescent idiopathic scoliosis: a case control study. D.C. Tracts. 2007;191:8-11 4p. PMID: 106176098. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
2 Adolescent scoliosis outcomes 50 years down the road. Joint Letter. 2003;95:51-52 2p. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.
3 Screening for adolescent idiopathic scoliosis. Policy statement. US Preventive Services Task Force. JAMA. 1993;26920:2664-6. PMID: 8487451. KQ1E6, KQ2E9, KQ3E12, KQ4E12, KQ5E9, KQ6E12.8487451
4 Spinal Stabilization Exercise Effectiveness for Low Back Pain in Adolescent Idiopathic Scoliosis: A Randomized Trial. Pediatric Physical Therapy. 2015;270:396-402 7p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
5 #Error SRS-7: A Valid, Responsive, Linear, and Unidimensional Functional Outcome Measure for Operatively Treated Patients With AIS. Spine (03622436). 2015;409:650-655 6p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
6 #Error To screen or not to screen for adolescent idiopathic scoliosis? A review of the literature. Public Health (Elsevier). 2015;1299:1267-1272. PMID: . KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.
7 Aaro S, Berg U. The immediate effect of Boston brace on renal function in patients with idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1982;0170:243-7. PMID: 7127954. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.7127954
8 Aaro S, Dahlborn M. The effect of Harrington instrumentation on the longitudinal axis rotation of the apical vertebra and on the spinal and rib-cage deformity in idiopathic scoliosis studied by computer tomography. Spine. 1982;75:456-62. PMID: 7178984. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7178984
9 Aartun E, Degerfalk A, Kentsdotter L . Screening of the spine in adolescents: inter- and intra-rater reliability and measurement error of commonly used clinical tests. BMC musculoskeletal disorders. 2014;150:37. PMID: 24512306. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.24512306
10 Abbott A,Moller H,Gerdhem P CONTRAIS: CONservative TReatment for Adolescent Idiopathic Scoliosis: A randomised controlled trial protocol. BMC musculoskeletal disorders. 2013;14:. PMID: 0. KQ1E12, KQ2E12, KQ3E6e, KQ4E12, KQ5E12, KQ6E6e.
11 Abo-Bakr A, Al-Mazyiad A, Al-Hussein M . Adolescent idiopathic scoliosis screening of schoolgirls. Annals of Saudi medicine. 1992;126:555-7. PMID: 17587048. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.17587048
12 Abott TR, Bentley G. Intra-operative awakening during scoliosis surgery. Anaesthesia. 1980;353:298-302. PMID: 7396143. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.7396143
13 Abul-Kasim K. and Ohlin A. The rate of screw misplacement in segmental pedicle screw fixation in adolescent idiopathic scoliosis. Acta Orthopaedica. 2011;821:50-55 6p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
14 Adler N, Bleck EE, Rinsky LA . Balance reactions and eye-hand coordination in idiopathic scoliosis. Journal of Orthopaedic Research. 1986;41:102-7. PMID: 3950801. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.3950801
15 Adler NS, Csongradi J, Bleck EE. School screening for scoliosis. One experience in California using clinical examination and moire photography. Western Journal of Medicine. 1984;1415:631-3. PMID: 6516333. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.6516333
16 Adobor RD, Riise RB, Sorensen R . Scoliosis detection, patient characteristics, referral patterns and treatment in the absence of a screening program in Norway. Scoliosis. 2012;71:18. PMID: 23098059. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.23098059
17 Agabegi SS, Kazemi N, Sturm PF . Natural History of Adolescent Idiopathic Scoliosis in Skeletally Mature Patients: A Critical Review. J Am Acad Orthop Surg. 2015;:. PMID: 26510624. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.26510624
18 Ajemba PO, Ramirez L, Durdle NG . A support vectors classifier approach to predicting the risk of progression of adolescent idiopathic scoliosis. IEEE Transactions on Information Technology in Biomedicine. 2005;92:276-82. PMID: 16138544. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.16138544
19 Akazawa T, Minami S, Kotani T . Health-Related Quality of Life and Low Back Pain of Patients Surgically Treated for Scoliosis After 21 Years or More of Follow-up: Comparison Among Nonidiopathic Scoliosis, Idiopathic Scoliosis, and Healthy Subjects. Spine (03622436). 2012;3722:1899-1903. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
20 Akazawa T. and Minami S. and Kotani T. and Nemoto T. and Koshi T. and Takahashi K. Long-term clinical outcomes of surgery for adolescent idiopathic scoliosis 21 to 41 years later. Spine (03622436). 2012;375:402-405 4p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E5, KQ5E12, KQ6E6.
21 Akoume MY, Azeddine B, Turgeon I . Cell-based screening test for idiopathic scoliosis using cellular dielectric spectroscopy. Spine (03622436). 2010;3513:E601-8 1p. PMID: . KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.
22 Al-Aubaidi ZT, Tropp H, Pedersen NW . Comparison of in-and outpatients protocols for providence night time only bracing in AIS patients - compliance and satisfaction. Scoliosis. 2013;80:6. PMID: 23587285. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.23587285
23 Alexander RG. The effects on tooth position and maxillofacial vertical growth during treatment of scoliosis with the Milwaukee brace. American Journal of Orthodontics. 1966;523:161-89. PMID: 4951430. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.4951430
24 Allen BLJr, Ferguson RL. Topics of interest in pediatric orthopedics. Pediatric Clinics of North America. 1985;325:1333-45. PMID: 3897993. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.3897993
25 Allington Nj,Bowen Jr Adolescent idiopathic scoliosis: treatment with the Wilmington brace. A comparison of full-time and part-time use. Journal of Bone and Joint Surgery. American Volume. 1996;787:1056-62. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
26 Alpert HW, Farley FA, Caird MS . Outcomes following removal of instrumentation after posterior spinal fusion. Journal of Pediatric Orthopedics. 2014;346:613-7. PMID: 24487974. KQ1E12, KQ2E12, KQ3E5, KQ4E5, KQ5E12, KQ6E5.24487974
27 Altiok H, Lubicky JP, DeWald CJ . The superior mesenteric artery syndrome in patients with spinal deformity. Spine. 2005;3019:2164-70. PMID: 16205341. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.16205341
28 Alves de AraÃºjo Maria ErivÃ¢nia and Bezerra da Silva Elirez and Bragade Mello Danielli and Cader SamÃ¡ria Ali and Shiguemi Inoue Salgado Afonso and Dantas EstÃ©lio Henrique Martin The effectiveness of the Pilates method: Reducing the degree of non-structural scoliosis, and improving flexibility and pain in female college students. Journal of Bodywork & Movement Therapies. 2012;162:191-198 8p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
29 Alves VL. and Avanzi O. Objective assessment of the cardiorespiratory function of adolescents with idiopathic scoliosis through the six-minute walk test. Spine (03622436). 2009;3425:E926-9 1p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
30 Alves Vlds,Stirbulov R, Avanzi O. Impact of a physical rehabilitation program on the respiratory function of adolescents with idiopathic scoliosis. Chest. 2006;1302:500-5. PMID: 0. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E6.
31 Amendt LE. and Ause-Ellias KL. and Eybers JL. and Wadsworth CT. and Nielsen DH. and Weinstein SL. Validity and reliability testing of the Scoliometer. Physical Therapy. 1990;702:108-17. PMID: 2296610. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.2296610
32 Amzallag-Bellenger E, Uyttenhove F, Nectoux E . Idiopathic scoliosis in children and adolescents: assessment with a biplanar X-ray device. Insights Into Imaging. 2014;55:571-83. PMID: 25217150. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.25217150
33 Anciaux M, Lenaert A, Van Beneden ML . Transcutaneous electrical stimulation (TCES) for the treatment of adolescent idiopathic scoliosis: preliminary results. Acta Orthopaedica Belgica. 1991;574:399-405. PMID: 1772016. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8.1772016
34 Andersen MÃ¸ and Thomsen K. and Kyvik KO. Perceived health status in self-reported adolescent idiopathic scoliosis: a survey based on a population of twins. Spine (03622436). 2010;3516:1571-1574. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
35 Andersen MO, Andersen GR, Thomsen K . Early weaning might reduce the psychological strain of Boston bracing: a study of 136 patients with adolescent idiopathic scoliosis at 3.5 years after termination of brace treatment. J Pediatr Orthop B. 2002;112:96-9. PMID: 11943980. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.11943980
36 Andersen MO, Christensen SB, Thomsen K. Outcome at 10 years after treatment for adolescent idiopathic scoliosis. Spine (03622436). 2006;313:350-354 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.
37 Andrews G, MacEwen GD. Idiopathic scoliosis. An 11-year follow-up study of the role of the Milwaukee brace in curve control and trunco-pelvic alignment. Orthopedics. 1989;126:809-16. PMID: 2740262. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.2740262
38 Andriacchi TP, Schultz AB, Belytschko TB . Milwaukee brace correction of idiopathic scoliosis. A biomechanical analysis and a restrospective study. Journal of Bone & Joint Surgery - American Volume. 1976;586:806-15. PMID: 956227. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.956227
39 Anekstein Y, Mirovsky Y, Arnabitsky V . Reversing the concept: correction of adolescent idiopathic scoliosis using the convex rod de-rotation maneuver. European Spine Journal. 2012;2110:1942-9. PMID: 22592881. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22592881
40 Anonymous New scoliosis database tracks treatment outcomes. Data Strategies & Benchmarks. 2002;67:108-11. PMID: 12219359. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.12219359
41 Anwer S, Alghadir A, Abu Shaphe M . Effects of Exercise on Spinal Deformities and Quality of Life in Patients with Adolescent Idiopathic Scoliosis. BioMed Research International. 2015;2015:123848. PMID: 26583083. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.26583083
42 Appelgren G, Willner S. End vertebra angle--a roentgenographic method to describe a scoliosis. A follow-up study of idiopathic scoliosis treated with the Boston brace. Spine. 1990;152:71-4. PMID: 2326714. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.2326714
43 Apter A, Morein G, Munitz H . The psychosocial sequelae of the Milwaukee brace in adolescent girls. Clinical Orthopaedics & Related Research. 1978;0131:156-9. PMID: 657613. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.657613
44 Archer IA, Dickson RA. Stature and idiopathic scoliosis. A prospective study. Journal of Bone & Joint Surgery - British Volume. 1985;672:185-8. PMID: 3980522. KQ1E12, KQ2E12, KQ3E12, KQ4E6a, KQ5E12, KQ6E12.3980522
45 Armstrong GW, Livermore NB 3rd,Suzuki N . Nonstandard vertebral rotation in scoliosis screening patients. Its prevalence and relation to the clinical deformity. Spine. 1982;71:50-4. PMID: 7071661. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7071661
46 Ascani E, Bartolozzi P, Logroscino CA . Natural history of untreated idiopathic scoliosis after skeletal maturity. Spine (Phila Pa 1976). 1986;118:784-9. PMID: 3810293. KQ1E12, KQ2E12, KQ3E12, KQ4E9c, KQ5E12, KQ6E12.3810293
47 Asher M, Burton D. Long-term effects of scoliosis. Studies in Health Technology & Informatics. 2002;910:369-71. PMID: 15457758. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.15457758
48 Asher M, Lai SM, Burton D . Discrimination validity of the Scoliosis Research Society-22 Patient Questionnaire: relationship to idiopathic scoliosis curve pattern and curve size…including commentary by Keller RB. Spine (03622436). 2003;281:74-78 5p. PMID: 106848568. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
49 Asher M, Lai SM, Burton D . Spine deformity correlates better than trunk deformity with idiopathic scoliosis patients' quality of life questionnaire responses. Studies in Health Technology & Informatics. 2002;910:462-4. PMID: 15457777. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E12, KQ6E6.15457777
50 Asher M, Manna B, Lark R. Coronal and transverse plane trunk asymmetry correction following torsional segmental spinal instrumentation for idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;880:393-4. PMID: 15456068. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.15456068
51 Asher M, Min Lai S, Burton D . The reliability and concurrent validity of the scoliosis research society-22 patient questionnaire for idiopathic scoliosis. Spine. 2003;281:63-9. PMID: 12544958. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8.12544958
52 Asher MA, Burton DC. Adolescent idiopathic scoliosis: natural history and long term treatment effects. Scoliosis. 2006;11:2. PMID: 16759428. KQ1E12, KQ2E12, KQ3E2, KQ4E2, KQ5E12, KQ6E2.16759428
53 Athanasopoulos S,Paxinos T,Tsafantakis E,Zachariou K,Chatziconstantinou S The effect of aerobic training in girls with idiopathic scoliosis. Scandinavian journal of medicine & science in sports. 1999;91:36-40. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
54 Auerbach JD, Lonner BS, Crerand CE . Body image in patients with adolescent idiopathic scoliosis: validation of the Body Image Disturbance Questionnaire--Scoliosis Version. Journal of Bone & Joint Surgery - American Volume. 2014;968:e61. PMID: 24740669. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24740669
55 Aulisa AG, Giordano M, Falciglia F . Correlation between compliance and brace treatment in juvenile and adolescent idiopathic scoliosis: SOSORT 2014 award winner. Scoliosis. 2014;90:6. PMID: 24995038. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.24995038
56 Aulisa AG, Guzzanti V, Falciglia F . Lyon bracing in adolescent females with thoracic idiopathic scoliosis: a prospective study based on SRS and SOSORT criteria. BMC musculoskeletal disorders. 2015;161:316. PMID: 26497776. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.26497776
57 Aulisa AG, Guzzanti V, Perisano C . CORRELATION BETWEEN HUMP DIMENSIONS AND CURVE SEVERITY IN IDIOPATHIC SCOLIOSIS BEFORE AND AFTER CONSERVATIVE TREATMENT. Spine (Phila Pa 1976). 2011;:. PMID: 21224763. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.21224763
58 Aulisa AG. and Guzzanti V. and Perisano C. and Marzetti E. and Falciglia F. and Aulisa L. Treatment of lumbar curves in scoliotic adolescent females with progressive action short brace: a case series based on the scoliosis research society committee criteria. Spine (03622436). 2012;3713:E786-91 1p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
59 Axelgaard J. and Brown JC. Lateral electrical surface stimulation for the treatment of progressive idiopathic scoliosis. Spine (Phila Pa 1976). 1983;83:242-60. PMID: 6604946. KQ1E12, KQ2E12, KQ3E8c, KQ4E12, KQ5E12, KQ6E8c.6604946
60 Babaee Taher and Kamya Mojtaba and Ganjavian Mohammad Saleh and Kamali Mohammad Milwaukee brace or thoracolumbosacral orthosis? Which one affects the quality of life of adolescents with idiopathic scoliosis more? A cross-sectional study using the SRS-22 questionnaire. Current Orthopaedic Practice. 2014;255:478-483 6p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
61 Babu SS, Kiran KR, Babu TV . Anthropometric estimation of body height after surgical correction of scoliosis. Journal of Orthopaedic Surgery. 2014;223:360-3. PMID: 25550019. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.25550019
62 Bago J, Perez-Grueso FJ, Pellise F . How do idiopathic scoliosis patients who improve after surgery differ from those who do not exceed a minimum detectable change?. European Spine Journal. 2012;211:50-6. PMID: 21932063. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21932063
63 Balg F, Juteau M, Theoret C . Validity and reliability of the iPhone to measure rib hump in scoliosis. Journal of Pediatric Orthopedics. 2014;348:774-9. PMID: 24787301. KQ1E1, KQ2E1, KQ3E12, KQ4E12, KQ5E1, KQ6E12.24787301
64 Banjar HH. Pediatric scoliosis and the lung. Saudi Medical Journal. 2003;249:957-63. PMID: 12973477. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.12973477
65 Bar-Dayan Y, Morad Y, Elishkevitz KP . Back disorders among Israeli youth: a prevalence study in young military recruits. Spine Journal: Official Journal of the North American Spine Society. 2012;129:749-55. PMID: 20541476. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.20541476
66 Barrack RL, Whitecloud TS 3rd,Burke SW . Proprioception in idiopathic scoliosis. Spine. 1984;97:681-5. PMID: 6505836. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.6505836
67 Barrios C, Cortés S, Pérez-Encinas C . Anthropometry and body composition profile of girls with nonsurgically treated adolescent idiopathic scoliosis. Spine (03622436). 2011;3618:1470-1477. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
68 Barrios C, Pérez-Encinas C, Maruenda JI . Significant ventilatory functional restriction in adolescents with mild or moderate scoliosis during maximal exercise tolerance test. Spine (03622436). 2005;3014:1610-1615. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
69 Bartal E, Gage JR. Idiopathic juvenile osteoporosis and scoliosis. Journal of Pediatric Orthopedics. 1982;23:295-8. PMID: 7130387. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.7130387
70 Bartie BJ, Lonstein JE, Winter RB. Long-term follow-up of adolescent idiopathic scoliosis patients who had Harrington instrumentation and fusion to the lower lumbar vertebrae: is low back pain a problem?. Spine (03622436). 2009;3424:E873-8 1p. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E6, KQ5E12, KQ6E8.
71 Bas T, Franco N, Bas P . Pain and disability following fusion for idiopathic adolescent scoliosis: prevalence and associated factors. Evidencebased Spinecare Journal. 2012;32:17-24. PMID: 23230414. KQ1E12, KQ2E12, KQ3E9c, KQ4E5, KQ5E12, KQ6E9c.23230414
72 Basques Bryce A, Bohl Daniel D, Golinvaux Nicholas S . Patient Factors Are Associated With Poor Short-term Outcomes After Posterior Fusion for Adolescent Idiopathic Scoliosis. Clinical Orthopaedics & Related Research. 2015;1:0. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5a.
73 Bassett GS, Bunnell WP, MacEwen GD. Treatment of idiopathic scoliosis with the Wilmington brace. Results in patients with a twenty to thirty-nine-degree curve. Journal of Bone & Joint Surgery - American Volume. 1986;684:602-5. PMID: 3957986. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.3957986
74 Bassett GS, Bunnell WP. Effect of a thoracolumbosacral orthosis on lateral trunk shift in idiopathic scoliosis. Journal of Pediatric Orthopedics. 1986;62:182-5. PMID: 3958173. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.3958173
75 Bassett Gs,Bunnell Wp Influence of the Wilmington brace on spinal decompensation in adolescent idiopathic scoliosis. Clin Orthop Relat Res. 1987;2230:164-9. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
76 Bastrom TP, Marks MC, Yaszay B . Prevalence of postoperative pain in adolescent idiopathic scoliosis and the association with preoperative pain. Spine (Phila Pa 1976). 2013;3821:1848-52. PMID: 23883827. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.23883827
77 Batouche M, Benlamri R, Kholladi MK. A computer vision system for diagnosing scoliosis using moire images. Computers in Biology & Medicine. 1996;264:339-53. PMID: 8814393. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.8814393
78 Beals RK, Kenney KH, Lees MH. Congenital heart disease and idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1972;890:112-6. PMID: 4646251. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.4646251
79 Beauséjour M, Roy-Beaudry M, Goulet L . Patient characteristics at the initial visit to a scoliosis clinic: a cross-sectional study in a community without school screening. Spine (03622436). 2007;3212:1349-1354. PMID: 0. KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.
80 Begon M, Scherrer SA, Coillard C . Three-dimensional vertebral wedging and pelvic asymmetries in the early stages of adolescent idiopathic scoliosis. Spine Journal: Official Journal of the North American Spine Society. 2015;153:477-86. PMID: 25463399. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.25463399
81 Bengtsson G. and Fallstrom K. and Jansson B. and Nachemson A. A psychological and psychiatric investigation of the adjustment of female scoliosis patients. Acta Psychiatr Scand. 1974;501:50-9. PMID: 4275025. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.4275025
82 Benli IT, Ates B, Akalin S . Minimum 10 years follow-up surgical results of adolescent idiopathic scoliosis patients treated with TSRH instrumentation. European Spine Journal. 2007;163:381-91. PMID: 16924553. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.16924553
83 Bennett JT, Hoashi JS, Ames RJ . The posterior pedicle screw construct: 5-year results for thoracolumbar and lumbar curves. Journal of Neurosurgery Spine. 2013;196:658-63. PMID: 24074506. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.24074506
84 Berg DC, Hill DL, Raso VJ . Using three-dimensional difference maps to assess changes in scoliotic deformities. Medical & Biological Engineering & Computing. 2002;403:290-5. PMID: 12195975. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.12195975
85 Berg U, Aaro S. Long-term effect of Boston brace treatment on renal function in patients with idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1983;0180:169-72. PMID: 6627785. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E10.6627785
86 Berliner JL, Verma K, Lonner BS . Discriminative validity of the Scoliosis Research Society 22 questionnaire among five curve-severity subgroups of adolescents with idiopathic scoliosis. Spine Journal: Official Journal of the North American Spine Society. 2013;132:127-33. PMID: 23218828. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.23218828
87 Bernard JC, Deceuninck J, Kohn C. Vital capacity evolution in patients treated with the CMCR brace: statistical analysis of 90 scoliotic patients treated with the CMCR brace. Scoliosis. 2011;61:19. PMID: 21880121. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E9c.21880121
88 Bernard JC, Lecante C, Deceuninck J . The carbon brace. Scoliosis. 2013;81:3. PMID: 23409701. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23409701
89 Bernard Jc,Jemni S,Schneider M,Boussard D,Saillard V,Bard R Evaluation of the efficacy of a carbon brace (“Corset monocoque carbone respectant la respiration” [CMCR]) preserving lung capacity to treat idiopathic scoliosis in children and adolescents: a retrospective study of 115 patients. Annales de Readaptation et de Medecine Physique. 2005;489:637-49. PMID: 0. KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
90 Bertrand SL, Drvaric DM, Lange N . Electrical stimulation for idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1992;0276:176-81. PMID: 1537148. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.1537148
91 Bettany-Saltikov J, Weiss HR, Chockalingam N . Surgical versus non-surgical interventions in people with adolescent idiopathic scoliosis. Cochrane Database of Systematic Reviews. 2015;40:CD010663. PMID: 25908428. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.25908428
92 Bettany-Saltikov Josette,Weiss Hans-Rudolf,Chockalingam Nachiappan,Taranu Razvan,Srinivas Shreya,Hogg Julie,Whittaker Victoria,Kalyan Raman V. Surgical versus non-surgical interventions in patients with adolescent idiopathic scoliosis. Cochrane Database of Systematic Reviews: Reviews. 2013;0:0. PMID: 10000010663. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
93 Betz RR, Ranade A, Samdani AF . Vertebral body stapling: a fusionless treatment option for a growing child with moderate idiopathic scoliosis. Spine (Phila Pa 1976). 2010;352:169-76. PMID: 20081512. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.20081512
94 Bialik V, Piggott H. Pseudarthrosis following treatment of idiopathic scoliosis by Harrington instrumentation and fusion without added bone. Journal of Pediatric Orthopedics. 1987;72:152-4. PMID: 3558796. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5.3558796
95 Birch JG, Herring JA, Roach JW . Cotrel-Dubousset instrumentation in idiopathic scoliosis. A preliminary report. Clinical Orthopaedics & Related Research. 1988;2270:24-9. PMID: 3338212. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3338212
96 Bjerkreim I, Hassan I. Progression in untreated idiopathic scoliosis after end of growth. Acta Orthop Scand. 1982;536:897-900. PMID: 7180400. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.7180400
97 Bjerkreim I, Steen H, Brox JI. Idiopathic scoliosis treated with cotrel-dubousset instrumentation: evaluation 10 years after surgery. Spine (03622436). 2007;3219:2103-2110. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
98 Bjure J, Grimby G, Nachemson A. The effect of physical training in girls with idiopathic scoliosis. Acta Orthop Scand. 1969;403:325-33. PMID: 5371314. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.5371314
99 Bjure J, Nachemson A. Non-treated scoliosis. Clinical Orthopaedics & Related Research. 1973;093:44-52. PMID: 4579097. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.4579097
100 Bleck EE. Adolescent idiopathic scoliosis. Developmental Medicine & Child Neurology. 1991;332:167-73. PMID: 2015986. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.2015986
101 Blicharska I, Brzek A, Durmala J. Short-term effect (ATR, Kasperczyk's Scale, chest's mobility) of using of physiotherapy method in the treatment of AIS - pilot study. Studies in Health Technology & Informatics. 2012;1760:387-92. PMID: 22744536. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.22744536
102 Boer Wa,Anderson Pg,Limbeek J,Kooijman Ma Treatment of idiopathic scoliosis with side-shift therapy: an initial comparison with a brace treatment historical cohort. European Spine Journal. 1999;85:406-10. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
103 Bohl Daniel D, Telles Connor J, Golinvaux Nicholas S . Effectiveness of providence nighttime bracing in patients with adolescent idiopathic scoliosis. Orthopedics. 2014;3712:e1085-90 1. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
104 Bohl DD, Telles CJ, Ruiz FK . A Genetic Test Predicts Providence Brace Success for Adolescent Idiopathic Scoliosis When Failure is Defined as Progression to Greater Than 45 Degrees. Journal of Spinal Disorders & Techniques. 2014;:. PMID: 24662287. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
105 Boot DA, McMaster MJ. The surgical management of adolescent idiopathic scoliosis in Edinburgh 1975-1982. Journal of the Royal College of Surgeons of Edinburgh. 1984;291:42679. PMID: 6707985. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.6707985
106 Botens-Helmus C, Klein R, Stephan C. The reliability of the Bad Sobernheim Stress Questionnaire (BSSQbrace) in adolescents with scoliosis during brace treatment. Scoliosis. 2006;1:22. PMID: 17176483. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E9.17176483
107 Bott J. Scoliosis. Journal of the Florida Medical Association. 1989;765:465-8. PMID: 2693581. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.2693581
108 Bowen JR, Keeler KA, Pelegie S. Adolescent idiopathic scoliosis managed by a nighttime bending brace. Orthopedics. 2001;2410:967-970 4p. PMID: 0. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E6.
109 Boyer J, Amin N, Taddonio R . Evidence of airway obstruction in children with idiopathic scoliosis. CHEST. 1996;1096:1532-1535. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
110 Branthwaite MA. Cardiorespiratory consequences of unfused idiopathic scoliosis. Br J Dis Chest. 1986;804:360-9. PMID: 3620323. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.3620323
111 Bridwell KH, Shufflebarger HL, Lenke LG . Parents' and patients' preferences and concerns in idiopathic adolescent scoliosis: a cross-sectional preoperative analysis. Spine (03622436). 2000;2518:2392-2399. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
112 Brooks HL, Azen SP, Gerberg E . Scoliosis: A prospective epidemiological study. Journal of Bone & Joint Surgery - American Volume. 1975;577:968-72. PMID: 1194304. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.1194304
113 Brown JC, Axelgaard J, Howson DC. Multicenter trial of a noninvasive stimulation method for idiopathic scoliosis. A summary of early treatment results. Spine. 1984;94:382-7. PMID: 6382634. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.6382634
114 Bruggi M, Lisi C, Rodigari A . Monitoring iliopsoas muscle contraction in idiopathic lumbar scoliosis patients. Giornale Italiano di Medicina del Lavoro Ed Ergonomia. 2014;363:186-91. PMID: 25369718. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.25369718
115 Buchanan R, Birch JG, Morton AA . Do you see what I see? Looking at scoliosis surgical outcomes through orthopedists' eyes. Spine. 2003;2824:2700-4; di. PMID: 14673372. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.14673372
116 Bunch WH, Chapman RG. Patient preferences in surgery for scoliosis. Journal of Bone & Joint Surgery - American Volume. 1985;675:794-9. PMID: 3997933. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3997933
117 Bunch WH. Posterior fusion for idiopathic scoliosis. Instr Course Lect. 1985;340:140-52. PMID: 3833935. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.3833935
118 Bunge EM, Habbema JDF, de Koning HJ. A randomised controlled trial on the effectiveness of bracing patients with idiopathic scoliosis: failure to include patients and lessons to be learnt. Eur Spine J. 2010;195:747-53. PMID: 20195651. KQ1E12, KQ2E12, KQ3E6e, KQ4E12, KQ5E12, KQ6E6e.20195651
119 Bunge EM, Juttmann RE, de Koning HJ. Screening for scoliosis: do we have indications for effectiveness?. Journal of Medical Screening. 2006;131:29-33 5p. PMID: 0. KQ1E9, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
120 Bunge EM, Juttmann RE, van Biezen FC . Estimating the effectiveness of screening for scoliosis: a case-control study. Pediatrics. 2008;1211:9-14 6p. PMID: 0. KQ1E9, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
121 Bunge Em,Juttmann Re,Kleuver M,Biezen Fc,Koning Hj Health-related quality of life in patients with adolescent idiopathic scoliosis after treatment: short-term effects after brace or surgical treatment. European Spine Journal. 2007;161:83-9. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
122 Bunge Em,Koning Hj Bracing patients with idiopathic scoliosis: design of the Dutch randomized controlled treatment trial. BMC musculoskeletal disorders. 2008;9:57. PMID: 0. KQ1E12, KQ2E12, KQ3E6e, KQ4E12, KQ5E12, KQ6E6e.18430217
123 Bunnell WP, MacEwen GD, Jayakumar S. The use of plastic jackets in the non-operative treatment of idiopathic scoliosis. Preliminary report. Journal of Bone & Joint Surgery - American Volume. 1980;621:31-8. PMID: 7351413. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.7351413
124 Bunnell WP. Outcome of spinal screening. Spine (Phila Pa 1976). 1993;1812:1572-80. PMID: 8235833. KQ1E12, KQ2E5, KQ3E12, KQ4E12, KQ5E12, KQ6E12.8235833
125 Bunnell WP. Selective screening for scoliosis. Clinical Orthopaedics & Related Research,. 2005;434:. PMID: 0. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.
126 Bunnell WP. The natural history of idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1988;0229:20-5. PMID: 3280198. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.3280198
127 Bunnell WP. The natural history of idiopathic scoliosis before skeletal maturity. Spine (Phila Pa 1976). 1986;118:773-6. PMID: 3810290. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.3810290
128 Buric M, Momcilovic B. Growth pattern and skeletal age in school girls with idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1982;0170:238-42. PMID: 7127953. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.7127953
129 Burwell RG, Dangerfield PH, Moulton A . Whither the etiopathogenesis (and scoliogeny) of adolescent idiopathic scoliosis? Incorporating presentations on scoliogeny at the 2012 IRSSD and SRS meetings. Scoliosis. 2013;81:4. PMID: 23448588. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.23448588
130 Burwell RG, Dangerfield PH. The NOTOM hypothesis for idiopathic scoliosis: is it nullified by the delayed puberty of female rhythmic gymnasts and ballet dancers with scoliosis?. Studies in Health Technology & Informatics. 2002;910:42708. PMID: 15457686. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.15457686
131 Burwell RG, James NJ, Johnson F . Standardised trunk asymmetry scores. A study of back contour in healthy school children. Journal of Bone & Joint Surgery - British Volume. 1983;654:452-63. PMID: 6874719. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.6874719
132 Butler PF, Thomas AW, Thompson WE . Simple methods to reduce patient exposure during scoliosis radiography. Radiologic Technology. 1986;575:411-7. PMID: 3715012. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.3715012
133 Buttermann GR, Mullin WJ. Pain and disability correlated with disc degeneration via magnetic resonance imaging in scoliosis patients. European Spine Journal. 2008;172:240-9. PMID: 17973128. KQ1E12, KQ2E12, KQ3E12, KQ4E9b, KQ5E12, KQ6E12.17973128
134 Cahill PJ, Hoashi JS, Betz RR . Is there a role for the 5-degree rule in adolescent idiopathic scoliosis?. Journal of Pediatric Orthopedics. 2014;342:194-201. PMID: 25028800. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.25028800
135 Cahill PJ, Warnick DE, Lee MJ . Infection after spinal fusion for pediatric spinal deformity: thirty years of experience at a single institution. Spine (03622436). 2010;3512:1211-1217. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6d.
136 Campos M. and Dolan L. and Weinstein S. Unanticipated revision surgery in adolescent idiopathic scoliosis. Spine (03622436). 2012;3712:1048-1053. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
137 Carman D, Roach JW, Speck G . Role of exercises in the Milwaukee brace treatment of scoliosis. Journal of Pediatric Orthopedics. 1985;51:65-8. PMID: 3980709. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3980709
138 Carpineta L, Labelle H. Evidence of three-dimensional variability in scoliotic curves. Clinical Orthopaedics & Related Research. 2003;0412:139-48. PMID: 12838064. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.12838064
139 Carr WA, Moe JH, Winter RB . Treatment of idiopathic scoliosis in the Milwaukee brace. Journal of Bone & Joint Surgery - American Volume. 1980;624:599-612. PMID: 7380859. KQ1E12, KQ2E12, KQ3E9, KQ4E9, KQ5E12, KQ6E9.7380859
140 Carreon LY, Puno RM, Lenke LG . Non-neurologic complications following surgery for adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery, American Volume. 2007;11:2427-2432. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6d.
141 Carreon LY, Sanders JO, Diab M . The minimum clinically important difference in Scoliosis Research Society-22 Appearance, Activity, And Pain domains after surgical correction of adolescent idiopathic scoliosis. Spine (03622436). 2010;3523:2079-2083. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
142 Carreon LY. and Sanders JO. and Diab M. and Sturm PF. and Sucato DJ. Patient satisfaction after surgical correction of adolescent idiopathic scoliosis. Spine (03622436). 2011;3612:965-968 4p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
143 Cassella MC, Hall JE. Current treatment approaches in the nonoperative and operative management of adolescent idiopathic scoliosis. Physical Therapy. 1991;7112:897-909. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
144 Caufriez Marcel,Fernández-Domínguez Juan Carlos,Brynhildsvoll Nils Preliminary study on the action of hypopressive gymnastics in the treatment of idiopathic scoliosis. Enfermeria Clinica. 2011;216:354-358 5p. PMID: . KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
145 Chaib Y, Bachy M, Zakine S . Postoperative perceived health status in adolescent following idiopathic scoliosis surgical treatment: results using the adapted French version of Scoliosis Research Society Outcomes questionnaire (SRS-22). Orthopaedics & traumatology, surgery & research. 2013;994:441-7. PMID: 23639761. KQ1E12, KQ2E12, KQ3E9, KQ4E6a, KQ5E12, KQ6E9.23639761
146 Chalmers E, Hill D, Zhao V . Prescriptive analytics applied to brace treatment for AIS: a pilot demonstration. Scoliosis. 2015;10:S13. PMID: 25815052. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.25815052
147 Chalmers E, Westover L, Jacob J . Predicting success or failure of brace treatment for adolescents with idiopathic scoliosis. Medical & Biological Engineering & Computing. 2015;5310:1001-9. PMID: 26002592. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.26002592
148 Chan A, Lou E, Hill D. Review of current technologies and methods supplementing brace treatment in adolescent idiopathic scoliosis. Journal of Childrens Orthopaedics. 2013;74:309-16. PMID: 24432092. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.24432092
149 Chan A, Moller J, Vimpani G . The case for scoliosis screening in Australian adolescents. Med J Aust. 1986;1458:379-83. PMID: 3762475. KQ1E6a, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.3762475
150 Chan SL, Cheung KM, Luk KD . A correlation study between in-brace correction, compliance to spinal orthosis and health-related quality of life of patients with Adolescent Idiopathic Scoliosis. Scoliosis. 2014;91:1. PMID: 24559234. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6a.24559234
151 Chan V. and Fong GC. and Luk KD. and Yip B. and Lee MK. and Wong MS. and Lu DD. and Chan TK. A genetic locus for adolescent idiopathic scoliosis linked to chromosome 19p13.3. Am J Hum Genet. 2002;712:401-6. PMID: 12094330. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.12094330
152 Charles YP, Daures JP, de Rosa V . Progression risk of idiopathic juvenile scoliosis during pubertal growth. Spine. 2006;3117:1933-42. PMID: 16924210. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.16924210
153 Charles YP. and DimÃ©glio A. and Marcoul M. and Bourgin JF. and Marcoul A. and Bozonnat MC. Influence of idiopathic scoliosis on three-dimensional thoracic growth. Spine (03622436). 2008;3311:1209-1218. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
154 Cheng JC, Guo X. Osteopenia in adolescent idiopathic scoliosis. A primary problem or secondary to the spinal deformity?. Spine. 1997;2215:1716-21. PMID: 9259781. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.9259781
155 Cheng JC, Hung VW, Lee WT . Persistent osteopenia in adolescent idiopathic scoliosis--longitudinal monitoring of bone mineral density until skeletal maturity. Studies in Health Technology & Informatics. 2006;1230:47-51. PMID: 17108402. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.17108402
156 Cheung J, Veldhuizen AG, Halbertsma JP . The relation between electromyography and growth velocity of the spine in the evaluation of curve progression in idiopathic scoliosis. Spine. 2004;299:1011-6. PMID: 15105674. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.15105674
157 Cheung Kmc,Cheng Eyl,Chan Scw,Yeung Kwk,Luk Kdk Outcome assessment of bracing in adolescent idiopathic scoliosis by the use of the SRS-22 questionnaire. International Orthopaedics. 2007;314:507-11. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
158 Chockalingam N, Rahmatalla A, Dangerfield P . Can posture analysis point towards curve progression in scoliotic subjects?. Studies in Health Technology & Informatics. 2006;1230:201-6. PMID: 17108427. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.17108427
159 Choi J,Kim Hs,Kim Gs,Lee H,Jeon H-S,Chung K-M Posture management program based on theory of planned behavior for adolescents with mild idiopathic scoliosis. Asian nursing research. 2013;73:120-7. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
160 Chong KC, Letts RM, Cumming GR. Influence of spinal curvature on exercise capacity. Journal of Pediatric Orthopedics. 1981;13:251-4. PMID: 7334102. KQ1E12, KQ2E12, KQ3E12, KQ4E6a, KQ5E12, KQ6E12.7334102
161 Chotigavanichaya C. Surgical treatment of idiopathic scoliosis. Journal of the Medical Association of Thailand. 1974;572:69-75. PMID: 4813707. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4813707
162 Chow DHK, Ng XHY, Holmes AD . Effects of backpack loading on the pulmonary capacities of normal schoolgirls and those with adolescent idiopathic scoliosis. Spine (03622436). 2005;3021:E649-54 1p. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
163 Christine C, Alin C, Rivard CH. Treatment of early adolescent idiopathic scoliosis using the SpineCor System. Studies in Health Technology & Informatics. 2008;1350:341-55. PMID: 18401103. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18401103
164 Christodoulou AG, Prince HG, Webb JK . Adolescent idiopathic thoracic scoliosis. A prospective trial with and without bracing during postoperative care. J Bone Joint Surg Br. 1987;691:13-6. PMID: 3818719. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3818719
165 Chu WCW, Li AM, Ng BKW . Dynamic magnetic resonance imaging in assessing lung volumes, chest wall, and diaphragm motions in adolescent idiopathic scoliosis versus normal controls. Spine (03622436). 2006;3119:2243-2249. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
166 Chun Yiu Cheng J, Lam TP, Wong MS . Answer to the letter of the editor T. Cook concerning ‘a prospective randomized controlled study on the treatment outcome of SpineCor brace versus rigid brace for adolescent idiopathic scoliosis with follow-up according to the SRS standardized criteria’ b. European Spine Journal. 2014;237:1580. PMID: 24861699. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.24861699
167 Cil A, Pekmezci M, Yazici M . The validity of Lenke criteria for defining structural proximal thoracic curves in patients with adolescent idiopathic scoliosis. Spine. 2005;3022:2550-5. PMID: 16284594. KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.16284594
168 Clark EM, Taylor HJ, Harding I . Association between components of body composition and scoliosis: a prospective cohort study reporting differences identifiable before the onset of scoliosis. Journal of Bone & Mineral Research. 2014;298:1729-36. PMID: 24616164. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.24616164
169 Clark EM, Tobias JH, Fairbank J. The Impact of Small Spinal Curves in Adolescents Who Have Not Presented to Secondary Care: A Population-Based Cohort Study. Spine. 2016;4110:E611-7. PMID: 26583476. KQ1E6, KQ2E7a, KQ3E6, KQ4E6a, KQ5E6, KQ6E6.26583476
170 Clayson D, Levine DB. Adolescent scoliosis patients. Personality patterns and effects of corrective surgery. Clinical Orthopaedics & Related Research. 1976;0116:99-102. PMID: 1277659. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.1277659
171 Clayson D, Mahon B, Levine DB. Preoperative personality characteristics as predictors of postoperative physical and psychological patterns in scoliosis. Spine. 1981;61:42625. PMID: 7209678. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.7209678
172 Climent JM. and Sanchez J. Impact of the type of brace on the quality of life of adolescents with spine deformities. Spine (03622436). 1999;2418:1903-1908. PMID: 107228281. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
173 Clough M, Justice CM, Marosy B . Males with familial idiopathic scoliosis: a distinct phenotypic subgroup. Spine (Phila Pa 1976). 2010;352:162-8. PMID: 20081511. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.20081511
174 Cochran T, Irstam L, Nachemson A. Long-term anatomic and functional changes in patients with adolescent idiopathic scoliosis treated by Harrington rod fusion. Spine. 1983;86:576-84. PMID: 6228016. KQ1E12, KQ2E12, KQ3E5, KQ4E9b, KQ5E12, KQ6E5.6228016
175 Cochran T, Nachemson A. Long-term anatomic and functional changes in patients with adolescent idiopathic scoliosis treated with the Milwaukee brace. Spine. 1985;102:127-33. PMID: 3159101. KQ1E12, KQ2E12, KQ3E9, KQ4E9c, KQ5E12, KQ6E8b.3159101
176 Coe JD, Arlet V, Donaldson W . Complications in spinal fusion for adolescent idiopathic scoliosis in the new millennium. A report of the Scoliosis Research Society Morbidity and Mortality Committee. Spine (03622436). 2006;313:345-349 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.
177 Coelho DM, Bonagamba GH, Oliveira AS. Scoliometer measurements of patients with idiopathic scoliosis. Brazilian Journal of Physical Therapy. 2013;172:179-84. PMID: 23778766. KQ1E6, KQ2E4, KQ3E12, KQ4E12, KQ5E6, KQ6E12.23778766
178 Coillard C, Circo A, Rivard CH. A new concept for the non-invasive treatment of adolescent idiopathic scoliosis: the CORRECTIVE MOVEMENT principle integrated in the SpineCor System. Disability & Rehabilitation: Assistive Technology. 2008;33:112-119 8p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
179 Coillard C, Leroux MA, Zabjek KF . SpineCor--a non-rigid brace for the treatment of idiopathic scoliosis: post-treatment results. European Spine Journal. 2003;122:141-8. PMID: 12709852. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.12709852
180 Coillard C,Vachon V,Circo Ab,Beausejour M,Rivard Ch Effectiveness of the SpineCor brace based on the new standardized criteria proposed by the scoliosis research society for adolescent idiopathic scoliosis. Journal of Pediatric Orthopaedics. 2007;274:375-9. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
181 ÇOlak TuĞBa Kuru,Apti Adnan,Dereli EElÇIn,ÖZdinÇLer Arzu Razak,ÇOlak İLker Scoliosis screening results of primary school students (11-15 years old group) in the west side of Istanbul. Journal of Physical Therapy Science. 2015;279:2797-2801. PMID: 110383461. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.
182 Collis DK, Ponseti IV. Long-term follow-up of patients with idiopathic scoliosis not treated surgically. J Bone Joint Surg Am. 1969;513:425-45. PMID: 4238082. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.4238082
183 Connolly PJ, Von Schroeder HP, Johnson GE . Adolescent idiopathic scoliosis. Long-term effect of instrumentation extending to the lumbar spine. Journal of Bone & Joint Surgery - American Volume. 1995;778:1210-6. PMID: 7642667. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7642667
184 Cook SD, Harding AF, Morgan EL . Trabecular bone mineral density in idiopathic scoliosis. Journal of Pediatric Orthopedics. 1987;72:168-74. PMID: 3558800. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.3558800
185 Cook T. Comment on Guo et al. entitled ‘a prospective randomized controlled study on the treatment outcome of SpineCor brace versus rigid brace for adolescent idiopathic scoliosis with follow-up according to the SRS standardized criteria’. European Spine Journal. 2014;237:1579. PMID: 24854727. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.24854727
186 Cooke ED, Carter LM, Pilcher MF. Identifying scoliosis in the adolescent with thermography: a preliminary study. Clinical Orthopaedics & Related Research. 1980;0148:172-6. PMID: 7379390. KQ1E9, KQ2E9, KQ3E12, KQ4E12, KQ5E9, KQ6E12.7379390
187 Coonrad RW, Murrell GA, Motley G . A logical coronal pattern classification of 2,000 consecutive idiopathic scoliosis cases based on the scoliosis research society-defined apical vertebra. Spine. 1998;2312:1380-91. PMID: 9654630. KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.9654630
188 Cooper DM, Rojas JV, Mellins RB . Respiratory mechanics in adolescents with idiopathic scoliosis. American Review of Respiratory Disease. 1984;1301:16-22. PMID: 6742606. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.6742606
189 Cordover AM, Betz RR, Clements DH . Natural history of adolescent thoracolumbar and lumbar idiopathic scoliosis into adulthood. J Spinal Disord. 1997;103:193-6. PMID: 9213273. KQ1E12, KQ2E12, KQ3E12, KQ4E10, KQ5E12, KQ6E12.9213273
190 Cote P, Kreitz BG, Cassidy JD . A study of the diagnostic accuracy and reliability of the Scoliometer and Adam's forward bend test. Spine. 1998;237:796-802; d. PMID: 9563110. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.9563110
191 Cote P, Kreitz BG, Cassidy JD . A study of the diagnostic accuracy and reliability of the Scoliometer and Adam's forward bend test… including commentary by Lonstein JE. Spine (03622436). 1998;237:796-803 8p. PMID: 107270316. KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.
192 Courvoisier A, Drevelle X, Vialle R . 3D analysis of brace treatment in idiopathic scoliosis. European Spine Journal. 2013;2211:2449-55. PMID: 23812685. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23812685
193 Courvoisier A, Eid A, Bourgeois E . Growth tethering devices for idiopathic scoliosis. Expert Review of Medical Devices. 2015;124:449-56. PMID: 26027921. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.26027921
194 Cowley DM, Pabari M, Sinton TJ . Pathogenesis of postoperative hyponatraemia following correction of scoliosis in children. Australian & New Zealand Journal of Surgery. 1988;586:485-9. PMID: 3077898. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3077898
195 Crostelli M, Mazza O. AIS and spondylolisthesis. European Spine Journal. 2013;0:S172-84. PMID: 22569830. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.22569830
196 Cuddihy L, Danielsson AJ, Cahill PJ . Vertebral Body Stapling versus Bracing for Patients with High-Risk Moderate Idiopathic Scoliosis. BioMed Research International. 2015;2015:438452. PMID: 26618169. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.26618169
197 Cundy TP, Delaney CL, Rackham MD . Chromium ion release from stainless steel pediatric scoliosis instrumentation. Spine (03622436). 2010;359:967-974 8p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.
198 Czaprowski D, Kotwicki T, Biernat R . Physical capacity of girls with mild and moderate idiopathic scoliosis: influence of the size, length and number of curvatures. European Spine Journal. 2012;216:1099-105. PMID: 22101867. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.22101867
199 Daentzer D,Steitz V,Noll C Influence of proprioceptive insoles on spine statics in patients with slight idiopathic scoliosis. European Spine Journal. 2014;2311:2488. PMID: 0. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
200 D'Agata E, Perez-Testor C, Negrini S . What is the role of self-esteem in adolescents with idiopathic scoliosis under a conservative treatment?. Scoliosis. Conference: 9th International Conference on Conservative Management of Spinal Deformities - SOSORT 2012 Annual Meeting Italy. Conference Start: 20120510 Conference End: 20120512. 2013;80:. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.
201 d'Amato CR, Griggs S, McCoy B. Nighttime bracing with the Providence brace in adolescent girls with idiopathic scoliosis. Spine (03622436). 2001;2618:2006-2012. PMID: 0. KQ1E12, KQ2E12, KQ3E9c, KQ4E6a, KQ5E12, KQ6E6.
202 Dang NR, Moreau MJ, Hill DL . Intra-observer reproducibility and interobserver reliability of the radiographic parameters in the Spinal Deformity Study Group's AIS Radiographic Measurement Manual. Spine. 2005;309:1064-9. PMID: 15864160. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.15864160
203 Danielsson AJ, Hasserius R, Ohlin A . A prospective study of brace treatment versus observation alone in adolescent idiopathic scoliosis: a follow-up mean of 16 years after maturity. Spine (03622436). 2007;3220:2198-2207. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
204 Danielsson AJ, Nachemson AL. Back pain and function 23 years after fusion for adolescent idiopathic scoliosis: a case-control study -- part II. Spine (03622436). 2003;2818:E373-83 1p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E9b, KQ5E12, KQ6E9.
205 Danielsson AJ, Nachemson AL. Back pain and function 23 years after fusion for adolescent idiopathic scoliosis: a case-control study-part II. Spine. 2003;2818:E373-83. PMID: 14501939. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.14501939
206 Danielsson AJ, Nachemson AL. Radiologic findings and curve progression 22 years after treatment for adolescent idiopathic scoliosis: comparison of brace and surgical treatment with matching control group of straight individuals. Spine (Phila Pa 1976). 2001;265:516-25. PMID: 11242379. KQ1E12, KQ2E12, KQ3E9, KQ4E6a, KQ5E12, KQ6E9.11242379
207 Danielsson AJ, Romberg K, Nachemson AL. Spinal range of motion, muscle endurance, and back pain and function at least 20 years after fusion or brace treatment for adolescent idiopathic scoliosis: a case-control study. Spine (03622436). 2006;313:275-283 9p. PMID: 106432972. KQ1E12, KQ2E12, KQ3E9, KQ4E6, KQ5E12, KQ6E9.
208 Danielsson AJ. What impact does spinal deformity correction for adolescent idiopathic scoliosis make on quality of life?. Spine (03622436). 2007;3219:S101-8 1p. PMID: 0. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
209 Daruwalla JS, Balasubramaniam P. Moire topography in scoliosis. Its accuracy in detecting the site and size of the curve. Journal of Bone & Joint Surgery - British Volume. 1985;672:211-3. PMID: 3980527. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.3980527
210 Daruwalla JS. and Balasubramaniam P. and Chay SO. and Rajan U. and Lee HP. Idiopathic scoliosis. Prevalence and ethnic distribution in Singapore schoolchildren. J Bone Joint Surg Br. 1985;672:182-4. PMID: 3980521. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.3980521
211 Dastych M, Cienciala J. Idiopathic scoliosis and concentrations of zinc, copper, and selenium in blood plasma. Biological Trace Element Research. 2002;892:105-10. PMID: 12449234. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.12449234
212 Daubs Michael D, Hung Man,Neese Ashley,Hon Shirley D, Lawrence Brandon D . Scoliosis research society-22 results in 3052 healthy adolescents aged 10 to 19 years. Spine (03622436). 2014;3910:826-832 7p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
213 De Gauzy JS, Domenech P, Dupui P . Effect of bracing on postural balance in idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;880:239-40. PMID: 15456041. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15456041
214 De Giorgi S, Piazzolla A, Tafuri S . Cheneau brace for adolescent idiopathic scoliosis: long-term results. Can it prevent surgery?. European Spine Journal. 2013;0:S815-22. PMID: 24043341. KQ1E12, KQ2E12, KQ3E9, KQ4E9c, KQ5E12, KQ6E6.24043341
215 de Kleuver M, Lewis SJ, Germscheid NM . Optimal surgical care for adolescent idiopathic scoliosis: an international consensus. European Spine Journal. 2014;2312:2603-18. PMID: 24957258. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.24957258
216 De Korvin G, Randriaminahisoa T, Cugy E . Detection of progressive idiopathic scoliosis during growth using back surface topography: a prospective study of 100 patients. Annals of Physical & Rehabilitation Medicine. 2014;5742623:629-39. PMID: 25267453. KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.25267453
217 De la Garza Ramos R, Goodwin CR, Abu-Bonsrah N . Patient and operative factors associated with complications following adolescent idiopathic scoliosis surgery: an analysis of 36,335 patients from the Nationwide Inpatient Sample. Journal of Neurosurgery. 2016;0:42376. PMID: 27564784. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6d.27564784
218 de Mauroy JC, Lecante C, Barral F. ‘Brace Technology’ Thematic Series - The Lyon approach to the conservative treatment of scoliosis. Scoliosis. 2011;60:4. PMID: 21418597. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.21418597
219 De Mauroy JC, Pourret S, Barral F. Immediate in-brace correction with the new Lyon brace (ARTbrace): Results of 141 consecutive patients in accordance with SRS criteria for bracing studies. Annals of Physical & Rehabilitation Medicine. 2016;0:e32. PMID: 27676900. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
220 de Souza FI, Di Ferreira RB, Labres D . Epidemiology of adolescent idiopathic scoliosis in students of the public schools in Goiania-GO. Acta Ortopedica Brasileira. 2013;214:223-5. PMID: 24453673. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.24453673
221 De Wilde L, Plasschaert F, Cattoir H . Examination of the back using the Bunnell scoliometer in a Belgian school population around puberty. Acta Orthopaedica Belgica. 1998;642:136-43. PMID: 9689752. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.9689752
222 Dede Ozgur,Ward William Timothy,Bosch Patrick,Bowles Austin J, Roach James W. Using the freehand pedicle screw placement technique in adolescent idiopathic scoliosis surgery: what is the incidence of neurological symptoms secondary to misplaced screws?. Spine (03622436). 2014;394:286-290 5p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
223 De-Giorgio F, Arena V, Turturro F . 11 year-old girl undergoing scoliosis surgery. Brain Pathology. 2012;224:571-4. PMID: 22697383. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22697383
224 Deng M, Hui SC, Yu FW . MRI-based morphological evidence of spinal cord tethering predicts curve progression in adolescent idiopathic scoliosis. Spine Journal: Official Journal of the North American Spine Society. 2015;156:1391-401. PMID: 25725365. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.25725365
225 Dhuper S, Ehlers KH, Fatica NS . Incidence and risk factors for mitral valve prolapse in severe adolescent idiopathic scoliosis. Pediatric Cardiology. 1997;186:425-8. PMID: 9326688. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.9326688
226 Diab AA. The role of forward head correction in management of adolescent idiopathic scoliosis patients: a randomized controlled trial. D.C. Tracts. 2013;252:8-8 1p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
227 Diab Aliaa A. The role of forward head correction in management of adolescent idiopathic scoliotic patients: a randomized controlled trial. Clinical Rehabilitation. 2012;2612:1123-1132. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
228 Diab KM, Sevastik JA, Hedlund R . Accuracy and applicability of measurement of the scoliotic angle at the frontal plane by Cobb's method, by Ferguson's method and by a new method. European Spine Journal. 1995;45:291-5. PMID: 8581530. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.8581530
229 Diab M, Sharkey M, Emans J . Preoperative bracing affects postoperative outcome of posterior spine fusion with instrumentation for adolescent idiopathic scoliosis. Spine (03622436). 2010;3520:1876-1879. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
230 Diab M, Smith AR, Kuklo TR. Neural complications in the surgical treatment of adolescent idiopathic scoliosis. Spine (03622436). 2007;3224:2759-2763. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5a.
231 Dickson JH, Dericks GH, Rossi CD. Results in operated idiopathic scoliosis patients previously treated in the Milwaukee brace. Texas Medicine. 1981;778:45-7. PMID: 7268645. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7268645
232 Dickson JH. and Erwin WD. and Rossi D. Harrington instrumentation and arthrodesis for idiopathic scoliosis. A twenty-one-year follow-up. Journal of Bone & Joint Surgery - American Volume. 1990;725:678-83. PMID: 2141336. KQ1E12, KQ2E12, KQ3E9, KQ4E8, KQ5E12, KQ6E9.2141336
233 Dickson RA, Archer IA. Surgical treatment of late-onset idiopathic thoracic scoliosis. The Leeds procedure. Journal of Bone & Joint Surgery - British Volume. 1987;695:709-14. PMID: 3680329. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E6.3680329
234 Dickson RA, Stamper P, Ardran GM. A method for minimizing the radiation exposure from scoliosis radiographs. Journal of Bone & Joint Surgery - American Volume. 1981;639:1499-500. PMID: 7320045. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.7320045
235 Dickson RA, Stamper P, Sharp AM . School screening for scoliosis: cohort study of clinical course. British Medical Journal. 1980;2816235:265-7. PMID: 7427237. KQ1E6, KQ2E7e, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7427237
236 Dickson RA. Scoliosis in the community. British Medical Journal Clinical Research Ed.. 1983;2866365:615-8. PMID: 6402173. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.6402173
237 Dickson RA. and Leatherman KD. Cotrel traction, exercises, casting in the treatment of idiopathic scoliosis. A pilot study and prospective randomized controlled clinical trial. Acta Orthop Scand. 1978;491:46-8. PMID: 350002. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.350002
238 Dieck GS, Kelsey JL, Goel VK . An epidemiologic study of the relationship between postural asymmetry in the teen years and subsequent back and neck pain. Spine. 1985;1010:872-7. PMID: 2938272. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.2938272
239 Diefenbach Christopher and Lonner Baron S. and Auerbach Joshua D. and Bharucha Neil and Dean Laura E. Is radiation-free diagnostic monitoring of adolescent idiopathic scoliosis feasible using upright positional magnetic resonance imaging?. Spine (03622436). 2013;387:576-580 5p. PMID: . KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
240 Ding R, Liang J, Qiu G . Evaluation of quality of life in adolescent idiopathic scoliosis with different distal fusion level: a comparison of L3 versus L4. Journal of Spinal Disorders & Techniques. 2014;275:E155-61. PMID: 24513659. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.24513659
241 DiRaimondo CV. and Green NE. Brace-wear compliance in patients with adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 1988;82:143-6. PMID: 3350947. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.3350947
242 DiRocco PJ, Breed AL, Carlin JI . Physical work capacity in adolescent patients with mild idiopathic scoliosis. Archives of Physical Medicine & Rehabilitation. 1983;6410:476-8. PMID: 6625882. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.6625882
243 Divecha HM, Siddique I, Breakwell LM . Complications in spinal deformity surgery in the United Kingdom: 5-year results of the annual British Scoliosis Society National Audit of Morbidity and Mortality. European Spine Journal. 2014;0:S55-60. PMID: 24458937. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.24458937
244 Dobosiewicz K, Durmala J, Czernicki K . Pathomechanic basics of conservative treatment of progressive idiopathic scoliosis according to Dobosiewicz method based upon radiologic evaluation. Studies in Health Technology & Informatics. 2002;910:336-41. PMID: 15457751. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.15457751
245 Dobosiewicz K, Durmala J, Czernicki K . Radiological results of Dobosiewicz method of three-dimensional treatment of progressive idiopathic scoliosis. Studies in Health Technology & Informatics. 2006;1230:267-72. PMID: 17108438. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.17108438
246 Dobosiewicz K, Durmala J, Jendrzejek H . Influence of method of asymmetric trunk mobilization on shaping of a physiological thoracic kyphosis in children and youth suffering from progressive idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;910:348-51. PMID: 15457753. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15457753
247 Dobosiewicz K, Flak M, Durmala J . Tibial nerve somato-sensory evoked potentials in idiopathic scoliosis. Ortopedia Traumatologia Rehabilitacja. 2005;71:42596. PMID: 17675950. KQ1E12, KQ2E12, KQ3E1, KQ4E1, KQ5E12, KQ6E1.17675950
248 Dolan JA, MacEwen GD. Surgical treatment of scoliosis. Clinical Orthopaedics & Related Research. 1971;760:125-37. PMID: 4931055. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4931055
249 Dolan L, Weinstein S. Health, function, quality of life and self-esteem in AIS; preliminary results from BrAIST. Scoliosis. Conference: 11th International Conference on Conservative Management of Spinal Deformities - SOSORT 2014 Annual Meeting Germany. Conference Start: 20140508 Conference End: 20140510. 2014;90:. PMID: 0. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E6.
250 Dolan L, Weinstein S. To BrAIST or not to BrAIST: Decisions and characteristics of 1131 patients eligible for the Bracing in Adolescent Idiopathic Scoliosis Trial. Scoliosis. Conference: 8th International Conference on Conservative Management of Spinal Deformities - SOSORT 2011 Annual Meeting Spain. Conference Start: 20110519 Conference End: 20110521. 2012;70:. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.
251 Dolan LA, Donnelly MJ, Spratt KF . Professional opinion concerning the effectiveness of bracing relative to observation in adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 2007;273:270-6. PMID: 17414008. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.17414008
252 Dolan LA, Weinstein SL. Surgical rates after observation and bracing for adolescent idiopathic scoliosis: an evidence-based review. Spine (Phila Pa 1976). 2007;32:S91-S100. PMID: 17728687. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.17728687
253 Donaldson S, Stephens D, Howard A . Surgical decision making in adolescent idiopathic scoliosis. Spine (03622436). 2007;3214:1526-1532. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
254 Donnelly MJ, Dolan LA, Grande L . Patient and parent perspectives on treatment for adolescent idiopathic scoliosis. Iowa Orthopaedic Journal. 2004;240:76-83. PMID: 15296211. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15296211
255 Donzelli S, Zaina F, Lusini M . In favour of the definition ‘adolescents with idiopathic scoliosis’: juvenile and adolescent idiopathic scoliosis braced after ten years of age, do not show different end results. SOSORT award winner 2014. Scoliosis. 2014;90:7. PMID: 25031608. KQ1E12, KQ2E12, KQ3E6, KQ4E6b, KQ5E12, KQ6E6.25031608
256 Doody MM, Lonstein JE, Stovall M . Breast cancer mortality after diagnostic radiography: findings from the U.S. Scoliosis Cohort Study. Spine (03622436). 2000;2516:2052-2063. PMID: 0. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
257 Dos Santos Alves VL, Stirbulov R, Avanzi O. Long-term impact of pre-operative physical rehabilitation protocol on the 6-min walk test of patients with adolescent idiopathic scoliosis: A randomized clinical trial. Revista Portuguesa de Pneumologia. 2015;213:138-43. PMID: 25926252. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.25926252
258 Downey EF Jr, Butler P. Less radiation and better images: a new scoliosis radiography system. Military Medicine. 1984;1499:526-8. PMID: 6435022. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.6435022
259 Dreimann Marc,Hoffmann Michael,Kossow Kai,Hitzl Wolfgang,Meier Oliver,Koller Heiko Scoliosis and Chest Cage Deformity Measures Predicting Impairments in Pulmonary Function: A Cross-sectional Study of 492 Patients With Scoliosis to Improve the Early Identification of Patients at Risk. Spine (03622436). 2014;3924:2024-2033. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
260 Drummond D, Ranallo F, Lonstein J . Radiation hazards in scoliosis management. Spine. 1983;87:741-8. PMID: 6665576. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.6665576
261 Drummond DS, Rogala EJ. Growth and maturation of adolescents with idiopathic scoliosis. Spine. 1980;56:507-11. PMID: 7466459. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.7466459
262 Durham JW, Moskowitz A, Whitney J. Surface electrical stimulation versus brace in treatment of idiopathic scoliosis. Spine. 1990;159:888-92. PMID: 2259976. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.2259976
263 Durmala J, Blicharska I, Drosdzol-Cop A . The assessment of the sexual functioning in women with idiopathic scoliosis- preliminary study. Scoliosis. Conference: 11th International Conference on Conservative Management of Spinal Deformities - SOSORT 2014 Annual Meeting Germany. Conference Start: 20140508 Conference End: 20140510. 2014;90:. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E9, KQ5E12, KQ6E9.
264 Durmala J, Blicharska I, Drosdzol-Cop A . The Level of Self-Esteem and Sexual Functioning in Women with Idiopathic Scoliosis: A Preliminary Study. International Journal of Environmental Research & Public Health [Electronic Resource]. 2015;128:9444-53. PMID: 26274967. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.26274967
265 Durmala J,Dobosiewicz K,Jendrzejek H,Pius W Exercise efficiency of girls with idiopathic scoliosis based on the ventilatory anaerobic threshold. Studies in health technology and informatics. 2002;91:357-60. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15457755
266 Dutro CL, Keene KJ. Electrical muscle stimulation in the treatment of progressive adolescent idiopathic scoliosis: a literature review. Journal of Manipulative & Physiological Therapeutics. 1985;84:257-60. PMID: 3878386. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3878386
267 Dworkin B, Miller NE, Dworkin S . Behavioral method for the treatment of idiopathic scoliosis. Proceedings of the National Academy of Sciences of the United States of America. 1985;828:2493-7. PMID: 3857596. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.3857596
268 Dwyer AF, Newton NC, Sherwood AA. An anterior approach to scoliosis. A preliminary report. Clinical Orthopaedics & Related Research. 1969;620:192-202. PMID: 5774835. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5774835
269 Dwyer AF, Schafer MF. Anterior approach to scoliosis. Results of treatment in fifty-one cases. Journal of Bone & Joint Surgery - British Volume. 1974;562:218-24. PMID: 4850587. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4850587
270 Dykes MH, Fuller JE, Goldstein LA. Sudden cessation of cardiac output during spinal fusion. Anesthesia & Analgesia. 1970;494:596-9. PMID: 5534670. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5534670
271 Eastham RM An evaluation of stabilizing appliances for Milwaukee brace patients. American Journal of Orthodontics. 1971;605:445-77. PMID: 5286675. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.5286675
272 Edelmann P. Brace treatment in idiopathic scoliosis. Acta Orthopaedica Belgica. 1992;0:85-90. PMID: 1456024. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.1456024
273 Edgar MA. The natural history of unfused scoliosis. Orthopedics. 1987;106:931-9. PMID: 2956582. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.2956582
274 Edgar MA. and Mehta MH. Long-term follow-up of fused and unfused idiopathic scoliosis. J Bone Joint Surg Br. 1988;705:712-6. PMID: 3192566. KQ1E12, KQ2E12, KQ3E5, KQ4E5, KQ5E12, KQ6E5.3192566
275 Edmonsson AS, Morris JT. Follow-up study of Milwaukee brace treatment in patients with idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1977;0126:58-61. PMID: 598140. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.598140
276 Ehrmann Feldman D, Beausejour M, Sosa JF . Cost effectiveness of school screening for scoliosis: a systematic review. International Journal of Child and Adolescent Health. 2014;71:42564. PMID: 12014034399. KQ1E12, KQ2E9, KQ3E12, KQ4E12, KQ5E12, KQ6E12.
277 Eliason MJ, Richman LC. Psychological effects of idiopathic adolescent scoliosis. Journal of Developmental & Behavioral Pediatrics. 1984;54:169-72. PMID: 6470151. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.6470151
278 el-Sayyad M, Conine TA Effect of exercise, bracing and electrical surface stimulation on idiopathic scoliosis: a preliminary study. International journal of rehabilitation research. Internationale Zeitschrift für Rehabilitationsforschung. Revue internationale de recherches de réadaptation. 1994;171:70-4. PMID: 0. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E6.
279 Emans JB. Scoliosis: diagnosis and current treatment. Women & Health. 1984;942403:81-102. PMID: 6331686. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.6331686
280 Emans JB. and Kaelin A. and Bancel P. and Hall JE. and Miller ME. The Boston bracing system for idiopathic scoliosis. Follow-up results in 295 patients. Spine (Phila Pa 1976). 1986;118:792-801. PMID: 3810295. KQ1E12, KQ2E5, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3810295
281 Enwemeka CS. Physical deformities in Nigerian schools: the Port Harcourt Cohort study. International Journal of Rehabilitation Research. 1984;72:163-72. PMID: 6238005. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.6238005
282 Erken HY, Burc H, Saka G . Disagreements in surgical planning still exist between spinal surgeons in adolescent idiopathic scoliosis: a multisurgeon assessment. European Spine Journal. 2014;236:1258-62. PMID: 24664428. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.24664428
283 Ersberg Anna and Gerdhem Paul Pre- and postoperative quality of life in patients treated for scoliosis. Acta Orthopaedica. 2013;846:537-543 7p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
284 Escalada F, Marco E, Aguirrezabal A . Growth, maturity and prognosis of scoliosis. Maturity evaluation methods. Rehabilitacion. 2009;436:276-280 5p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E1, KQ5E12, KQ6E12.
285 Escalada F, Marco E, Duarte E . Growth and curve stabilization in girls with adolescent idiopathic scoliosis. Spine. 2005;304:411-7. PMID: 15706338. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.15706338
286 Escalada F. and Boza R. and Duarte E. and Tejero M. and Muniesa JM. and Guillen A. and Marco E. Menarche and the Risser sign in idiopathic scoliosis of the adolescent. Some critical considerations. Rehabilitacion. 2008;423:137-142 6p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E1, KQ5E12, KQ6E12.
287 Evaniew N, Devji T, Drew B . The surgical management of scoliosis: a scoping review of the literature. Scoliosis. 2015;101:1. PMID: 25628756. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.25628756
288 Fabry G, Cuyvers P, Mulier JC. Operative treatment of adolescent idiopathic scoliosis with follow-up study of the postoperative physical and social status. Archives of Orthopaedic & Traumatic Surgery. 1980;964:287-9. PMID: 7396674. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.7396674
289 Falk Bareket,Rigby WAlan,Akseer Nasreen Adolescent idiopathic scoliosis: the possible harm of bracing and the likely benefit of exercise. Spine Journal. 2015;156:1169-1171. PMID: . KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
290 Fallstrom K, Cochran T, Nachemson A. Long-term effects on personality development in patients with adolescent idiopathic scoliosis. Influence of type of treatment. Spine (Phila Pa 1976). 1986;117:756-8. PMID: 3787349. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.3787349
291 Fang MQ, Wang C, Xiang GH . Long-term effects of the Cheneau brace on coronal and sagittal alignment in adolescent idiopathic scoliosis. Journal of Neurosurgery Spine. 2015;234:505-9. PMID: 26161517. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6c.26161517
292 Federico DJ, Renshaw TS. Results of treatment of idiopathic scoliosis with the Charleston bending orthosis. Spine. 1990;159:886-7. PMID: 2259975. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.2259975
293 Fernandez-Feliberti R, Flynn J, Ramirez N . Effectiveness of TLSO bracing in the conservative treatment of idiopathic scoliosis. Journal of Pediatric Orthopedics. 1995;152:176-81. PMID: 7745089. KQ1E12, KQ2E12, KQ3E10, KQ4E12, KQ5E12, KQ6E6.7745089
294 Ferraro C,Masiero S,Venturin A,Pigatto M,Migliorino N Effect of exercise therapy on mild idiopathic scoliosis. Preliminary results. Europa Medicophysica. 1998;341:25-31. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
295 Ferris B, Edgar M, Leyshon A. Screening for scoliosis. Acta Orthop Scand. 1988;594:417-8. PMID: 3421079. KQ1E7a, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.3421079
296 Filipovic V, Viskic-Stalec N. The mobility capabilities of persons with adolescent idiopathic scoliosis. Spine (03622436). 2006;3119:2237-2242. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
297 Fishman LM, Groessl EJ, Sherman KJ. Serial case reporting yoga for idiopathic and degenerative scoliosis. Global Advances in Health & Medicine. 2014;35:16-21. PMID: 25568820. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.25568820
298 Fisk JR, Winter RB, Moe JH. The lumbosacral curve in idiopathic scoliosis. Its significance and management. Journal of Bone & Joint Surgery - American Volume. 1980;621:39-46. PMID: 7351414. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E5.7351414
299 Focarile FA, Bonaldi A, Giarolo MA . Effectiveness of nonsurgical treatment for idiopathic scoliosis. Overview of available evidence. Spine (Phila Pa 1976). 1991;164:395-401. PMID: 1828625. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.1828625
300 Fong DY, Lee CF, Cheung KM . A meta-analysis of the clinical effectiveness of school scoliosis screening. Spine (Phila Pa 1976). 2010;3510:1061-71. PMID: 20393399. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.20393399
301 Fong DYT. and Cheung KMC. and Wong YW. and Cheung WY. and Fu ICY. and Kuong EE. and Mak KC. and To M. and Samartzis D. and Luk KDK. An alternative to a randomised control design for assessing the efficacy and effectiveness of bracing in adolescent idiopathic scoliosis. Bone & Joint Journal. 2015;7:973-981 9p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
302 Fortin C, Feldman DE, Cheriet F . Validity of a quantitative clinical measurement tool of trunk posture in idiopathic scoliosis. Spine (03622436). 2010;3519:E988-94 1p. PMID: . KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
303 Freidel K, Reichel D, Steiner A . Idiopathic scoliosis and quality of life. Studies in Health Technology & Informatics. 2002;880:24-9. PMID: 15456000. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15456000
304 Friedman HG, Herbert MA, Bobechko WP. Electrical stimulation for scoliosis. Am Fam Physician. 1982;254:155-60. PMID: 6978055. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.6978055
305 Fu KM, Smith JS, Polly DW . Morbidity and mortality associated with spinal surgery in children: a review of the Scoliosis Research Society morbidity and mortality database. Journal of Neurosurgery. Pediatrics.. 2011;71:37-41. PMID: 21194285. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E5.21194285
306 Fuller JE, Banta JV, Foley LC . Scoliosis surgery: a risk factor for cholelithiasis?. Journal of Pediatric Orthopedics. 1994;145:576-9. PMID: 7962496. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7962496
307 Furgal M Mental health of adults treated in adolescence with scoliosis-specific exercise program or observed for idiopathic scoliosis. TheScientificWorldJournal. 2014;2014:932827. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
308 Fusco C. and Zaina F. and Atanasio S. and Romano M. and Negrini A. and Negrini S. Physical exercises in the treatment of adolescent idiopathic scoliosis: an updated systematic review. Physiotherapy Theory & Practice. 2011;271:80-114. PMID: 21198407. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21198407
309 Gabos PG, Bojescul JA, Bowen JR . Long-term follow-up of female patients with idiopathic scoliosis treated with the Wilmington orthosis. Journal of Bone & Joint Surgery - American Volume. 2004;9:1891-9. PMID: 15342750. KQ1E12, KQ2E12, KQ3E9c, KQ4E9b, KQ5E12, KQ6E6.15342750
310 Gaines DL. Current concepts of treatment of idiopathic scoliosis. Journal of the Tennessee Medical Association. 1971;6411:953-8. PMID: 5121182. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.5121182
311 Gaines RW, Leatherman KD. Benefits of the Harrington compression system in lumbar and thoracolumbar idiopathic scoliosis in adolescents and adults. Spine. 1981;65:483-8. PMID: 7302682. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7302682
312 Gaines RW, Min K, Zarzycki D ‘Bone-omicronn-Bone’ surgical reconstruction of moderate severity, flexible single curve adolescent idiopathic scoliosis: continuing improvements of the technique and results in three scoliosis centers after almost twenty years of use. Scoliosis. 2015;100:10. PMID: 26000031. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.26000031
313 Galasko CS. Progression of scoliosis. Journal of Pediatric Orthopedics. 1997;173:407. PMID: 9150034. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.9150034
314 Garg S, Kipper E, LaGreca J . Are routine postoperative radiographs necessary during the first year after posterior spinal fusion for idiopathic scoliosis? A retrospective cohort analysis of implant failure and surgery revision rates. Journal of Pediatric Orthopedics. 2015;351:33-8. PMID: 24840654. KQ1E12, KQ2E12, KQ3E6c, KQ4E12, KQ5E12, KQ6E6c.24840654
315 Gebhart Sandra and Alton Timothy B. and Bompadre Viviana and Krengel Walter F. Do anchor density or pedicle screw density correlate with short-term outcome measures in adolescent idiopathic scoliosis surgery?. Spine (03622436). 2014;392:E104-10 1p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
316 Ghandehari H, Mahabadi MA, Mahdavi SM . Evaluation of Patient Outcome and Satisfaction after Surgical Treatment of Adolescent Idiopathic Scoliosis Using Scoliosis Research Society-30. Archives of Bone & Joint Surgery. 2015;32:109-13. PMID: 26110177. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.26110177
317 Ghionzoli M, Martin A, Bongini M . Scoliosis and Pectus Excavatum in Adolescents: Does the Nuss Procedure Affect the Scoliotic Curvature?. Journal of Laparoendoscopic & Advanced Surgical Techniques. Part A. 2016;269:734-9. PMID: 27529379. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.27529379
318 Gitelman Y. and Lenke LG. and Bridwell KH. and Auerbach JD. and Sides BA. Pulmonary Function in Adolescent Idiopathic Scoliosis Relative to the Surgical Procedure: A 10-Year Follow-up Analysis. Spine (03622436). 2011;3620:1665-1672. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
319 Glowacki M, Misterska E, Adamczyk K . Changes in Scoliosis Patient and Parental Assessment of Mental Health in the Course of Cheneau Brace Treatment Based on the Strengths and Difficulties Questionnaire. J Dev Phys Disabil. 2013;253:325-342. PMID: 23667301. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23667301
320 Glowacki M, Misterska E, Adamczyk K . Prospective Assessment of Scoliosis-Related Anxiety and Impression of Trunk Deformity in Female Adolescents Under Brace Treatment. J Dev Phys Disabil. 2013;252:203-220. PMID: 23504280. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.23504280
321 Göcen S, Havitcioglu H. Effect of rotation on frontal plane deformity in idiopathic scoliosis. Orthopedics. 2001;243:265-268 4p. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
322 Goldberg C, Dowling FE, Fogarty EE . Electro-spinal stimulation in children with adolescent and juvenile scoliosis. Spine. 1988;135:482-4. PMID: 3263704. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3263704
323 Goldberg CJ, Dowling FE, Fogarty EE . Adolescent idiopathic scoliosis as developmental instability. Genetica. 1995;963:247-55. PMID: 8522164. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.8522164
324 Goldberg CJ, Dowling FE, Fogarty EE. Adolescent idiopathic scoliosis--early menarche, normal growth. Spine. 1993;185:529-35. PMID: 8484142. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.8484142
325 Goldberg CJ, Fogarty EE, Moore DP . Scoliosis and developmental theory: adolescent idiopathic scoliosis. Spine. 1997;2219:2228-37; d. PMID: 9346143. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.9346143
326 Goldberg CJ, Grove D, Moore DP . Surface topography and vectors: a new measure for the three dimensional quantification of scoliotic deformity. Studies in Health Technology & Informatics. 2006;1230:449-55. PMID: 17108467. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.17108467
327 Goldberg CJ, Moore DP, Fogarty EE . Adolescent idiopathic scoliosis: metric analysis of the deformity. Studies in Health Technology & Informatics. 2006;1230:109-16. PMID: 17108412. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.17108412
328 Goldberg CJ, Moore DP, Fogarty EE . Adolescent idiopathic scoliosis: natural history and prognosis. Studies in Health Technology & Informatics. 2002;910:59-63. PMID: 15457694. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15457694
329 Goldberg CJ, Moore DP, Fogarty EE . Handedness and spinal deformity. Studies in Health Technology & Informatics. 2006;1230:442-8. PMID: 17108466. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.17108466
330 Goldberg CJ,Moore DP,Fogarty EE,Dowling FE Adolescent idiopathic scoliosis: the effect of brace treatment on the incidence of surgery. Spine. 2001;261:42-47. PMID: .KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
331 Goldberg MS, Mayo NE, Poitras B . The Ste-Justine Adolescent Idiopathic Scoliosis Cohort Study. Part I: Description of the study. Spine (Phila Pa 1976). 1994;1914:1551-61. PMID: 7939991. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.7939991
332 Goldberg MS, Mayo NE, Poitras B . The Ste-Justine adolescent idiopathic scoliosis cohort study. Part II: perception of health, self and body image, and participation in physical activities. Spine (03622436). 1994;1914:1562-1572. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
333 Goldberg MS, Poitras B, Mayo NE . Observer variation in assessing spinal curvature and skeletal development in adolescent idiopathic scoliosis. Spine. 1988;1312:1371-7. PMID: 3212571. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.3212571
334 Goldstein LA, Evarts CM. Follow-up notes on articles previously published in the journal. Further experiences with the treatment of scoliosis by cast correction and spine fusion with fresh autogenous iliac-bone grafts. Journal of Bone & Joint Surgery - American Volume. 1966;485:962-6. PMID: 5328988. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5328988
335 Goldstein LA. Current and developing aspects in management of scoliosis. New York State Journal of Medicine. 1972;7224:2977-92. PMID: 4564506. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.4564506
336 Goldstein LA. The surgical management of scoliosis. Clinical Orthopaedics & Related Research. 1964;350:95-115. PMID: 4873305. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4873305
337 Goldstein LA. The surgical management of scoliosis. Clinical Orthopaedics & Related Research. 1971;770:32-56. PMID: 5140460. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.5140460
338 Goldstein LA. The surgical treatment of idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1973;093:131-57. PMID: 4722940. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4722940
339 González Viejo MA, Catalán Esparducer MJ. Comparative analysis with evidence available on the effectiveness of the CCR brace in combined idiopathic scoliosis. Rehabilitacion. 2000;344:299-305 7p. PMID: 107009877. KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
340 Goodbody CM, Asztalos IB, Sankar WN . It's not just the big kids: both high and low BMI impact bracing success for adolescent idiopathic scoliosis. Journal of Childrens Orthopaedics. 2016;105:395-404. PMID: 27501808. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.27501808
341 Goodbody CM, Sankar WN, Flynn JM Presentation of Adolescent Idiopathic Scoliosis: The Bigger the Kid, the Bigger the Curve. Journal of Pediatric Orthopedics. 2015;:. PMID: 26114242. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.26114242
342 Gore DR, Passehl R, Sepic S . Scoliosis screening: results of a community project. Pediatrics. 1981;672:196-200. PMID: 7243444. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7243444
343 Gorton GE 3rd and Young ML. and Masso PD. Accuracy, reliability, and validity of a 3-dimensional scanner for assessing torso shape in idiopathic scoliosis. Spine (03622436). 2012;3711:957-965 9p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
344 Gorzkowicz B, Kolban M, Szych Z. Assessment of quality of life in patients with idiopathic scoliosis treated operatively. Ortopedia Traumatologia Rehabilitacja. 2009;116:530-41. PMID: 20032529. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.20032529
345 Gotze C, Liljenqvist UR, Slomka A . Quality of life and back pain: outcome 16.7 years after Harrington instrumentation. Spine. 2002;2713:1456-63; d. PMID: 12131746. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.12131746
346 Goultidis TT, Papavasiliou KA, Petropoulos AS . Higher levels of melatonin in early stages of adolescent idiopathic scoliosis: toward a new scenario. Journal of Pediatric Orthopedics. 2014;348:768-73. PMID: 24787309. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24787309
347 Gratz RR. and Papalia-Finlay D. Psychosocial adaptation to wearing the Milwaukee brace for scoliosis. A pilot study of adolescent females and their mothers. J Adolesc Health Care. 1984;54:237-42. PMID: 6490478. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.6490478
348 Green Ne Part-time bracing of adolescent idiopathic scoliosis. Journal of Bone and Joint Surgery. 1986;685:738-42. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
349 Greggi T, Bakaloudis G, Fusaro I . Pulmonary function after thoracoplasty in the surgical treatment of adolescent idiopathic scoliosis. Journal of Spinal Disorders & Techniques. 2010;238:e63-9. PMID: 20625329. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E8.20625329
350 Grivas TB, Vasiliadis E, Savvidou OD . What a school screening program could contribute in clinical research of idiopathic scoliosis aetiology. Disability & Rehabilitation. 2008;3010:752-762 11. PMID: . KQ1E6, KQ2E5, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
351 Grivas TB, Vasiliadis ES, O'Brien J P. Suggestions for improvement of school screening for idiopathic scoliosis. Studies in Health Technology & Informatics. 2008;1400:245-8. PMID: 18810031. KQ1E9, KQ2E9, KQ3E12, KQ4E12, KQ5E9, KQ6E12.18810031
352 Grivas TB, Vasiliadis ES, O'Brien JP. How to improve the effectiveness of school screening for idiopathic scoliosis. Studies in Health Technology & Informatics. 2008;1350:115-21. PMID: 18401085. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.18401085
353 Grivas TB, Vasiliadis ES, Rodopoulos G . School screening as a research tool in epidemiology, natural history and aetiology of idiopathic scoliosis. Studies in Health Technology & Informatics. 2008;1350:84-93. PMID: 18401083. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.18401083
354 Grivas TB, Wade MH, Negrini S . SOSORT consensus paper: school screening for scoliosis. Where are we today?. Scoliosis. 2007;20:17. PMID: 18039374. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.18039374
355 Grosso C, Negrini S, Boniolo A . The validity of clinical examination in adolescent spinal deformities. Studies in Health Technology & Informatics. 2002;910:123-5. PMID: 15462010. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.15462010
356 Grouw AV, Nadel CI, Weierman RJ . Long term follow-up of patients with idiopathic scoliosis treated surgically: a preliminary subjective study. Clinical Orthopaedics & Related Research. 1976;0117:197-201. PMID: 1277665. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.1277665
357 Gruca A. On the pathology and treatment of ‘idiopathic’ scolioses. Acta Medica Polona. 1974;153:139-56. PMID: 4455034. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.4455034
358 Gu SX. and Zhu XD. and Wang CF. and Wu DJ. and Zhao YC. and Li M. Ritzman TF, Upasani VV, Bastrom TP, . Comparison of compensatory curve spontaneous derotation after selective thoracic or lumbar fusions in adolescent idiopathic scoliosis. Spine 2008;33:2643-7…Spine (Phila Pa 1976). 2008 Nov 15;33(24):2643-7. Spine (03622436). 2009;347:754-755 2p. PMID: . KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
359 Guay J, Haig M, Lortie L . Predicting blood loss in surgery for idiopathic scoliosis. Can J Anaesth. 1994;419:775-81. PMID: 7954993. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.7954993
360 Gunnoe BA. Adolescent idiopathic scoliosis. Orthopaedic Review. 1990;191:35-43. PMID: 2405336. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.2405336
361 Guo J, Lam TP, Wong MS . A prospective randomized controlled study on the treatment outcome of SpineCor brace versus rigid brace for adolescent idiopathic scoliosis with follow-up according to the SRS standardized criteria. European Spine Journal. 2014;2312:2650-7. PMID: 24378629. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.24378629
362 Guo J, Liu Z, Lv F . Pelvic tilt and trunk inclination: new predictive factors in curve progression during the Milwaukee bracing for adolescent idiopathic scoliosis. European Spine Journal. 2012;2110:2050-8. PMID: 22732829. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22732829
363 Guo J,Lam Tp,Wong Ms,Ng Bkw,Lee Km,Liu Kl,Hung Lh,Lau Ahy,Sin Sw,Kwok Wk,Yu Fwp,Qiu Y,Cheng Jcy A prospective randomized controlled study on the treatment outcome of SpineCor brace versus rigid brace for adolescent idiopathic scoliosis with follow-up according to the SRS standardized criteria. European Spine Journal. 2013;2312:2650-7. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
364 Guo X, Chau WW, Chan YL . Relative anterior spinal overgrowth in adolescent idiopathic scoliosis. Results of disproportionate endochondral-membranous bone growth. Journal of Bone & Joint Surgery - British Volume. 2003;857:1026-31. PMID: 14516040. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.14516040
365 Gur G, Ayhan C, Yakut Y. The effectiveness of core stabilization exercise in adolescent idiopathic scoliosis: A randomized controlled trial. Prosthetics & Orthotics International. 2016;13:13. PMID: 27625122. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.27625122
366 Gur G, Dilek B, Ayhan C . Effect of a spinal brace on postural control in different sensory conditions in adolescent idiopathic scoliosis: a preliminary analysis. Gait & posture. 2015;411:93-9. PMID: 25262334. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.25262334
367 Gurr JF. A school screening program that works. Canadian Nurse. 1977;7312:24-9. PMID: 589576. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.589576
368 Haefeli M, Elfering A, Kilian R . Nonoperative treatment for adolescent idiopathic scoliosis: a 10- to 60-year follow-up with special reference to health-related quality of life…including commentary by Noonan KJ. Spine (03622436). 2006;313:355-367 13. PMID: 106433030. KQ1E12, KQ2E12, KQ3E9, KQ4E6, KQ5E12, KQ6E6.
369 Haher TR, Gorup JM, Shin TM . Results of the Scoliosis Research Society instrument for evaluation of surgical outcome in adolescent idiopathic scoliosis: a multicenter study of 244 patients. Spine (03622436). 1999;2414:1435-1440. PMID: 107210257. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
370 Haher TR, Merola A, Zipnick RI . Meta-analysis of surgical outcome in adolescent idiopathic scoliosis. A 35-year English literature review of 11,000 patients. Spine. 1995;2014:1575-84. PMID: 7570172. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7570172
371 Hamill CL, Lenke LG, Bridwell KH . The use of pedicle screw fixation to improve correction in the lumbar spine of patients with idiopathic scoliosis. Is it warranted?. Spine. 1996;2110:1241-9. PMID: 8727200. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.8727200
372 Hamilton DK. and Smith JS. and Sansur CA. and Glassman SD. and Ames CP. and Berven SH. and Polly DW Jr. and Perra JH. and Knapp DR. and Boachie-Adjei O. and McCarthy RE. and Shaffrey CI. Rates of new neurological deficit associated with spine surgery based on 108,419 procedures: a report of the scoliosis research society morbidity and mortality committee. Spine (03622436). 2011;3615:1218-1228. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
373 Hammond KE, Dierckman BD, Burnworth L . Inter-observer and intra-observer reliability of the Risser sign in a metropolitan scoliosis screening program. Journal of Pediatric Orthopedics. 2011;318:e80-4. PMID: 22101671. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.22101671
374 Hanks GA, Zimmer B, Nogi J. TLSO treatment of idiopathic scoliosis. An analysis of the Wilmington jacket. Spine. 1988;136:626-9. PMID: 3175752. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.3175752
375 Harlin VK, Benson KD, Wade B . Results of school screening for scoliosis in the San Juan Unified School District, Sacramento, California. Journal of School Health. 1977;478:483-4. PMID: 243085. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.243085
376 Harrington PR, Dickson JH. An eleven-year clinical investigation of Harrington instrumentation. A preliminary report on 578 cases. Clinical Orthopaedics & Related Research. 1973;093:113-30. PMID: 4581508. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4581508
377 Hasler C, Schmid C, Enggist A . No effect of osteopathic treatment on trunk morphology and spine flexibility in young women with adolescent idiopathic scoliosis. Journal of Childrens Orthopaedics. 2010;43:219-26. PMID: 21629373. KQ1E12, KQ2E12, KQ3E6d, KQ4E12, KQ5E12, KQ6E6.21629373
378 Hasler CC. A brief overview of 100 years of history of surgical treatment for adolescent idiopathic scoliosis. Journal of Childrens Orthopaedics. 2013;71:57-62. PMID: 24432060. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.24432060
379 Hassan I, Bjerkreim I. Progression in idiopathic scoliosis after conservative treatment. Acta Orthop Scand. 1983;541:88-90. PMID: 6829286. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.6829286
380 Hausmann O, Min K, Boni T . SSEP analysis in surgery of idiopathic scoliosis: the influence of spine deformity and surgical approach. European Spine Journal. 2003;122:117-23. PMID: 12709848. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.12709848
381 Hausmann ON, Boni T, Pfirrmann CW . Preoperative radiological and electrophysiological evaluation in 100 adolescent idiopathic scoliosis patients. European Spine Journal. 2003;125:501-6. PMID: 12905054. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.12905054
382 Hawes MC, O'Brien JP. A century of spine surgery: what can patients expect?. Disability & Rehabilitation. 2008;3010:808-17. PMID: 18432439. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18432439
383 Hawes MC The use of exercises in the treatment of scoliosis: an evidence-based critical review of the literature. Pediatric Rehabilitation. 2003;642433:171-182 12. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
384 Hazebroek-Kampschreur AA, Hofman A, van Dijk AP . Prevalence of trunk abnormalities in eleven-year-old schoolchildren in Rotterdam, The Netherlands. Journal of Pediatric Orthopedics. 1992;124:480-4. PMID: 1613091. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.1613091
385 He JW. and Yan ZH. and Liu J. and Yu ZK. and Wang XY. and Bai GH. and Ye XJ. and Zhang X. Accuracy and repeatability of a new method for measuring scoliosis curvature. Spine (03622436). 2009;349:E323-9 1p. PMID: . KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.
386 Heckman Schatzinger LA, Nash CL Jr . Emotional adjustment in scoliosis. Clinical Orthopaedics & Related Research. 1977;0125:145-50. PMID: 880756. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.880756
387 Heilbronner DM, Sussman MD. Early mobilization of adolescent scoliosis patients following Wisconsin interspinous segmental instrumentation as an adjunct to Harrington distraction instrumentation. Preliminary report. Clinical Orthopaedics & Related Research. 1988;0229:52-8. PMID: 3349691. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8a.3349691
388 Helenius I, Remes V, Yrjonen T . Does gender affect outcome of surgery in adolescent idiopathic scoliosis?. Spine. 2005;304:462-7. PMID: 15706345. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15706345
389 Henderson MH Jr, Rieger MA . Influence of parental age on degree of curvature in idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1990;726:910-3. PMID: 2365723. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.2365723
390 Hengwei F, Zifang H, Qifei W . Prevalence of Idiopathic Scoliosis in Chinese Schoolchildren: A Large, Population-Based Study. Spine. 2016;413:259-64. PMID: 26866739. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.26866739
391 Herbert MA, Bobechko WP. Scoliosis treatment in children using a programmable, totally implantable muscle stimulator (ESI). IEEE Transactions on Biomedical Engineering. 1989;367:801-2. PMID: 2787288. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.2787288
392 Herbert R. Commentary to: Effect of Schroth exercises on curve characteristics and clinical outcomes in adolescent idiopathic scoliosis: protocol for a multicentre randomised controlled trial. Journal of Physiotherapy. 2014;604:234. PMID: 27373525. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.27373525
393 Hicks JM. and Singla A. and Shen FH. and Arlet V. Complications of pedicle screw fixation in scoliosis surgery: a systematic review. Spine (Phila Pa 1976). 2010;3511:E465-70. PMID: 20473117. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.20473117
394 Hilibrand AS, Tannenbaum DA, Graziano GP . The sagittal alignment of the cervical spine in adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 1995;155:627-32. PMID: 7593575. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7593575
395 Hill D, Raso VJ, Moreau K . Long-term follow-up of surgically treated AIS patients. Studies in Health Technology & Informatics. 2002;910:477-80. PMID: 15457781. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.15457781
396 Himmetoglu S, Guven MF, Bilsel N . DNA damage in children with scoliosis following X-ray exposure. Minerva Pediatrica. 2015;673:245-9. PMID: 25941131. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E4, KQ6E12.25941131
397 Hines Tabatha,Roland Sandy,Nguyen Dylan,Kennard Beth,Richard Heather,Hughes Carroll W, McClintock Shawn M, Ramo Brandon,Herring Tony School Scoliosis Screenings: Family Experiences and Potential Anxiety After Orthopaedic Referral. Spine (03622436). 2015;4021:E1135-E114. PMID: 112569956. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E9, KQ6E12.
398 Hoffman DA, Lonstein JE, Morin MM . Breast cancer in women with scoliosis exposed to multiple diagnostic x rays. Journal of the National Cancer Institute. 1989;8117:1307-12. PMID: 2769783. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.2769783
399 Hokama A, Tomiyama R, Kishimoto K . Chronic intermittent vomiting after scoliosis surgery. Gut. 2005;542:222, 281. PMID: 15647185. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.15647185
400 Hong JY. and Suh SW. and Modi HN. and Hur CY. and Song HR. and Ryu JH. Centroid method: reliable method to determine the coronal curvature of scoliosis: a case control study comparing with the cobb method. Spine (03622436). 2011;3613:E855-61 1p. PMID: . KQ1E5, KQ2E7, KQ3E12, KQ4E12, KQ5E5, KQ6E12.
401 Hosman AJ, Slot GH, Beijneveld WJ . Correction of idiopathic scoliosis using the H-frame system. European Spine Journal. 1996;53:172-7. PMID: 8831119. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.8831119
402 Howard A, Donaldson S, Hedden D . Improvement in quality of life following surgery for adolescent idiopathic scoliosis. Spine (03622436). 2007;3224:2715-2718. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.
403 Hsu EY, Schwend RM, Julia L. How many referrals to a pediatric orthopaedic hospital specialty clinic are primary care problems?. Journal of Pediatric Orthopedics. 2012;327:732-6. PMID: 22955539. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.22955539
404 Hsu LC, Zucherman J, Tang SC . Dwyer instrumentation in the treatment of adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery - British Volume. 1982;645:536-41. PMID: 7142261. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7142261
405 Hughes Ls,Ebell Mh POEMs. Am Fam Physician. 2014;896:481. PMID: . KQ1E14, KQ2E14, KQ3E12, KQ4E12, KQ5E14, KQ6E12.
406 Hume K. Scoliosis: to screen or not to screen. British Journal of School Nursing. 2008;35:214-218 4p. PMID: . KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.
407 Humke T, Grob D, Scheier H . Cotrel-Dubousset and Harrington Instrumentation in idiopathic scoliosis: a comparison of long-term results. European Spine Journal. 1995;45:280-3. PMID: 8581528. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.8581528
408 Hundozi-Hysenaj H, Dallku IB, Murtezani A . Treatment of the idiopathic scoliosis with brace and physiotherapy. Nigerian Journal of Medicine: Journal of the National Association of Resident Doctors of Nigeria. 2009;183:256-9. PMID: 20120640. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.20120640
409 Hwang SW, Samdani AF, Lonner BS . A multicenter analysis of factors associated with change in height after adolescent idiopathic scoliosis deformity surgery in 447 patients. Journal of Neurosurgery Spine. 2013;183:298-302. PMID: 23330975. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.23330975
410 Hwang SW, Samdani AF, Stanton P . Impact of pedicle screw fixation on loss of deformity correction in patients with adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 2013;334:377-82. PMID: 23653025. KQ1E12, KQ2E12, KQ3E9, KQ4E6a, KQ5E12, KQ6E9.23653025
411 Hyndman JC, Christie WH. Scoliosis: facts and fiction for the family physician. Canadian Family Physician. 1975;219:92-4. PMID: 20469235. KQ1E2, KQ2E2, KQ3E2, KQ4E12, KQ5E2, KQ6E2.20469235
412 Hyun SJ, Kim WB, Park YS . Adolescent Idiopathic Scoliosis Treatment by a Korean Neurosurgeon: The Changing Role for Neurosurgeons. Journal of Korean Neurosurgical Society. 2015;581:50-3. PMID: 26279813. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8.26279813
413 Inoue M. and Minami S. and Kitahara H. and Otsuka Y. and Nakata Y. and Takaso M. and Moriya H. Idiopathic scoliosis in twins studied by DNA fingerprinting: the incidence and type of scoliosis. J Bone Joint Surg Br. 1998;802:212-7. PMID: 9546446. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.9546446
414 Jackson RP, Simmons EH, Stripinis D. Incidence and severity of back pain in adult idiopathic scoliosis. Spine. 1983;87:749-56. PMID: 6229884. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.6229884
415 Jain Amit,Karas Dominique J, Skolasky Richard L, Sponseller Paul D. Thromboembolic complications in children after spinal fusion surgery. Spine (03622436). 2014;3916:1325-1329. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
416 Jain Amit,Puvanesarajah Varun,Menga Emmanuel N, Sponseller Paul D. Unplanned Hospital Readmissions and Reoperations After Pediatric Spinal Fusion Surgery. Spine (03622436). 2015;4011:856-862 7p. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
417 Janicki Ja, Poe-Kochert C, Armstrong Dg, Thompson Gh A comparison of the thoracolumbosacral orthoses and providence orthosis in the treatment of adolescent idiopathic scoliosis: results using the new SRS inclusion and assessment criteria for bracing studies. Journal of Pediatric Orthopedics. 2007;274:369-74. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
418 Jaremko JL,Poncet P,Ronsky J . Comparison of Cobb angles measured manually, calculated from 3-D spinal reconstruction, and estimated from torso asymmetry. Computer Methods in Biomechanics & Biomedical Engineering. 2002;54:277-81. PMID: 12186706. KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.12186706
419 Jaremko JL, Poncet P, Ronsky J . Indices of torso asymmetry related to spinal deformity in scoliosis. Clinical Biomechanics. 2002;178:559-68. PMID: 12243715. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.12243715
420 Jarvis JG, Greene RN. Adolescent idiopathic scoliosis. Correction of vertebral rotation with use of Wisconsin segmental spinal instrumentation. Journal of Bone & Joint Surgery - American Volume. 1996;7811:1707-12. PMID: 8934486. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.8934486
421 Jeng CL. and Sponseller PD. and Tolo VT. Outcome of Wisconsin instrumentation in idiopathic scoliosis. Minimum 5-year follow-up. Spine (Phila Pa 1976). 1993;1812:1584-90. PMID: 8235835. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.8235835
422 Jensen GM, Wilson KB. Horizontal postrotatory nystagmus response in female subjects with adolescent idiopathic scoliosis. Physical Therapy. 1979;5910:1226-33. PMID: 315073. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.315073
423 Jenyo MS, Asekun-Olarinmoye EO. Prevalence of scoliosis in secondary school children in Osogbo, Osun State, Nigeria. African Journal of Medicine & Medical Sciences. 2005;344:361-4. PMID: 16752666. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.16752666
424 Ji XR, Yang ZD, Yang XH . Change of selenium in environment and risk of adolescent idiopathic scoliosis: a retrospective cohort study. European Review for Medical & Pharmacological Sciences. 2013;1718:2499-503. PMID: 24089230. KQ1E12, KQ2E12, KQ3E12, KQ4E4, KQ5E12, KQ6E12.24089230
425 Johnson JP, Daniels AH, Grabel ZJ . Referral for Adolescent Idiopathic Scoliosis by Pediatric Primary Care Providers. Clin Pediatr (Phila). 2016;:. PMID: 27412803. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.27412803
426 Jones JS, Cotugno RE, Singhal NR . Evaluation of dexmedetomidine and postoperative pain management in patients with adolescent idiopathic scoliosis: conclusions based on a retrospective study at a tertiary pediatric hospital. Pediatric Critical Care Medicine. 2014;156:e247-52. PMID: 24743445. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.24743445
427 Kafer ER. Respiratory and cardiovascular functions in scoliosis. Bulletin Europeen de Physiopathologie Respiratoire. 1977;132:299-321. PMID: 324540. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.324540
428 Kager AN, Marks M, Bastrom T . Morbidity of iliac crest bone graft harvesting in adolescent deformity surgery. Journal of Pediatric Orthopedics. 2006;261:132-4. PMID: 16439918. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E6.16439918
429 Kahanovitz N, Levine DB, Lardone J. The part-time Milwaukee brace treatment of juvenile idiopathic scoliosis. Long-term follow-up. Clinical Orthopaedics & Related Research. 1982;0167:145-51. PMID: 7094456. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7094456
430 Kahanovitz N, Weiser S. Lateral electrical surface stimulation (LESS) compliance in adolescent female scoliosis patients. Spine. 1986;117:753-5. PMID: 3491431. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.3491431
431 Kahanovitz N, Weiser S. The psychological impact of idiopathic scoliosis on the adolescent female. A preliminary multi-center study. Spine. 1989;145:483-5. PMID: 2658124. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.2658124
432 Kane WJ, Brown JC, Hensinger RN . Scoliosis and school screening for spinal deformity. Am Fam Physician. 1978;175:123-7. PMID: 655064. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.655064
433 Kane WJ. Scoliosis prevalence: a call for a statement of terms. Clin Orthop Relat Res. 1977;126:43-6. PMID: 598138. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.598138
434 Karol LA, Johnston CE2nd,Browne RH . Progression of the curve in boys who have idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1993;7512:1804-10. PMID: 8258551. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.8258551
435 Karol LA, Virostek D, Felton K . The Effect of the Risser Stage on Bracing Outcome in Adolescent Idiopathic Scoliosis. Journal of Bone & Joint Surgery - American Volume. 2016;9815:1253-9. PMID: 27489315. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c, KQ6E9c.27489315
436 Karol LA. Effectiveness of bracing in male patients with idiopathic scoliosis. Spine (03622436). 2001;2618:2001-2005. PMID: 0. KQ1E12, KQ2E12, KQ3E9c, KQ4E6a, KQ5E12, KQ6E6.
437 Kasper MJ, Robbins L, Root L . A musculoskeletal outreach screening, treatment, and education program for urban minority children. Arthritis Care & Research (08937524). 1993;63:126-133 8p. PMID: 0. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
438 Kasper MJ. Outcomes of a musculoskeletal outreach screening, treatment and education program for urban minority children. 1992;0:115 p-115. PMID: . KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.
439 Katsaris G,Loukos A,Valavanis J,Vassiliou M,Behrakis Pk The immediate effect of a Boston brace on lung volumes and pulmonary compliance in mild adolescent idiopathic scoliosis. European Spine Journal. 1999;81:42407. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
440 Katz DE, Durrani AA. Factors that influence outcome in bracing large curves in patients with adolescent idiopathic scoliosis. Spine (03622436). 2001;2621:2354-2361. PMID: 0. KQ1E12, KQ2E12, KQ3E9c, KQ4E6, KQ5E12, KQ6E6.
441 Katz DE, Herring JA, Browne RH . Brace wear control of curve progression in adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery, American Volume. 2010;6:1343-1352. PMID: . KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.
442 Kearon C, Viviani GR, Kirkley A . Factors determining pulmonary function in adolescent idiopathic thoracic scoliosis. American Review of Respiratory Disease. 1993;1482:288-94. PMID: 8342890. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.8342890
443 Keiser RP, Shufflebarger HL. The Milwaukee brace in idiopathic scoliosis: evaluation of 123 completed cases. Clinical Orthopaedics & Related Research. 1976;0118:19-24. PMID: 954276. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.954276
444 Keller RB. Nonoperative treatment of adolescent idiopathic scoliosis. Instr Course Lect. 1989;380:129-35. PMID: 2649565. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.2649565
445 Kelly DM. and McCarthy RE. and McCullough FL. and Kelly HR. Long-term Outcomes of Anterior Spinal Fusion With Instrumentation for Thoracolumbar and Lumbar Curves in Adolescent Idiopathic Scoliosis. Spine (03622436). 2010;352:194-198 5p. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
446 Kennedy JD, Robertson CF, Hudson I . Effect of bracing on respiratory mechanics in mild idiopathic scoliosis. Thorax. 1989;447:548-53. PMID: 2772855. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.2772855
447 Kennedy JD, Robertson CF, Olinsky A . Pulmonary restrictive effect of bracing in mild idiopathic scoliosis. Thorax. 1987;4212:959-61. PMID: 3438884. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3438884
448 Kesling KL, Lonstein JE, Denis F . The crankshaft phenomenon after posterior spinal arthrodesis for congenital scoliosis: a review of 54 patients. Spine. 2003;283:267-71. PMID: 12567029. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.12567029
449 Kibsgard T, Brox JI, Reikeras O Physical and mental health in young adults operated on for idiopathic scoliosis. Journal of Orthopaedic Science. 2004;94:360-3. PMID: 15278773. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.15278773
450 Kinel E, Kotwicki T, Podolska A . Quality of life and stress level in adolescents with idiopathic scoliosis subjected to conservative treatment. Studies in Health Technology & Informatics. 2012;1760:419-22. PMID: 22744544. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.22744544
451 Kinnear WJ, Kinnear GC, Watson L . Pulmonary function after spinal surgery for idiopathic scoliosis. Spine. 1992;176:708-13. PMID: 1626305. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.1626305
452 Kinnear WJ. and Johnston ID. Does Harrington instrumentation improve pulmonary function in adolescents with idiopathic scoliosis? A meta-analysis. Spine (Phila Pa 1976). 1993;1811:1556-9. PMID: 8235829. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.8235829
453 Klemme WR, Denis F, Winter RB . Spinal instrumentation without fusion for progressive scoliosis in young children. Journal of Pediatric Orthopedics. 1997;176:734-42. PMID: 9591974. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.9591974
454 Knapp DR Jr, Jones ET . Allograft bone in spinal fusion for adolescent idiopathic scoliosis. Journal of Spinal Disorders & Techniques. 2005;0:S73-6. PMID: 15699809. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15699809
455 Koch KD, Buchanan R, Birch JG . Adolescents undergoing surgery for idiopathic scoliosis: how physical and psychological characteristics relate to patient satisfaction with the cosmetic result. Spine (03622436). 2001;2619:2119-2124. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.
456 Kogutt MS, Warren FH, Kalmar JA. Low dose imaging of scoliosis: use of a computed radiographic imaging system. Pediatric Radiology. 1989;2042371:85-6. PMID: 2602023. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.2602023
457 Koh KT, Low BY, Balachandran N. Idiopathic scoliosis--treatment by pre-operative Risser's localiser cast followed by Harrington rodding and posterior spinal fusion. Singapore Medical Journal. 1988;293:219-21. PMID: 3187572. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3187572
458 Kohler R, Galland O, Mechin H . The Dwyer procedure in the treatment of idiopathic scoliosis. A 10-year follow-up review of 21 patients. Spine. 1990;152:75-80. PMID: 2326715. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8.2326715
459 Koller H. and Zenner J. and Hitzl W. and Meier O. and Ferraris L. and Acosta F. and Hempfing A. The morbidity of open transthoracic approach for anterior scoliosis correction. Spine (03622436). 2010;3526:E1586-92 1. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
460 Kondratek M, Ponners D. Commentary on ‘Spinal Stabilization Exercise Effectiveness for Low Back Pain in Adolescent Idiopathic Scoliosis: A Randomized Trial’. Pediatric Physical Therapy. 2015;274:402. PMID: 26397086. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.26397086
461 Korbel K, Kozinoga M, Stolinski L . Scoliosis Research Society (SRS) Criteria and Society of Scoliosis Orthopaedic and Rehabilitation Treatment (SOSORT) 2008 Guidelines in Non-Operative Treatment of Idiopathic Scoliosis. Polish Orthopedics & Traumatology. 2014;790:118-22. PMID: 25066033. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.25066033
462 Kornberg M, Herndon WA, Rechtine GR. Lumbar nerve root compression at the site of hook insertion. Late complication of Harrington rod instrumentation for scoliosis. Spine. 1985;109:853-5. PMID: 2935952. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.2935952
463 Korovessis P, Filos KS, Zielke K. Effects of the combined VDS-Zielke and Harrington operation on the frontal rib cage deformity of double major curves in idiopathic scoliosis. Spine. 1995;209:1061-7. PMID: 7631236. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.7631236
464 Korovessis P, Iliopoulos P, Koureas G . Evolution of anterior chest wall blood supply in female adolescents with progressive right-convex thoracic idiopathic scoliosis. Journal of Spinal Disorders & Techniques. 2007;203:190-4. PMID: 17473637. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.17473637
465 Korovessis P, Kyrkos C, Piperos G . Effects of thoracolumbosacral orthosis on spinal deformities, trunk asymmetry, and frontal lower rib cage in adolescent idiopathic scoliosis. Spine. 2000;2516:2064-71. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
466 Korovessis P, Stamatakis M, Baikousis A . Vertical transmission of the hip rolls due to wearing of TLSO for scoliosis. J Spinal Disord. 1996;94:326-33. PMID: 8877961. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.8877961
467 Korovessis P, Zacharatos S, Koureas G . Comparative multifactorial analysis of the effects of idiopathic adolescent scoliosis and Scheuermann kyphosis on the self-perceived health status of adolescents treated with brace. European Spine Journal. 2007;164:537-46. PMID: 16953447. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.16953447
468 Korovessis P. Sagittal plane analysis of adolescent idiopathic scoliosis. The effect of anterior versus posterior instrumentation. Spine. 2003;2814:1624-5; au. PMID: 12865858. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.12865858
469 Korovessis P. and Filos KS. and Georgopoulos D. Long-term alterations of respiratory function in adolescents wearing a brace for idiopathic scoliosis. Spine (03622436). 1996;2117:1979-1984. PMID: 107312052. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
470 Korovessis PG, Stamatakis MV. Prediction of scoliotic cobb angle with the use of the scoliometer.[Erratum appears in Spine (Phila Pa 1976). 1997 Apr 15;22(8):926; PMID: 9127930]. Spine. 1996;2114:1661-6. PMID: 8839469. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.8839469
471 Kotwicki T, Chowanska J, Kinel E . Optimal management of idiopathic scoliosis in adolescence. Adolescent Health Medicine & Therapeutics. 2013;40:59-73. PMID: 24600296. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.24600296
472 Koukourakis I. and Giaourakis G. and Kouvidis G. and Kivernitakis E. and Blazos J. and Koukourakis M. Screening school children for scoliosis on the island of Crete. J Spinal Disord. 1997;106:527-31. PMID: 9438820. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.9438820
473 Kuklo TR, Lehman RA Jr . Structures at risk following anterior instrumented spinal fusion for thoracic adolescent idiopathic scoliosis. Journal of Spinal Disorders & Techniques. 2005;0:S58-64. PMID: 15699806. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.15699806
474 Kumano K, Miyashita H, Tanaka T . Energy expenditure during exercise on a treadmill before and after surgical correction of spinal deformities. Nippon Seikeigeka Gakkai Zasshi - Journal of the Japanese Orthopaedic Association. 1986;604:439-48. PMID: 3734529. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3734529
475 Kumano K, Tsuyama N. Pulmonary function before and after surgical correction of scoliosis. Journal of Bone & Joint Surgery - American Volume. 1982;642:242-8. PMID: 7056779. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7056779
476 Kumano K,Maruyama T,Kojima T,Kondoh Y,Shimode M Results of wearing Milwaukee brace at night for adolescent idiopathic scoliosis. Journal of the Western Pacific Orthopaedic Association. 1992;292:53-7. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
477 Kuroki H, Inomata N, Hamanaka H . Efficacy of the Osaka Medical College (OMC) brace in the treatment of adolescent idiopathic scoliosis following Scoliosis Research Society brace studies criteria. Scoliosis. 2015;100:12. PMID: 25932040. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.25932040
478 Kuroki H,Inomata N,Hamanaka H,Higa K,Chosa E,Tajima N Predictive factors of Osaka Medical College (OMC) brace treatment in patients with adolescent idiopathic scoliosis. Scoliosis. 2015;101:. PMID: 0. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E6.
479 Kuru T, Yeldan I, Dereli EE . The efficacy of three-dimensional Schroth exercises in adolescent idiopathic scoliosis: A randomised controlled clinical trial. Clin Rehabil. 2015;:. PMID: 25780260. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.25780260
480 Kusakabe T and Mehta JS. and Gaines RW.. Short segment bone-on-bone instrumentation for adolescent idiopathic scoliosis: a mean follow-up of six years. Spine (03622436). 2011;3614:1123-1130. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
481 Kwan MK, Chiu CK, Gani SM . Accuracy and Safety of Pedicle Screw Placement in Adolescent Idiopathic Scoliosis (AIS) Patients: A Review of 2020 Screws Using Computed Tomography Assessment. Spine. 2016;15:15. PMID: 27310021. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.27310021
482 Kwiatkowski M, Mnich K, Karpinski M . Assessment of Idiopathic Scoliosis Patients' Satisfaction with Thoracolumbar Brace Treatment. Ortopedia Traumatologia Rehabilitacja. 2015;172:111-9. PMID: 26248755. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.26248755
483 Labelle H, Dansereau J, Bellefleur C . Peroperative three-dimensional correction of idiopathic scoliosis with the Cotrel-Dubousset procedure. Spine. 1995;2012:1406-9. PMID: 7676340. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7676340
484 Labelle H, Richards SB, De Kleuver M . Screening for adolescent idiopathic scoliosis: an information statement by the scoliosis research society international task force. Scoliosis. 2013;8:17. PMID: 24171910. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.24171910
485 Lai S, Asher M, Burton D. Estimating SRS-22 quality of life measures with SF-36: application in idiopathic scoliosis. Spine (03622436). 2006;314:473-478 6p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
486 Laituri CA, Schwend RM, Holcomb GW . Thoracoscopic vertebral body stapling for treatment of scoliosis in young children. Journal of Laparoendoscopic & Advanced Surgical Techniques. Part A. 2012;228:830-3. PMID: 23039706. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.23039706
487 Lam TP, Hung VW, Yeung HY . Quantitative ultrasound for predicting curve progression in adolescent idiopathic scoliosis: a prospective cohort study of 294 cases followed-up beyond skeletal maturity. Ultrasound in Medicine & Biology. 2013;393:381-7. PMID: 23245828. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.23245828
488 Lamerain M, Bachy M, Delpont M . CoCr rods provide better frontal correction of adolescent idiopathic scoliosis treated by all-pedicle screw fixation. European Spine Journal. 2014;236:1190-6. PMID: 24448894. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.24448894
489 LaMontagne LL, Hepworth JT, Cohen F . Adolescent scoliosis: effects of corrective surgery, cognitive-behavioral interventions, and age on activity outcomes. Applied Nursing Research. 2004;173:168-177 10. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
490 Landauer F, Wimmer C, Behensky H. Estimating the final outcome of brace treatment for idiopathic thoracic scoliosis at 6-month follow-up. Pediatric Rehabilitation. 2003;642433:201-207 7p. PMID: 0. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E6.
491 Landman Z, Oswald T, Sanders J . Prevalence and predictors of pain in surgical treatment of adolescent idiopathic scoliosis. Spine (03622436). 2011;3610:825-829 5p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
492 Lange JE, Steen H, Brox JI. Long-term results after Boston brace treatment in adolescent idiopathic scoliosis. Scoliosis. 2009;40:17. PMID: 19709435. KQ1E12, KQ2E12, KQ3E9, KQ4E9c, KQ5E12, KQ6E9.19709435
493 Lange JE, Steen H, Gunderson R . Long-term results after Boston brace treatment in late-onset juvenile and adolescent idiopathic scoliosis. Scoliosis. 2011;60:18. PMID: 21880123. KQ1E12, KQ2E12, KQ3E9, KQ4E6, KQ5E12, KQ6E9.21880123
494 Lantz CA, Chen J. Effect of chiropractic intervention on small scoliotic curves in younger subjects: a time-series cohort design. Journal of Manipulative & Physiological Therapeutics. 2001;246:385-393 9p. PMID: 0. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.
495 Lapinksy AS, Richards BS. Preventing the crankshaft phenomenon by combining anterior fusion with posterior instrumentation. Does it work?. Spine. 1995;2012:1392-8. PMID: 7676338. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7676338
496 Lapuente Jp,Sastre S,Barrios C Idiopathic scoliosis under 30 degrees in growing patients. A comparative study of the F.E.D. method and other conservative treatments. Studies in health technology and informatics. 2002;88:258-69. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15456046
497 Larson AN, Fletcher ND, Daniel C . Lumbar Curve Is Stable After Selective Thoracic Fusion for Adolescent Idiopathic Scoliosis: A 20-Year Follow-up. Spine (03622436). 2012;3710:833-839 7p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
498 Laulund T, Sojbjerg JO, Horlyck E. Moire topography in school screening for structural scoliosis. Acta Orthop Scand. 1982;535:765-8. PMID: 7136586. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7136586
499 Lavelle WF, Samdani AF, Cahill PJ . Clinical outcomes of nitinol staples for preventing curve progression in idiopathic scoliosis. Journal of Pediatric Orthopedics. 2011;31:S107-13. PMID: 21173612. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.21173612
500 Leaver JM, Alvik A, Warren MD. Prescriptive screening for adolescent idiopathic scoliosis: a review of the evidence. International Journal of Epidemiology. 1982;112:101-11. PMID: 7047422. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.7047422
501 Lebel DE, Al-Aubaidi Z, Shin EJ . Three dimensional analysis of brace biomechanical efficacy for patients with AIS. European Spine Journal. 2013;2211:2445-8. PMID: 23873054. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.23873054
502 Ledonio CG. and Polly DW. and Vitale MG. and Wang Q. and Richards BS. Pediatric pedicle screws: comparative effectiveness and safety: a systematic literature review from the scoliosis research society and the pediatric orthopaedic society of north america task force. Journal of Bone & Joint Surgery, American Volume. 2011;13:1227-1234. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
503 Lee CS, Hwang CJ, Kim DJ . Effectiveness of the Charleston night-time bending brace in the treatment of adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 2012;324:368-72. PMID: 22584837. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22584837
504 Lee CS, Nachemson AL. The crankshaft phenomenon after posterior Harrington fusion in skeletally immature patients with thoracic or thoracolumbar idiopathic scoliosis followed to maturity. Spine. 1997;221:58-67. PMID: 9122783. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.9122783
505 Lee DK, Chun EM, Suh SW . Evaluation of postoperative change in lung volume in adolescent idiopathic scoliosis: Measured by computed tomography. Indian Journal of Orthopaedics. 2014;484:360-5. PMID: 25143638. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6d.25143638
506 Lee JZ, Lam DJ, Lim KB. Late presentation in adolescent idiopathic scoliosis: who, why, and how often?. Journal of Pediatric Orthopaedics, Part B. 2014;231:42535. PMID: 24201070. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24201070
507 Lee Mark C. and Ounpuu Sylvia and Solomito Matthew and Smith Brian G. and Thomson Jeffrey D. Loss in spinal motion from inclusion of a single midlumbar level in posterior spinal fusion for adolescent idiopathic scoliosis. Spine (03622436). 2013;3822:E1405-10 1. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
508 Lee WT, Cheung CS, Tse YK . Association of osteopenia with curve severity in adolescent idiopathic scoliosis: a study of 919 girls. Osteoporosis International. 2005;1612:1924-32. PMID: 16163440. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.16163440
509 Lee WT, Cheung CS, Tse YK . Generalized low bone mass of girls with adolescent idiopathic scoliosis is related to inadequate calcium intake and weight bearing physical activity in peripubertal period. Osteoporosis International. 2005;169:1024-35. PMID: 15726296. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.15726296
510 Leech JA, Ernst P, Rogala EJ . Cardiorespiratory status in relation to mild deformity in adolescent idiopathic scoliosis. Journal of Pediatrics. 1985;1061:143-9. PMID: 3965673. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.3965673
511 Lehman RA. and Lenke LG. and Keeler KA. and Kim YJ. and Buchowski JM. and Cheh G. and Kuhns CA. and Bridwell KH. Operative treatment of adolescent idiopathic scoliosis with posterior pedicle screw-only constructs: minimum three-year follow-up of one hundred fourteen cases. Spine (03622436). 2008;3314:1598-1604. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
512 Leider LL Jr, Moe JH . Early ambulation after the surgical treatment of idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1973;555:1003-15. PMID: 4586405. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4586405
513 Lenke LG, Betz RR, Bridwell KH . Intraobserver and interobserver reliability of the classification of thoracic adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1998;808:1097-106. PMID: 9730118. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.9730118
514 Lenke LG, Bridwell KH, Blanke K . Analysis of pulmonary function and chest cage dimension changes after thoracoplasty in idiopathic scoliosis. Spine. 1995;2012:1343-50. PMID: 7676331. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E6c.7676331
515 Lennartsson B, Friede H. Influence on dentofacial morphology of scoliosis therapy with the original and modified Milwaukee brace. Swedish Dental Journal. 1981;52:55-64. PMID: 6943735. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.6943735
516 Lensman L. Getting it straight: scoliosis and structural integration. Massage & Bodywork. 2003;185:56-61 5p. PMID: 106697189. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.
517 Lenssinck ML. and Frijlink AC. and Berger MY. and Bierman-Zeinstra SM. and Verkerk K. and Verhagen AP. Effect of bracing and other conservative interventions in the treatment of idiopathic scoliosis in adolescents: a systematic review of clinical trials. Physical Therapy. 2005;8512:1329-39. PMID: 16305271. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.16305271
518 Leone A, Aulisa A, Perisano C . Advantages of a two-step procedure for school-based scoliosis screening. Radiologia Medica. 2010;1152:238-45. PMID: 19789960. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.19789960
519 Lerman JA, Sullivan E, Haynes RJ. The Pediatric Outcomes Data Collection Instrument (PODCI) and functional assessment in patients with adolescent or juvenile idiopathic scoliosis and congenital scoliosis or kyphosis. Spine. 2002;2718:2052-7; di. PMID: 12634568. KQ1E12, KQ2E12, KQ3E9a, KQ4E9, KQ5E12, KQ6E9a.12634568
520 Lerner T, Frobin W, Bullmann V . Changes in disc height and posteroanterior displacement after fusion in patients with idiopathic scoliosis: a 9-year follow-up study. Journal of Spinal Disorders & Techniques. 2007;203:195-202. PMID: 17473638. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.17473638
521 Letts M, Quanbury A, Gouw G . Computerized ultrasonic digitization in the measurement of spinal curvature. Spine. 1988;1310:1106-10. PMID: 3061023. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.3061023
522 Levy AR, Goldberg MS, Hanley JA . Projecting the lifetime risk of cancer from exposure to diagnostic ionizing radiation for adolescent idiopathic scoliosis. Health Physics. 1994;666:621-33. PMID: 8181937. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E6, KQ6E6.8181937
523 Levy AR, Goldberg MS, Mayo NE . Reducing the lifetime risk of cancer from spinal radiographs among people with adolescent idiopathic scoliosis. Spine. 1996;2113:1540-7; di. PMID: 8817782. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E12, KQ6E6.8817782
524 Levy AR, Goldberg MS, Mayo NE . Reducing the lifetime risk of cancer from spinal radiographs among people with adolescent idiopathic scoliosis… including commentary by Ehrhardt JC. Spine (03622436). 1996;2113:1540-1548. PMID: 107381585. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
525 Li HP, Zhou JN. Anterior spinal artery ischemia syndrome--a possible complication following surgery for the correction of scoliosis. Journal of Tongji Medical University. 1988;83:182-5. PMID: 3230595. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3230595
526 Li M, Fang X, Sun Y, . Thoracic curve correction after posterior fusion and instrumentation of structural lumbar curves in patients with adolescent idiopathic scoliosis. Archives of Orthopaedic & Trauma Surgery. 2011;13110:1375-81. PMID: 21567144. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.21567144
527 Li Meng and Wong MS. and Luk Keith DK. and Wong Kenneth WH. and Cheung Kenneth MC. Time-dependent response of scoliotic curvature to orthotic intervention: when should a radiograph be obtained after putting on or taking off a spinal orthosis?. Spine (03622436). 2014;3917:1408-1416. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
528 Lin HY, Nash CL, Herndon CH . The effect of corrective surgery on pulmonary function in scoliosis. Journal of Bone & Joint Surgery - American Volume. 1974;566:1173-9. PMID: 4436354. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.4436354
529 Lin JJ. and Chen WH. and Chen PQ. and Tsauo JY. Alteration in shoulder kinematics and associated muscle activity in people with idiopathic scoliosis. Spine (03622436). 2010;3511:1151-1157. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
530 Liston C. An evaluation of school screening for scoliosis in Western australia. Australian Journal of Physiotherapy. 1981;272:37-43. PMID: 25026449. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.25026449
531 Liu H, Li Z, Li S . Main thoracic curve adolescent idiopathic scoliosis: association of higher rod stiffness and concave-side pedicle screw density with improvement in sagittal thoracic kyphosis restoration. Journal of Neurosurgery Spine. 2015;223:259-66. PMID: 25525960. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.25525960
532 Loncar-Dusek M, Pecina M, Prebeg Z. A longitudinal study of growth velocity and development of secondary gender characteristics versus onset of idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1991;0270:278-82. PMID: 1884550. KQ1E6, KQ2E7, KQ3E12, KQ4E4, KQ5E6, KQ6E12.1884550
533 Londono Douglas and Kou Ikuyo and Johnson Todd A and Sharma Swarkar and Ogura Yoji and Tsunoda Tatsuhiko and Takahashi Atsushi and Matsumoto Morio and Herring John A. and Lam Tsz-Ping and Wang Xingyan and Tam Elisa MS. A meta-analysis identifies adolescent idiopathic scoliosis association with LBX1 locus in multiple ethnic groups. Journal of Medical Genetics. 2014;516:401-6. PMID: 24721834. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24721834
534 Lonner Baron and Yoo Andrew and Terran Jamie S. and Sponseller Paul and Samdani Amer and Betz Randy and Shuffelbarger Harry and Shah Suken A. and Newton Peter Effect of spinal deformity on adolescent quality of life: comparison of operative scheuermann kyphosis, adolescent idiopathic scoliosis, and normal controls. Spine (03622436). 2013;3812:1049-1055. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
535 Lonstein J, Winter R, Moe J . Wound infection with Harrington instrumentation and spine fusion for scoliosis. Clinical Orthopaedics & Related Research. 1973;096:222-33. PMID: 4584242. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4584242
536 Lonstein JE, Bjorklund S, Wanninger MH . Voluntary school screening for scoliosis in Minnesota. Journal of Bone & Joint Surgery - American Volume. 1982;644:481-8. PMID: 6802853. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.6802853
537 Lonstein JE, Winter RB. The Milwaukee brace for the treatment of adolescent idiopathic scoliosis. A review of one thousand and twenty patients. Journal of Bone & Joint Surgery - American Volume. 1994;768:1207-21. PMID: 8056801. KQ1E12, KQ2E12, KQ3E8c, KQ4E12, KQ5E12, KQ6E6.8056801
538 Lonstein JE. and Carlson JM. The prediction of curve progression in untreated idiopathic scoliosis during growth. Journal of Bone & Joint Surgery - American Volume. 1984;667:1061-71. PMID: 6480635. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.6480635
539 Lou E, Hill D, Hedden D . An objective measurement of brace usage for the treatment of adolescent idiopathic scoliosis. Medical engineering & physics. 2011;333:290-4. PMID: 21112234. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21112234
540 Lou E, Hill D, Raso J . Prediction of brace treatment outcomes by monitoring brace usage. Studies in Health Technology & Informatics. 2006;1230:239-44. PMID: 17108433. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.17108433
541 Lou E,Hill D,Raso J,Donauer A,Moreau M,Mahood J,Hedden D Smart brace versus standard rigid brace for the treatment of scoliosis: a pilot study. Studies in health technology and informatics. 2012;176:338-41. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22744524
542 Lou E,Raso Jv,Hill Dl,Mahood Jk,Moreau Mj Correlation between quantity and quality of orthosis wear and treatment outcomes in adolescent idiopathic scoliosis. Prosthetics and Orthotics International. 2004;281:49-54. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
543 Lou EH, Chan AC, Donauer A . Ultrasound-assisted brace casting for adolescent idiopathic scoliosis, IRSSD Best research paper 2014. Scoliosis. 2015;100:13. PMID: 25883676. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.25883676
544 Lou EH, Hill DL, Raso JV . How quantity and quality of brace wear affect the brace treatment outcomes for AIS. European Spine Journal. 2015;:. PMID: 26386869. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.26386869
545 Lovallo JL, Banta JV, Renshaw TS. Adolescent idiopathic scoliosis treated by Harrington-rod distraction and fusion. Journal of Bone & Joint Surgery - American Volume. 1986;689:1326-30. PMID: 3782204. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3782204
546 Luhmann SJ, Lenke LG, Bridwell KH . Revision surgery after primary spine fusion for idiopathic scoliosis. Spine (03622436). 2009;3420:2191-2197. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
547 Luk KD, Lee FB, Leong JC . The effect on the lumbosacral spine of long spinal fusion for idiopathic scoliosis. A minimum 10-year follow-up. Spine. 1987;1210:996-1000. PMID: 2964730. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.2964730
548 Lusini M, Donzelli S, Minnella S . Brace treatment is effective in idiopathic scoliosis over 45degree: an observational prospective cohort controlled study. Spine Journal: Official Journal of the North American Spine Society. 2014;149:1951-6. PMID: 24295798. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.24295798
549 Lykissas MG, Jain VV, Nathan ST . Mid- to long-term outcomes in adolescent idiopathic scoliosis after instrumented posterior spinal fusion: a meta-analysis. Spine (Phila Pa 1976). 2013;382:E113-9. PMID: 23124268. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.23124268
550 Lykissas MG, Sharma V, V VJain,Crawford AH Assessment of rib hump deformity correction in adolescent idiopathic scoliosis with or without costoplasty using the double rib contour sign. Journal of Spinal Disorders & Techniques. 2015;284:134-9. PMID: 23027365. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.23027365
551 MacEwen GD, Bunnell WP, Sriram K. Acute neurological complications in the treatment of scoliosis. A report of the Scoliosis Research Society. Journal of Bone & Joint Surgery - American Volume. 1975;573:404-8. PMID: 1123394. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.1123394
552 Mackenzie WGStuart and Matsumoto Hiroko and Williams Brendan A. and Corona Jacqueline and Lee Christopher and Cody Stephanie R. and Covington Lisa and Saiman Lisa and Flynn John M. and Skaggs David L. and Roye Jr David P Surgical site infection following spinal instrumentation for scoliosis: a multicenter analysis of rates, risk factors, and pathogens. Journal of Bone & Joint Surgery, American Volume. 2013;9:800-806 7p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
553 MacLean WE Jr, Green NE . Stress and coping with scoliosis: psychological effects on adolescents and their families. Journal of Pediatric Orthopedics. 1989;93:257-61. PMID: 2786006. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.2786006
554 Mac-Thiong JM, Labelle H, Charlebois M . Sagittal plane analysis of the spine and pelvis in adolescent idiopathic scoliosis according to the coronal curve type. Spine. 2003;2813:1404-9. PMID: 12838098. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.12838098
555 Mac-Thiong JM, Labelle H, de Guise JA. Comparison of sacropelvic morphology between normal adolescents and subjects with adolescent idiopathic scoliosis. Studies in Health Technology & Informatics. 2006;1230:195-200. PMID: 17108426. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.17108426
556 Mac-Thiong JM. and Parent S. and Poitras B. and Joncas J. and Hubert L. Neurological outcome and management of pedicle screws misplaced totally within the spinal canal. Spine (03622436). 2013;383:229-237 9p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
557 Mahaudens Philippe,Raison Maxime,Banse Xavier,Mousny Maryline,Detrembleur Christine Effect of long-term orthotic treatment on gait biomechanics in adolescent idiopathic scoliosis. Spine Journal. 2014;148:1510-1519. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
558 Makino T, Kaito T, Kashii M . Low back pain and patient-reported QOL outcomes in patients with adolescent idiopathic scoliosis without corrective surgery. Springerplus. 2015;40:397. PMID: 26261755. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.26261755
559 Mamyama T, Kitagawal T, Takeshita K . Side shift exercise for idiopathic scoliosis after skeletal maturity. Studies in Health Technology & Informatics. 2002;910:361-4. PMID: 15457756. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15457756
560 Mannherz RE, Betz RR, Clancy M . Juvenile idiopathic scoliosis followed to skeletal maturity. Spine. 1988;1310:1087-90. PMID: 3206264. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.3206264
561 Mao S, Shi B, Xu L . Initial Cobb angle reduction velocity following bracing as a new predictor for curve progression in adolescent idiopathic scoliosis. European Spine Journal. 2015;:. PMID: 25906378. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.25906378
562 Margonato V, Fronte F, Rainero G . Effects of short term cast wearing on respiratory and cardiac responses to submaximal and maximal exercise in adolescents with idiopathic scoliosis. Europa Medicophysica. 2005;412:135-40. PMID: 16200029. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.16200029
563 Mariconda M, Galasso O, Barca P . Minimum 20-year follow-up results of Harrington rod fusion for idiopathic scoliosis. European Spine Journal. 2005;149:854-61. PMID: 15864669. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.15864669
564 Marks M, Petcharaporn M, Betz RR . Outcomes of surgical treatment in male versus female adolescent idiopathic scoliosis patients. Spine (03622436). 2007;325:544-549 6p. PMID: 0. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E9d.
565 Marti CL, Glassman SD, Knott PT . Scoliosis Research Society members attitudes towards physical therapy and physiotherapeutic scoliosis specific exercises for adolescent idiopathic scoliosis. Scoliosis. 2015;100:16. PMID: 26056527. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.26056527
566 Martinez-Llorens J, Ramirez M, Colomina MJ . Muscle dysfunction and exercise limitation in adolescent idiopathic scoliosis. European Respiratory Journal. 2010;362:393-400. PMID: 20032022. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.20032022
567 Maruyama T, Grivas TB, Kaspiris A. Effectiveness and outcomes of brace treatment: a systematic review. Physiother Theory Pract. 2011;271:26-42. PMID: 21198404. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21198404
568 Maruyama T, Kobayashi Y, Miura M . Effectiveness of brace treatment for adolescent idiopathic scoliosis. Scoliosis. 2015;10:S12. PMID: 25815048. KQ1E12, KQ2E12, KQ3E9, KQ4E6b, KQ5E12, KQ6E9.25815048
569 Maruyama T, Takeshita K, Kitagawa T. Milwaukee brace today. Disability & Rehabilitation: Assistive Technology. 2008;33:136-138 3p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.
570 Maruyama T,Kitagawa T,Takeshita K,Mochizuki K, Nakamura K Conservative treatment for adolescent idiopathic scoliosis: can it reduce the incidence of surgical treatment?. Pediatric Rehabilitation. 2003;642433:215-9. PMID: .KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
571 Maruyama T. Bracing adolescent idiopathic scoliosis: a systematic review of the literature of effective conservative treatment looking for end results 5 years after weaning. Disability & Rehabilitation. 2008;3010:786-91. PMID: 18432436. KQ1E12, KQ2E12, KQ3E10, KQ4E12, KQ5E12, KQ6E10.18432436
572 Matamalas A, Bago J, D'Agata E . Body image in idiopathic scoliosis: a comparison study of psychometric properties between four patient-reported outcome instruments. Health & Quality of Life Outcomes. 2014;120:81. PMID: 24894714. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24894714
573 Matsunaga S, Hayashi K, Naruo T . Psychologic management of brace therapy for patients with idiopathic scoliosis. Spine (03622436). 2005;300:547-550 4p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
574 Mau H. Scoliosis screening in West Germany and its pitfalls with Scheuermann's disease. Archives of Orthopaedic & Traumatic Surgery. 1985;1044:201-6. PMID: 4084033. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.4084033
575 Mauroy JC, Pourret S, Barral F. Weaning results of a consecutive series of 125 adolescent idiopathic scoliosis treated by the new Lyon Brace (ART brace). Annals of Physical & Rehabilitation Medicine. 2016;0:e92. PMID: 27677033. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E9c.
576 Mayo NE, Goldberg MS, Poitras B . The Ste-Justine adolescent idiopathic scoliosis cohort study. Part III: back pain. Spine (03622436). 1994;1914:1573-1581. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
577 McArdle FJ, Griffiths CJ, Macdonald AM . Monitoring the thoracic sagittal curvature in kyphoscoliosis with surface topography: a trend analysis of 57 patients. Studies in Health Technology & Informatics. 2002;910:199-203. PMID: 15457723. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15457723
578 McCarthy RE. Prevention of the complications of scoliosis by early detection. Clinical Orthopaedics & Related Research. 1987;0222:73-8. PMID: 2957138. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.2957138
579 McCollough NC 3rd Electrical stimulation in management of idiopathic scoliosis. Instr Course Lect. 1985;340:119-26. PMID: 3879613. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3879613
580 McCollough NC3rd,Schultz M, Javech N . Miami TLSO in the management of scoliosis: preliminary results in 100 cases. Journal of Pediatric Orthopedics. 1981;12:141-52. PMID: 7334090. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.7334090
581 McIntire K, Asher M, Burton D . Comparison of isometric trunk rotational strength of adolescents with idiopathic scoliosis to healthy adolescents. Studies in Health Technology & Informatics. 2006;1230:509-12. PMID: 17108477. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.17108477
582 McIntire KL, Asher MA, Burton DC . Trunk rotational strength asymmetry in adolescents with idiopathic scoliosis: an observational study. Scoliosis. 2007;20:9. PMID: 17620141. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.17620141
583 McIntire Kl,Asher Ma,Burton Dc,Liu W Treatment of adolescent idiopathic scoliosis with quantified trunk rotational strength training: a pilot study. Journal of Spinal Disorders & Techniques. 2008;215:349-58. PMID: .KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
584 McLain RF, Karol L. Conservative treatment of the scoliotic and kyphotic patient. Brace treatment and other modalities. Archives of Pediatrics & Adolescent Medicine. 1994;1486:646-51. PMID: 8193695. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.8193695
585 McMaster ME, Lee AJ, Burwell RG. Physical activities of Patients with adolescent idiopathic scoliosis (AIS): preliminary longitudinal case-control study historical evaluation of possible risk factors. Scoliosis. 2015;100:6. PMID: 25866554. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.25866554
586 McPhail Gary L, Ehsan Zarmina,Howells Sacha A, Boesch RPaul,Fenchel Matthew C . Obstructive lung disease in children with idiopathic scoliosis. Journal of Pediatrics. 2015;1664:1018-1021. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
587 Meade KP, Bunch WH, Vanderby R . Progression of unsupported curves in adolescent idiopathic scoliosis. Spine. 1987;126:520-6. PMID: 3660076. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.3660076
588 Mejia EA, Hennrikus WL, Schwend RM . A prospective evaluation of idiopathic left thoracic scoliosis with magnetic resonance imaging. Journal of Pediatric Orthopedics. 1996;163:354-8. PMID: 8728637. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.8728637
589 Mellencamp DD, Blount WP, Anderson AJ. Milwaukee brace treatment of idiopathic scoliosis: late results. Clin Orthop Relat Res. 1977;0126:47-57. PMID: 598139. KQ1E12, KQ2E12, KQ3E9, KQ4E9, KQ5E12, KQ6E9.598139
590 Mellencamp DD, Blount WP. The natural history of idiopathic scoliosis. Late results revisited. Spine. 1986;118:805-6. PMID: 3810296. KQ1E12, KQ2E12, KQ3E12, KQ4E8, KQ5E12, KQ6E12.3810296
591 Meng F, Cao J, Meng X. Risk factors for surgical site infection following pediatric spinal deformity surgery: a systematic review and meta-analysis. Childs Nervous System. 2015;314:521-7. PMID: 25707483. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.25707483
592 Merenda Lisa and Costello Kimberly and Santangelo Anna Marie and Mulcahey Mary Jane Perceptions of self-image and physical appearance: conversations with typically developing youth and youth with idiopathic scoliosis. Orthopaedic Nursing. 2011;306:383-390 8p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
593 Merola AA, Haher TR, Brkaric M . A multicenter study of the outcomes of the surgical treatment of adolescent idiopathic scoliosis using the Scoliosis Research Society (SRS) outcome instrument. Spine (03622436). 2002;2718:2046-2051. PMID: 0. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6.
594 Miller JA, Nachemson AL, Schultz AB. Effectiveness of braces in mild idiopathic scoliosis. Spine (Phila Pa 1976). 1984;96:632-5. PMID: 6495034. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.6495034
595 Min K, Hahn F, Ziebarth K. Short anterior correction of the thoracolumbar/lumbar curve in King 1 idiopathic scoliosis: the behaviour of the instrumented and non-instrumented curves and the trunk balance. European Spine Journal. 2007;161:65-72. PMID: 16544158. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.16544158
596 Minghelli B, Nunes C, Oliveira R. Prevalence of scoliosis in southern Portugal adolescents. Pediatric Endocrinology Reviews. 2014;114:374-82. PMID: 24988690. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.24988690
597 Minguez MF, Buendia M, Cibrian RM . Quantifier variables of the back surface deformity obtained with a noninvasive structured light method: evaluation of their usefulness in idiopathic scoliosis diagnosis. European Spine Journal. 2007;161:73-82. PMID: 16609858. KQ1E6, KQ2E6, KQ3E6, KQ4E12, KQ5E6, KQ6E6.16609858
598 Mirovsky Y, Blankstein A, Shlamkovitch N. Postural control in patients with severe idiopathic scoliosis: a prospective study. Journal of Pediatric Orthopaedics, Part B. 2006;153:168-71. PMID: 16601583. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.16601583
599 Mirtz TA, Thompson MA, Greene L . Adolescent idiopathic scoliosis screening for school, community, and clinical health promotion practice utilizing the PRECEDE-PROCEED model. Chiropractic & Osteopathy. 2005;1311:[1-35] 1p. PMID: 0. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
600 Misterska E, Glowacki M, Adamczyk K . Patients' and Parents' Perceptions of Appearance in Scoliosis Treated with a Brace: A Cross-Sectional Analysis. J Child Fam Stud. 2014;237:1163-1171. PMID: 25210419. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.25210419
601 Misterska E, Glowacki M, Harasymczuk J. Personality characteristics of females with adolescent idiopathic scoliosis after brace or surgical treatment compared to healthy controls. Medical Science Monitor. 2010;1612:CR606-15. PMID: 21119579. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.21119579
602 Misterska E, Glowacki M, Latuszewska J . Perception of stress level, trunk appearance, body function and mental health in females with adolescent idiopathic scoliosis treated conservatively: a longitudinal analysis. Quality of Life Research. 2013;227:1633-45. PMID: 23188133. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.23188133
603 Misterska E, Glowacki M, Latuszewska J. Female patients' and parents' assessment of deformity- and brace-related stress in the conservative treatment of adolescent idiopathic scoliosis. Spine (03622436). 2012;3714:1218-1223. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
604 Misterska Ewa,Glowacki Maciej,Adamczyk Katarzyna,Glowacki Jakub,Harasymczuk Jerzy A longitudinal study of alexithymia in relation to physical activity in adolescent females with scoliosis subjected to cheneau brace treatment: preliminary report. Spine (03622436). 2014;3917:E1026-34 1. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
605 Mittal RL, Aggerwal R, Sarwal AK. School screening for scoliosis in India. The evaluation of a scoliometer. International Orthopaedics. 1987;114:335-8. PMID: 3440651. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.3440651
606 Modi HN, Chen T, Suh SW . Observer reliability between juvenile and adolescent idiopathic scoliosis in measurement of stable Cobb's angle. European Spine Journal. 2009;181:52-8. PMID: 19037669. KQ1E12, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.19037669
607 Modrzewski K, Skwarcz A. Causes and effects of delayed treatment of spine deformation in children and youth. Ortopedia Traumatologia Rehabilitacja. 2005;71:42-8. PMID: 17675955. KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.17675955
608 Moe JH, Kettleson DN. Idiopathic scoliosis. Analysis of curve patterns and the preliminary results of Milwaukee-brace treatment in one hundred sixty-nine patients. Journal of Bone & Joint Surgery - American Volume. 1970;528:1509-33. PMID: 5483076. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5483076
609 Moe JH, Kharrat K, Winter RB . Harrington instrumentation without fusion plus external orthotic support for the treatment of difficult curvature problems in young children. Clinical Orthopaedics & Related Research. 1984;0185:35-45. PMID: 6705397. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.6705397
610 Moe JH, Purcell GA, Bradford DS. Zielke instrumentation (VDS) for the correction of spinal curvature. Analysis of results in 66 patients. Clinical Orthopaedics & Related Research. 1983;0180:133-53. PMID: 6627784. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.6627784
611 Moe JH. Complications of scoliosis treatment. Clinical Orthopaedics & Related Research. 1967;530:21-30. PMID: 5589470. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.5589470
612 Mok JM. and Cloyd JM. and Bradford DS. and Hu SS. and Deviren V. and Smith JA. and Tay B. and Berven SH. Reoperation after primary fusion for adult spinal deformity: rate, reason, and timing. Spine (03622436). 2009;348:832-839 8p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5.
613 Montgomery F, Willner S. Screening for idiopathic scoliosis. Comparison of 90 cases shows less surgery by early diagnosis. Acta Orthop Scand. 1993;644:456-8. PMID: 8213127. KQ1E9, KQ2E7c, KQ3E12, KQ4E6, KQ5E6, KQ6E12.8213127
614 Montgomery F, Willner S. The natural history of idiopathic scoliosis. A study of the incidence of treatment. Spine. 1988;134:401-4. PMID: 3261455. KQ1E12, KQ2E7c, KQ3E12, KQ4E12, KQ5E12, KQ6E12.3261455
615 Montgomery F, Willner S. The natural history of idiopathic scoliosis. Incidence of treatment in 15 cohorts of children born between 1963 and 1977. Spine. 1997;227:772-4. PMID: 9106318. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E12, KQ6E6.9106318
616 Montgomery F, Willner S. The natural history of idiopathic scoliosis: incidence of treatment in 15 cohorts of children born between 1963 and 1977… including commentary by Weinstein SL. Spine (03622436). 1997;227:772-774 3p. PMID: 107237219. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
617 Montgomery F,Willner S Prognosis of brace-treated scoliosis. Comparison of the Boston and Milwaukee methods in 244 girls. Acta Orthop Scand. 1989;604:383-5. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
618 Montgomery F,Willner S,Appelgren G Long-term follow-up of patients with adolescent idiopathic scoliosis treated conservatively: an analysis of the clinical value of progression. Journal of Pediatric Orthopedics. 1990;101:48-52. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
619 Monticelli G, Ascani E, Salsano V. Analysis of the end results of the surgical treatment of idiopathic scoliosis. Israel Journal of Medical Sciences. 1973;96:823-36. PMID: 4737472. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4737472
620 Monticone M. Answer to the letter to the editor of S. Negrini et al. concerning ‘active self-correction and task-oriented exercises reduce spinal deformity and improve quality of life in subjects with mild adolescent idiopathic scoliosis. Results of a randomised contr. European Spine Journal. 2014;2310:2221-2. PMID: 25052210. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.25052210
621 Mooney V, Brigham A. The role of measured resistance exercises in adolescent scoliosis. Orthopedics. 2003;262:167-171 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
622 Mooney V, Mayer J, Woodbridge D. Exercise for managing adolescent scoliosis. Journal of Musculoskeletal Medicine. 2007;243:107-115 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
623 Morais T. and Bernier M. and Turcotte F. Age- and sex-specific prevalence of scoliosis and the value of school screening programs. Am J Public Health. 1985;7512:1377-80. PMID: 4061707. KQ1E12, KQ2E7a, KQ3E12, KQ4E12, KQ5E12, KQ6E12.4061707
624 Mordecai SC, Dabke HV. Efficacy of exercise therapy for the treatment of adolescent idiopathic scoliosis: a review of the literature. European Spine Journal. 2012;213:382-9. PMID: 22065168. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22065168
625 Mordecai Sc, Dabke Hv Efficacy of exercise therapy for treating adolescent idiopathic scoliosis: A systematic review of the literature. European Spine Journal. 2011;204:S542. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
626 Morningstar MW, Woggon D, Lawrence G. Scoliosis treatment using a combination of manipulative and rehabilitative therapy: a retrospective case series. BMC musculoskeletal disorders. 2004;50:32. PMID: 15363104. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15363104
627 Morr S, Carrer A, Alvarez-Garcia de Quesada LI . Skipped versus consecutive pedicle screw constructs for correction of Lenke 1 curves. European Spine Journal. 2015;247:1473-80. PMID: 25599851. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8.25599851
628 Morrissy RT, Goldsmith GS, Hall EC . Measurement of the Cobb angle on radiographs of patients who have scoliosis. Evaluation of intrinsic error. Journal of Bone & Joint Surgery - American Volume. 1990;723:320-7. PMID: 2312527. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.2312527
629 Morse LJ. and Kawakami N. and Lenke LG. and Sucato DJ. and Sanders JO. and Diab M. Culture and ethnicity influence outcomes of the scoliosis research society instrument in adolescent idiopathic scoliosis. Spine (03622436). 2012;3712:1072-1076. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
630 Morton A, Riddle R, Buchanan R . Accuracy in the prediction and estimation of adherence to bracewear before and during treatment of adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 2008;283:336-41. PMID: 18362800. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.18362800
631 Mulcahy T, Galante J, DeWald R . A follow-up study of forces acting on the Milwaukee brace on patients undergoing treatment for idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1973;093:53-68. PMID: 4722962. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4722962
632 Mullaji AB. and Upadhyay SS. and Luk KD. and Leong JC. Vertebral growth after posterior spinal fusion for idiopathic scoliosis in skeletally immature adolescents. The effect of growth on spinal deformity. J Bone Joint Surg Br. 1994;766:870-6. PMID: 7983109. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.7983109
633 Muller C, Fuchs K, Winter C . Prospective evaluation of physical activity in patients with idiopathic scoliosis or kyphosis receiving brace treatment. European Spine Journal. 2011;207:1127-36. PMID: 21479852. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.21479852
634 Murrell GA, Coonrad RW, Moorman CT . An assessment of the reliability of the Scoliometer. Spine. 1993;186:709-12. PMID: 8516699. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.8516699
635 Mustard WT. Scoliosis: diagnosis and natural history. Canadian Medical Association Journal. 1960;820:815-21. PMID: 14425549. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.14425549
636 Myers BA, Friedman SB, Weiner IB. Coping with a chronic disability. Psychosocial observations of girls with scoliosis treated with the Milwaukee brace. American Journal of Diseases of Children. 1970;1203:175-81. PMID: 4917851. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4917851
637 Nachemson A. A long term follow-up study of non-treated scoliosis. Acta Orthop Scand. 1968;394:466-76. PMID: 5726117. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.5726117
638 Nash CL Jr, Gregg EC . Risks of exposure to X-rays in patients undergoing long-term treatment for scoliosis. Journal of Bone & Joint Surgery - American Volume. 1979;613:371-4. PMID: 429405. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.429405
639 Nathan SW. Coping with disability and the surgical experience: body image of scoliotic female adolescents. Clinical Pediatrics. 1978;175:434-40. PMID: 648063. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.648063
640 Nault Marie-Lyne and Mac-Thiong Jean-Marc and Roy-Beaudry Marjolaine and Turgeon Isabelle and Deguise Jacques and Labelle Hubert and Parent Stefan Three-dimensional spinal morphology can differentiate between progressive and nonprogressive patients with adolescent idiopathic scoliosis at the initial presentation: a prospective study. Spine (03622436). 2014;3910:E601-6 1p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E6a, KQ5E12, KQ6E12.
641 Nault ML, Allard P, Hinse S . Relations between standing stability and body posture parameters in adolescent idiopathic scoliosis. Spine. 2002;2717:1911-7. PMID: 12221357. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.12221357
642 Negrini S, Antonini G, Carabalona R . Physical exercises as a treatment for adolescent idiopathic scoliosis. A systematic review. Pediatric Rehabilitation. 2003;642433:227-235 9p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
643 Negrini S, Atanasio S, Fusco C . Effectiveness of complete conservative treatment for adolescent idiopathic scoliosis (bracing and exercises) based on SOSORT management criteria: results according to the SRS criteria for bracing studies - SOSORT Award 2009 Winner. Scoliosis. 2009;40:19. PMID: 19732429. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.19732429
644 Negrini S, Atanasio S, Negrini F . The Sforzesco brace can replace cast in the correction of adolescent idiopathic scoliosis: A controlled prospective cohort study. Scoliosis. 2008;30:15. PMID: 18976485. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.18976485
645 Negrini S, Aulisa L, Ferraro C . Italian guidelines on rehabilitation treatment of adolescents with scoliosis or other spinal deformities. Eura Medicophys. 2005;412:183-201. PMID: 16200035. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.16200035
646 Negrini S, Bettany-Saltikov J, De Mauroy JC . Letter to the editor concerning: ‘active self-correction and task-oriented exercises reduce spinal deformity and improve quality of life in subjects with mild adolescent idiopathic scoliosis. Results of a randomised controlled trial’ by Monticone M, Ambro. European Spine Journal. 2014;2310:2218-20. PMID: 25148863. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.25148863
647 Negrini S, Carabalona R. Social acceptability of treatments for adolescent idiopathic scoliosis: a cross-sectional study. Scoliosis. 2006;10:14. PMID: 16930488. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.16930488
648 Negrini S, Donzelli S, Lusini M . The effectiveness of combined bracing and exercise in adolescent idiopathic scoliosis based on SRS and SOSORT criteria: a prospective study. BMC musculoskeletal disorders. 2014;150:263. PMID: 25095800. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.25095800
649 Negrini S, Grivas TB, Kotwicki T . Why do we treat adolescent idiopathic scoliosis? What we want to obtain and to avoid for our patients. SOSORT 2005 Consensus paper. Scoliosis. 2006;10:4. PMID: 16759352. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.16759352
650 Negrini S, Minozzi S, Bettany-Saltikov J . Braces for idiopathic scoliosis in adolescents. Spine (Phila Pa 1976). 2010;3513:1285-93. PMID: 20461027. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.20461027
651 Negrini S, Minozzi S, Bettany-Saltikov J . Braces for idiopathic scoliosis in adolescents. Cochrane Database of Systematic Reviews. 2015;6:0. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
652 Negrini S, Minozzi S, Bettany-Saltikov J . Braces for idiopathic scoliosis in adolescents.[Update of Cochrane Database Syst Rev. 2010;(1):CD006850; PMID: 20091609]. Cochrane Database of Systematic Reviews. 2015;60:CD006850. PMID: 26086959. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6d.26086959
653 Negrini S, Negrini A, Romano M . A controlled prospective study on the efficacy of SEAS.02 exercises in preparation to bracing for idiopathic scoliosis. Studies in Health Technology & Informatics. 2006;1230:519-22. PMID: 17108479. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.17108479
654 Negrini S, Negrini A, Romano M . A controlled prospective study on the efficacy of SEAS.02 exercises in preventing progression and bracing in mild idiopathic scoliosis. Studies in Health Technology & Informatics. 2006;1230:523-6. PMID: 17108480. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.17108480
655 Negrini S, Negrini F, Fusco C . Idiopathic scoliosis patients with curves more than 45 Cobb degrees refusing surgery can be effectively treated through bracing with curve improvements. Spine Journal: Official Journal of the North American Spine Society. 2011;115:369-80. PMID: 21292562. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21292562
656 Negrini S,Donzelli S,Dulio M,Zaina F Is the SRS-22 able to detect Quality of Life (QoL) changes during conservative treatments ?. Studies in health technology and informatics. 2012;176:433-6. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.22744547
657 Negrini S. and De Mauroy JC. and Grivas TB. and Knott P. and Kotwicki T. and Maruyama T. and O'Brien JP. and Rigo M. and Zaina F. Actual evidence in the medical approach to adolescents with idiopathic scoliosis. European journal of physical & rehabilitation medicine.. 2014;501:87-92. PMID: 24622050. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.24622050
658 Negrini S. and Fusco C. and Minozzi S. and Atanasio S. and Zaina F. and Romano M. Exercises reduce the progression rate of adolescent idiopathic scoliosis: results of a comprehensive systematic review of the literature. Disability & Rehabilitation. 2008;3010:772-85. PMID: 18432435. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18432435
659 Nery LS, Halpern R, Nery PC . Prevalence of scoliosis among school students in a town in southern Brazil. Sao Paulo Medical Journal = Revista Paulista de Medicina. 2010;1282:69-73. PMID: 20676572. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.20676572
660 Newton Peter O. and Marks Michelle C. and Bastrom Tracey P. and Betz Randal and Clements David and Lonner Baron and Crawford Alvin and Shufflebarger Harry and Obrien Michael and Yaszay Burt Surgical treatment of Lenke 1 main thoracic idiopathic scoliosis: results of a prospective, multicenter study. Spine (03622436). 2013;384:328-338 11. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
661 Newton PO, Parent S, Marks M . Prospective evaluation of 50 consecutive scoliosis patients surgically treated with thoracoscopic anterior instrumentation. Spine (Phila Pa 1976). 2005;30:S100-9. PMID: 16138057. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.16138057
662 Newton PO, Perry A, Bastrom TP . Predictors of change in postoperative pulmonary function in adolescent idiopathic scoliosis: a prospective study of 254 patients. Spine (03622436). 2007;3217:1875-1882. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
663 Newton PO, Upasani VV, Lhamby J . Surgical treatment of main thoracic scoliosis with thoracoscopic anterior instrumentation. a five-year follow-up study. Journal of Bone & Joint Surgery, American Volume. 2008;10:2077-2089. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
664 Ng BK, Chau WW, Hui CN . HRQoL assessment by SRS-30 for Chinese patients with surgery for Adolescent Idiopathic Scoliosis (AIS). Scoliosis. 2015;10:S19. PMID: 25810753. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.25810753
665 Nicholson GP, Ferguson-Pell MW, Smith K . Quantitative measurement of spinal brace use and compliance in the treatment of adolescent idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;910:372-7. PMID: 15457759. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15457759
666 Niemeyer T, Bovingloh AS, Grieb S . Low back pain after spinal fusion and Harrington instrumentation for idiopathic scoliosis. International Orthopaedics. 2005;291:47-50. PMID: 15526199. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15526199
667 Nilsonne U, Lundgren KD. Long-term prognosis in idiopathic scoliosis. Acta Orthop Scand. 1968;394:456-65. PMID: 5726116. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.5726116
668 Nissinen M, Heliovaara M, Seitsamo J . Trunk asymmetry, posture, growth, and risk of scoliosis. A three-year follow-up of Finnish prepubertal school children. Spine. 1993;181:42595. PMID: 8434329. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.8434329
669 Nissinen M. and Heliovaara M. and Ylikoski M. and Poussa M. Trunk asymmetry and screening for scoliosis: a longitudinal cohort study of pubertal schoolchildren. Acta Paediatr. 1993;821:77-82. PMID: 8453227. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.8453227
670 Noh Dong Koog and You Joshua H. and Koh Jae-Hyun and Kim Hoseong and Kim Donghyun and Ko Sung-Mok and Shin Ji-Youn Effects of novel corrective spinal technique on adolescent idiopathic scoliosis as assessed by radiographic imaging. Journal of Back & Musculoskeletal Rehabilitation. 2014;273:331-338 8p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
671 Noonan KJ, Dolan LA, Jacobson WC . Long-term psychosocial characteristics of patients treated for idiopathic scoliosis. Journal of Pediatric Orthopedics. 1997;176:712-7. PMID: 9591971. KQ1E12, KQ2E12, KQ3E6, KQ4E8b, KQ5E12, KQ6E9.9591971
672 Noonan KJ, Weinstein SL, Jacobson WC . Use of the Milwaukee brace for progressive idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1996;784:557-67. PMID: 8609134. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.8609134
673 Northway RO Jr, Alexander RG . A cephalometric evaluation of the old Milwaukee brace and the modified Milwaukee brace in relation to the normal growing child. American Journal of Orthodontics. 1974;654:341-63. PMID: 4206125. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4206125
674 Noshchenko A, Hoffecker L, Lindley EM . Predictors of spine deformity progression in adolescent idiopathic scoliosis: A systematic review with meta-analysis. World Journal of Orthopedics. 2015;67:537-58. PMID: 26301183. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.26301183
675 Nottage WM, Waugh TR, McMaster WC. Radiation exposure during scoliosis screening radiography. Spine. 1981;65:456-9. PMID: 7302679. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7302679
676 Nowotny-Czupryna O, Kowalczyk A, Czupryna K . Health status of adults treated for 1st degree scoliosis at school age. Ortopedia Traumatologia Rehabilitacja. 2012;143:229-38. PMID: 22764335. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.22764335
677 Nugent M, Tarrant RC, Queally JM . Influence of curve magnitude and other variables on operative time, blood loss and transfusion requirements in adolescent idiopathic scoliosis. Irish Journal of Medical Science. 2016;1852:513-20. PMID: 25935207. KQ1E12, KQ2E12, KQ3E6d, KQ4E12, KQ5E12, KQ6E6d.25935207
678 Nuno M, Drazin DG, Acosta FL . Differences in treatments and outcomes for idiopathic scoliosis patients treated in the United States from 1998 to 2007: impact of socioeconomic variables and ethnicity. Spine Journal: Official Journal of the North American Spine Society. 2013;132:116-23. PMID: 23182025. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.23182025
679 O'Donnell CS. and Bunnell WP. and Betz RR. and Bowen JR. and Tipping CR. Electrical stimulation in the treatment of idiopathic scoliosis. Clin Orthop Relat Res. 1988;0229:107-13. PMID: 3258214. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3258214
680 Ogilvie JW. Diagnosis and treatment of spinal deformities. What to do for the patient with scoliosis. Postgraduate Medicine. 1988;843:147-50, 15. PMID: 2970632. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.2970632
681 Oh CH, Shim YS, Yoon SH . The psychopathological influence of adolescent idiopathic scoliosis in korean male : an analysis of multiphasic personal inventory test results. Journal of Korean Neurosurgical Society. 2013;531:13-8. PMID: 23440382. KQ1E12, KQ2E12, KQ3E12, KQ4E6b, KQ5E12, KQ6E12.23440382
682 Ohrt-Nissen S, Hallager DW, Gehrchen M . Flexibility Predicts Curve Progression in Providence Nighttime Bracing of Patients with Adolescent Idiopathic Scoliosis. Spine. 2016;12:12. PMID: 27076435. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.27076435
683 Ohtsuka Y, Yamagata M, Arai S . School screening for scoliosis by the Chiba University Medical School screening program. Results of 1.24 million students over an 8-year period. Spine. 1988;1311:1251-7. PMID: 3206283. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.3206283
684 Olafsson Y, Saraste H, Ahlgren RM. Does bracing affect self-image? A prospective study on 54 patients with adolescent idiopathic scoliosis. Eur Spine J. 1999;85:402-5. PMID: 10552324. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9b.10552324
685 Olafsson Y, Saraste H, Soderlund V . Boston brace in the treatment of idiopathic scoliosis. Journal of Pediatric Orthopedics. 1995;154:524-7. PMID: 7560048. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7560048
686 Oneill Kevin R. and Lenke Lawrence G. and Bridwell Keith H. and Hyun Seung-Jae and Neuman Brian and Dorward Ian and Koester Linda Clinical and Radiographic Outcomes After 3-Column Osteotomies With 5-Year Follow-up. Spine (03622436). 2014;395:424-432 9p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
687 O'Neill PJ, Karol LA, Shindle MK . Decreased orthotic effectiveness in overweight patients with adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery, American Volume. 2005;5:1069-1074. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
688 Orvomaa E. Psychological evaluations of patients operated for idiopathic scoliosis by the Harrington method. International Journal of Rehabilitation Research. 1998;212:169-178 10. PMID: 0. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
689 Padua R, Padua S, Aulisa L . Patient outcomes after Harrington instrumentation for idiopathic scoliosis: a 15- to 28-year evaluation. Spine (03622436). 2001;2611:1268-1273. PMID: 0. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
690 Pang L, Watanabe K, Toyama Y . Massive hemothorax caused by Gelpi retractor during posterior correction surgery for adolescent idiopathic scoliosis: a case report. Scoliosis. 2014;9:17. PMID: 25904971. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.25904971
691 Paolucci T, Morone G, Di Cesare A . Effect of Cheneau brace on postural balance in adolescent idiopathic scoliosis: a pilot study. European journal of physical & rehabilitation medicine.. 2013;495:649-57. PMID: 23820877. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23820877
692 Paolucci T, Piccinini G, Iosa M . The importance of trunk perception during brace treatment in moderate juvenile idiopathic scoliosis: What is the impact on self-image?. Journal of Back & Musculoskeletal Rehabilitation. 2016;30:30. PMID: 27392847. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E9d.27392847
693 Parent EC, Hill D, Mahood J . Associations between quality-of-life and internal or external spinal deformity measurements in adolescent with idiopathic scoliosis (AIS). Studies in Health Technology & Informatics. 2006;1230:357-63. PMID: 17108452. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.17108452
694 Parent EC, Hill D, Moreau M . Score distribution of the Scoliosis Quality of Life Index questionnaire in different subgroups of patients with adolescent idiopathic scoliosis. Spine (03622436). 2007;3216:1767-1777. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
695 Parent EC, Schreiber S, Hedden D . The effect of a 6-month Schroth exercise program: A pilot study using subjects as their own controls. Scoliosis. Conference: 10th International Conference on Conservative Management of Spinal Deformities - SOSORT 2013 Annual Meeting United States. Conference Start: 20130508 Conference End: 20130511. 2013;80:. PMID: 0. KQ1E12, KQ2E12, KQ3E7e, KQ4E12, KQ5E12, KQ6E7e.
696 Parent EC, Wong D, Hill D . The association between Scoliosis Research Society-22 scores and scoliosis severity changes at a clinically relevant threshold. Spine (03622436). 2010;353:315-322 8p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
697 Parent EC. and Dang R. and Hill D. and Mahood J. and Moreau M. and Raso J. and Lou E. Score distribution of the scoliosis research society-22 questionnaire in subgroups of patients of all ages with idiopathic scoliosis. Spine (03622436). 2010;355:568-577 10. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
698 Park J, Houtkin S, Grossman J . A modified brace (Prenyl) for scoliosis. Clinical Orthopaedics & Related Research. 1977;0126:67-73. PMID: 598142. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.598142
699 Pasha Saba and Aubin Carl-Eric and Sangole Archana P. and Labelle Hubert and Parent Stefan and Mac-Thiong Jean-Marc Three-dimensional spinopelvic relative alignment in adolescent idiopathic scoliosis. Spine (03622436). 2014;397:564-570 7p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
700 Patil CG, Santarelli J, Lad SP . Inpatient complications, mortality, and discharge disposition after surgical correction of idiopathic scoliosis: a national perspective. Spine Journal: Official Journal of the North American Spine Society. 2008;86:904-10. PMID: 18358787. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5.18358787
701 Patil CG. and Lad EM. and Lad SP. and Ho C. and Boakye M. Visual loss after spine surgery: a population-based study. Spine (03622436). 2008;3313:1491-1496. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
702 Payne WK III and Ogilvie JW. and Resnick MD. and Kane RL. and Transfeldt EF. and Blum RW. Does scoliosis have a psychological impact and does gender make a difference?. Spine (03622436). 2014;3919:E1174-80. PMID: 109754913. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
703 Pazos V, Cheriet F, Danserau J . Reliability of trunk shape measurements based on 3-D surface reconstructions. European Spine Journal. 2007;1611:1882-91. PMID: 17701228. KQ1E6, KQ2E6, KQ3E6, KQ4E12, KQ5E6, KQ6E6.17701228
704 Pecina M, Dakovic M, Bojanic I. The natural history of mild idiopathic scoliosis. Acta Medica Croatica. 1992;462:75-8. PMID: 1384838. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.1384838
705 Pecina M, Dapic T. More than 20-year follow-up Harrington instrumentation in the treatment of severe idiopathic scoliosis. European Spine Journal. 2007;162:299-300. PMID: 17024401. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.17024401
706 Pehrsson K, Bake B, Larsson S . Lung function in adult idiopathic scoliosis: a 20 year follow up. Thorax. 1991;467:474-8. PMID: 1877034. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.1877034
707 Pehrsson K, Larsson S, Oden A . Long-term follow-up of patients with untreated scoliosis. A study of mortality, causes of death, and symptoms. Spine. 1992;179:1091-6. PMID: 1411763. KQ1E12, KQ2E12, KQ3E12, KQ4E9c, KQ5E12, KQ6E12.1411763
708 Pellegrino Ln, Avanzi O Prospective evaluation of quality of life in adolescent idiopathic scoliosis before and after surgery. Journal of Spinal Disorders & Techniques. 2014;278:409-14. PMID: 0. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
709 Peltonen J, Poussa M, Ylikoski M. Three-year results of bracing in scoliosis. Acta Orthop Scand. 1988;595:487-90. PMID: 3188850. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.3188850
710 Perez-Prieto D, Sanchez-Soler JF, Martinez-Llorens J . Poor outcomes and satisfaction in adolescent idiopathic scoliosis surgery: the relevance of the body mass index and self-image. European Spine Journal. 2015;242:276-80. PMID: 25077944. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E6c.25077944
711 Perie D, Aubin CE, Petit Y . Boston brace correction in idiopathic scoliosis: a biomechanical study. Spine. 2003;2815:1672-7. PMID: 12897490. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.12897490
712 Persky SL, Johnston LE. An evaluation of dentofacial changes accompanying scoliosis therapy with a modified Milwaukee brace. American Journal of Orthodontics. 1974;654:364-71. PMID: 4522226. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4522226
713 Pesenti S, Jouve JL, Morin C . Evolution of adolescent idiopathic scoliosis: Results of a multicenter study at 20 years' follow-up. Orthopaedics & traumatology, surgery & research. 2015;1015:619-22. PMID: 26194208. KQ1E12, KQ2E12, KQ3E12, KQ4e6, KQ5E12, KQ6E12.26194208
714 Peters BM. Threat appraisal by an adolescent girl undergoing surgical correction of scoliosis. Maternal-Child Nursing Journal. 1976;53:167-78. PMID: 1049382. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.1049382
715 Pfeiffer M, Griss P, Haake M . Standardized evaluation of long-term results after anterior lumbar interbody fusion. European Spine Journal. 1996;55:299-307. PMID: 8915634. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.8915634
716 Pham Vm,Herbaux B,Schill A, Thevenon A Evaluation of the Cheneau brace in adolescent idiopathic scoliosis. Annales de Readaptation et de Medecine Physique. 2007;503:125-33. PMID: .KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
717 Pham Vm,Houlliez A,Carpentier A,Herbaux B,Schill A,Thevenon A Determination of the influence of the Cheneau brace on quality of life for adolescent with idiopathic scoliosis. Annales de readaptation et de medecine physique. 2008;511:42444. PMID: 0. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E6.
718 Phan P. and Mezghani N. and Nault ML. and Aubin CE. and Parent S. and de Guise J. and Labelle H. A decision tree can increase accuracy when assessing curve types according to Lenke classification of adolescent idiopathic scoliosis. Spine (03622436). 2010;3410:1054-1059. PMID: . KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.
719 Piazza MR, Bassett GS. Curve progression after treatment with the Wilmington brace for idiopathic scoliosis. Journal of Pediatric Orthopedics. 1990;101:39-43. PMID: 2298893. KQ1E12, KQ2E12, KQ3E9, KQ4E6a, KQ5E12, KQ6E9.2298893
720 Picault C, deMauroy JC, Mouilleseaux B . Natural history of idiopathic scoliosis in girls and boys. Spine. 1986;118:777-8. PMID: 3810291. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.3810291
721 Picelli A, Negrini S, Zenorini A . Do adolescents with idiopathic scoliosis have body schema disorders? A cross-sectional study. J Back Musculoskelet Rehabil. 2015;:. PMID: 26406220. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.26406220
722 Pin LH, Mo LY, Lin L . Early diagnosis of scoliosis based on school-screening. Journal of Bone & Joint Surgery - American Volume. 1985;678:1202-5. PMID: 4055844. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.4055844
723 Pingot M, Czernicki J, Kubacki J. Assessment of muscle strength of hip joints in children with idiopathic scoliosis. Ortopedia Traumatologia Rehabilitacja. 2007;96:636-43. PMID: 18227755. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.18227755
724 Pinto WC, Avanzi O, Dezen E. Common sense in the management of adolescent idiopathic scoliosis. Orthopedic Clinics of North America. 1994;252:215-23. PMID: 8159396. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.8159396
725 Plaszewski M, Bettany-Saltikov J. Are current scoliosis school screening recommendations evidence-based and up to date? A best evidence synthesis umbrella review. European Spine Journal. 2014;2312:2572-85. PMID: 24777669. KQ1E12, KQ2E9, KQ3E12, KQ4E12, KQ5E12, KQ6E12.24777669
726 Plaszewski M, Cieslinski I, Kowalski P . Does scoliosis-specific exercise treatment in adolescence alter adult quality of life?. TheScientificWorldJournal. 2014;20140:539671. PMID: 25436225. KQ1E12, KQ2E12, KQ3E9, KQ4E9, KQ5E12, KQ6E6.25436225
727 Plaszewski M, Nowobilski R, Kowalski P . Screening for scoliosis: different countries' perspectives and evidence-based health care. International Journal of Rehabilitation Research. 2012;351:13-9. PMID: 22123730. KQ1E12, KQ2E9, KQ3E12, KQ4E12, KQ5E12, KQ6E12.22123730
728 Plaszewski M. and Bettany-Saltikov J. Non-surgical interventions for adolescents with idiopathic scoliosis: an overview of systematic reviews. PLoS ONE [Electronic Resource]. 2014;910:e110254. PMID: 25353954. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.25353954
729 Plewka B, Sibinski M, Synder M . Clinical assessment of the efficacy of SpineCor brace in the correction of postural deformities in the course of idiopathic scoliosis. Polish Orthopedics & Traumatology. 2013;780:85-9. PMID: 23535882. KQ1E12, KQ2E12, KQ3E8b, KQ4E12, KQ5E12, KQ6E6.23535882
730 Plewka B, Sibinski M, Synder M . Radiological evaluation of treatment with SpineCor brace in children with idiopathic spinal scoliosis. Ortopedia Traumatologia Rehabilitacja. 2013;153:227-34. PMID: 23897999. KQ1E12, KQ2E12, KQ3E8b, KQ4E12, KQ5E12, KQ6E6.23897999
731 Poitras B, Mayo NE, Goldberg MS . The Ste-Justine Adolescent Idiopathic Scoliosis Cohort Study. Part IV: Surgical correction and back pain. Spine (Phila Pa 1976). 1994;1914:1582-8. PMID: 7939994. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.7939994
732 Pollack JJ. The effects of the Milwaukee brace on the dentition and jaws. Journal of the National Medical Association. 1970;621:27-35. PMID: 5445441. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5445441
733 Ponseti IV, Friedman B. Prognosis in idiopathic scoliosis. J Bone Joint Surg Am. 1950;02:381-95. PMID: 15412180. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.15412180
734 Posadzki Paul,Myeong Soo Lee,Ernst Edzard Osteopathic Manipulative Treatment for Pediatric Conditions: A Systematic Review. Pediatrics. 2013;1321:140-152 13. PMID: .KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
735 Potaczek T, Zarzycki D, Tesiorowski M . Does instrumentation removal cause curve progression in patients with adolescent idiopathic scoliosis?. Ortopedia Traumatologia Rehabilitacja. 2009;116:501-12. PMID: 20032526. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.20032526
736 Potter BK, Rosner MK, Lehman RA . Reliability of end, neutral, and stable vertebrae identification in adolescent idiopathic scoliosis. Spine. 2005;3014:1658-63. PMID: 16025037. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.16025037
737 Poussa M, Mellin G. Spinal mobility and posture in adolescent idiopathic scoliosis at three stages of curve magnitude. Spine. 1992;177:757-60. PMID: 1502638. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.1502638
738 Pratt RK, Burwell RG, Cole AA . Patient and parental perception of adolescent idiopathic scoliosis before and after surgery in comparison with surface and radiographic measurements. Spine. 2002;2714:1543-50; d. PMID: 12131715. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.12131715
739 Pratt RK, Webb JK, Burwell RG . Re: Koch et al. Adolescents undergoing surgery for idiopathic scoliosis: how physical and psychological characteristics relate to patient satisfaction with cosmetic result. (Spine 2001;26:2119-24). Spine. 2002;2714:1594-5; au. PMID: 12131728. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.12131728
740 Pratt WB, Schader JB, Phippen WG. Elevation of hair copper in idiopathic scoliosis. A follow-up report. Spine. 1984;95:540. PMID: 6149620. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.6149620
741 Price Ct,Scott Ds,Reed Fe,Riddick Mf Nighttime bracing for adolescent idiopathic scoliosis with the Charleston bending brace. Preliminary report. Spine. 1990;1512:1294-9. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
742 Price Ct,Scott Ds,Reed Fr,Sproul Jt,Riddick Mf Nighttime bracing for adolescent idiopathic scoliosis with the Charleston Bending Brace: long-term follow-up. Journal of Pediatric Orthopedics. 1997;176:703-7. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
743 Primiano FP Jr, Nussbaum E . Early echocardiographic and pulmonary function findings in idiopathic scoliosis. Journal of Pediatric Orthopedics. 1983;34:475-81. PMID: 6630493. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.6630493
744 Prowse A, Pope R, Gerdhem P . Reliability and validity of inexpensive and easily administered anthropometric clinical evaluation methods of postural asymmetry measurement in adolescent idiopathic scoliosis: a systematic review. European Spine Journal. 2015;00:0. PMID: 25917824. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.25917824
745 Pruijs JE, Hageman MA, Keessen W . Variation in Cobb angle measurements in scoliosis. Skeletal Radiol. 1994;237:517-20. PMID: 7824978. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7824978
746 Pruijs JE, Stengs C, Keessen W. Parameter variation in stable scoliosis. European Spine Journal. 1995;43:176-9. PMID: 7552652. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.7552652
747 Pruijs JE. and van der Meer R. and Hageman MA. and Keessen W. and van Wieringen JC. The benefits of school screening for scoliosis in the central part of The Netherlands. European Spine Journal. 1996;56:374-9. PMID: 8988379. KQ1E9, KQ2E7a, KQ3E12, KQ4E12, KQ5E12, KQ6E12.8988379
748 Puno RM, An KC, Puno RL . Treatment recommendations for idiopathic scoliosis: an assessment of the Lenke classification. Spine. 2003;2818:2102-14; d. PMID: 14501921. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.14501921
749 Puno RM, Mehta S, Byrd JA . Surgical treatment of idiopathic thoracolumbar and lumbar scoliosis in adolescent patients. Orthopedic Clinics of North America. 1994;252:275-86. PMID: 8159401. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.8159401
750 Qian X-H,Tang Z-Y,Ye X-L,Bi Ly,Wu T,Jiang H,Shi Q [Daoyin manipulation for adolescent idiopathic scoliosis: a multicenter laminating randomized control study]. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007;1149:9890-3. PMID: 0. KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
751 Qiu G, Zhang J, Wang Y . A new operative classification of idiopathic scoliosis: a peking union medical college method. Spine. 2005;3012:1419-26. PMID: 15959372. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15959372
752 Qiu G. and Li Q. and Wang Y. and Yu B. and Qian J. and Yu K. and Lee CI. and Zhang J. and Shen J. and Zhao Y. and Weng X. and Wang T. and Aladin DM. and Lu WW. Comparison of reliability between the PUMC and Lenke classification systems for classifying adolescent idiopathic scoliosis. Spine (03622436). 2008;3322:E836-42 1p. PMID: . KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.
753 Qiu Y, Sun X, Cheng JC . Bone mineral accrual in osteopenic and non-osteopenic girls with idiopathic scoliosis during bracing treatment. Spine (03622436). 2008;3315:1682-1689. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
754 Rackham MD. and Cundy TP. and Antoniou G. and Freeman BJ. and Sutherland LM. and Cundy PJ. Predictors of serum chromium levels after stainless steel posterior spinal instrumentation for adolescent idiopathic scoliosis. Spine (03622436). 2010;359:975-982 8p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
755 Rahman T, Bowen JR, Takemitsu M . The association between brace compliance and outcome for patients with idiopathic scoliosis. Journal of Pediatric Orthopedics. 2005;254:420-2. PMID: 15958887. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15958887
756 Rainoldi Laura and Zaina Fabio and VillafaÃ±e Jorge H. and Donzelli Sabrina and Negrini Stefano Quality of life in normal and idiopathic scoliosis adolescents before diagnosis: reference values and discriminative validity of the SRS-22. A cross-sectional study of 1,205 pupils. Spine Journal. 2015;154:662-667 6p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
757 Ramirez L, Durdle NG, Raso VJ . A support vector machines classifier to assess the severity of idiopathic scoliosis from surface topography. IEEE Transactions on Information Technology in Biomedicine. 2006;101:84-91. PMID: 16445253. KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.16445253
758 Ramirez M, Martinez-Llorens J, Sanchez JF . Body composition in adolescent idiopathic scoliosis. European Spine Journal. 2013;222:324-9. PMID: 22886589. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.22886589
759 Ramirez N, Johnston CE, Browne RH. The prevalence of back pain in children who have idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1997;793:364-8. PMID: 9070524. KQ1E12, KQ2E12, KQ3E12, KQ4E6a, KQ5E12, KQ6E12.9070524
760 Ran B, Chen XY, Zhang GY . Comparison of the sagittal profiles among thoracic idiopathic scoliosis patients with different Cobb angles and growth potentials.[Erratum appears in J Orthop Surg Res. 2014;9:82 Note: Qiao, Dun-yi and Guan, Jun-hui [Added]; Qi, Dun-yi [Deleted]], [Retrac. Journal of Orthopaedic Surgery. 2014;90:19. PMID: 24635839. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24635839
761 Ran B, Zhang GY, Shen F . Comparison of the sagittal profiles among thoracic idiopathic scoliosis patients with different Cobb angles and growth potentials. Journal of Orthopaedic Surgery. 2014;90:19. PMID: 24635839. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24635839
762 Ransford AO, Manning CW. Complications of halo-pelvic distraction for scoliosis. Journal of Bone & Joint Surgery - British Volume. 1975;572:131-7. PMID: 1141278. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.1141278
763 Rao PS, Gregg EC. A revised estimate of the risk of carcinogenesis from x-rays to scoliosis patients. Investigative Radiology. 1984;191:58-60. PMID: 6706520. KQ1E6, KQ2E6, KQ3E6, KQ4E12, KQ5E6, KQ6E6.6706520
764 Rapp SM. SRS database finds 8.5% complication rate following pediatric spine surgery. Orthopedics Today. 2010;3011:22-22 1p. PMID: . KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
765 Reames DL, Smith JS, Fu KM . Complications in the surgical treatment of 19,360 cases of pediatric scoliosis: a review of the Scoliosis Research Society Morbidity and Mortality database. Spine (Phila Pa 1976). 2011;3618:1484-91. PMID: 21037528. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5a.21037528
766 Reddi V, Clarke DV Jr . Anterior thoracoscopic instrumentation in adolescent idiopathic scoliosis: a systematic review. Spine (Phila Pa 1976). 2008;3318:1986-94. PMID: 18665023. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18665023
767 Richards BS, Scaduto A, Vanderhave K . Assessment of trunk balance in thoracic scoliosis. Spine. 2005;3014:1621-6. PMID: 16025031. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.16025031
768 Richards BS. Delayed infections following posterior spinal instrumentation for the treatment of idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1995;774:524-9. PMID: 7713968. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.7713968
769 Richards BS. and Bernstein RM. and D'Amato CR. and Thompson GH. Standardization of criteria for adolescent idiopathic scoliosis brace studies: SRS Committee on Bracing and Nonoperative Management. Spine (Phila Pa 1976). 2005;3018:2068-75; d. PMID: 16166897. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.16166897
770 Rigo M, Quera-Salva G, Puigdevall N . Retrospective results in immature idiopathic scoliotic patients treated with a Cheneau brace. Studies in Health Technology & Informatics. 2002;880:241-5. PMID: 15456042. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15456042
771 Rigo M, Quera-Salva G, Villagrasa M. Sagittal configuration of the spine in girls with idiopathic scoliosis: progressing rather than initiating factor. Studies in Health Technology & Informatics. 2006;1230:90-4. PMID: 17108409. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.17108409
772 Rigo M, Reiter CH, Weiss H. Effect of conservative management on the prevalence of surgery in patients with adolescent idiopathic scoliosis. Pediatric Rehabilitation. 2003;642433:209-214 6p. PMID: 0. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E6.
773 Rinsky LA, Gamble JG. Adolescent idiopathic scoliosis. Western Journal of Medicine. 1988;1482:182-91. PMID: 3279708. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.3279708
774 Riseborough EJ. The effects of scoliotic deformities on pulmonary function. Israel Journal of Medical Sciences. 1973;96:787-90. PMID: 4724288. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.4724288
775 Riseborough EJ. and Wynne-Davies R. A genetic survey of idiopathic scoliosis in Boston, Massachusetts. Journal of Bone & Joint Surgery - American Volume. 1973;555:974-82. PMID: 4760104. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.4760104
776 Riska EB. End results in the treatment of scoliosis. A survey of 57 cases. Acta Orthop Scand. 1967;00:Suppl 102:. PMID: 5341246. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.5341246
777 Riska EB. Spinal Fusion in Scoliosis. A Survey of 197 Cases. Acta Orthop Scand. 1964;0:SUPPL 1667. PMID: 14162287. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.14162287
778 Rivett L, Stewart A, Potterton J. The effect of compliance to a Rigo System Cheneau brace and a specific exercise programme on idiopathic scoliosis curvature: a comparative study: SOSORT 2014 award winner. Scoliosis. 2014;90:5. PMID: 24926318. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6c.24926318
779 Roberto RF, Lonstein JE, Winter RB . Curve progression in Risser stage 0 or 1 patients after posterior spinal fusion for idiopathic scoliosis. Journal of Pediatric Orthopedics. 1997;176:718-25. PMID: 9591972. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.9591972
780 Roberts DW, Savage JW, Schwartz DG . Male-female differences in scoliosis research society-30 scores in adolescent idiopathic scoliosis. Spine (03622436). 2011;361:E53-9 1p. PMID: . KQ1E12, KQ2E12, KQ3E9b, KQ4E12, KQ5E12, KQ6E9b.
781 Roberts RS, Price CT, Riddick MF. Use of a bivalved polypropylene orthosis in the postoperative management of idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1984;0185:25-34. PMID: 6705389. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.6705389
782 Robitaille Y, Villavicencio-Pereda C, Gurr J. Adolescent idiopathic scoliosis: epidemiology and treatment outcome in a large cohort of children six years after screening. International Journal of Epidemiology. 1984;133:319-23. PMID: 6490302. KQ1E6, KQ2E7a, KQ3E12, KQ4E6, KQ5E6, KQ6E12.6490302
783 Rogala EJ. and Drummond DS. and Gurr J. Scoliosis: incidence and natural history. A prospective epidemiological study. Journal of Bone & Joint Surgery - American Volume. 1978;602:173-6. PMID: 641080. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.641080
784 Romano M, Minozzi S, Zaina F . Exercises for adolescent idiopathic scoliosis: a Cochrane systematic review. Spine (Phila Pa 1976). 2013;3814:E883-93. PMID: 23558442. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.23558442
785 Romano M, Negrini S. Manual therapy as a conservative treatment for adolescent idiopathic scoliosis: a systematic review. Scoliosis. 2008;30:2. PMID: 18211702. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18211702
786 Romano M. and Minozzi S. and Bettany-Saltikov J. and Zaina F. and Chockalingam N. and Kotwicki T. and Maier-Hennes A. and Negrini S. Exercises for adolescent idiopathic scoliosis. Cochrane Database of Systematic Reviews. 2012;80:CD007837. PMID: 22895967. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22895967
787 Roubal PJ, Freeman DC, Placzek JD. Costs and effectiveness of scoliosis screening. Physiotherapy. 1999;855:259-270 12. PMID: 0. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
788 Roussouly P, Labelle H, Rouissi J . Pre- and post-operative sagittal balance in idiopathic scoliosis: a comparison over the ages of two cohorts of 132 adolescents and 52 adults. European Spine Journal. 2013;0:S203-15. PMID: 23188161. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.23188161
789 Rowe De, Feise Rj, Crowther Er, Grod Jp, Menke Jm, Goldsmith Ch, Stoline Mr, Souza Ta, Kambach B Chiropractic manipulation in adolescent idiopathic scoliosis: A pilot study. Chiropractic & Osteopathy. 2006;14:15. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.16923185
790 Rowe DE. and Bernstein SM. and Riddick MF. and Adler F. and Emans JB. and Gardner-Bonneau D. A meta-analysis of the efficacy of non-operative treatments for idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1997;795:664-74. PMID: 9160938. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.9160938
791 Roye BD. and Wright ML. and Williams BA. and Matsumoto H. and Corona J. and Hyman JE. and Roye DPJr. and Vitale MG. Does ScoliScore Provide More Information Than Traditional Clinical Estimates of Curve Progression?. Spine (03622436). 2012;3725:2099-2103. PMID: . KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
792 Roye DP Jr, Farcy JP . Results of spinal instrumentation of adolescent idiopathic scoliosis by King type. Spine. 1992;17:S270-3. PMID: 1523511. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.1523511
793 Rullander Anna-Clara and Jonsson HÃ¥kan and LundstrÃ¶m Mats and Lindh Viveca Young People's Experiences With Scoliosis Surgery…A survey of pain, nausea, and global satisfaction. Orthopaedic Nursing. 2013;326:327-335 9p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
794 Rushton PR, Grevitt MP, Sell PJ. Anterior or posterior surgery for right thoracic adolescent idiopathic scoliosis (AIS)? A prospective cohorts' comparison using radiologic and functional outcomes. Journal of Spinal Disorders & Techniques. 2015;283:80-8. PMID: 22820280. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E8b.22820280
795 Rushton PR. and Grevitt MP. Comparison of untreated adolescent idiopathic scoliosis with normal controls: a review and statistical analysis of the literature. Spine (Phila Pa 1976). 2013;389:778-85. PMID: 23169069. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.23169069
796 Rushton PR. and Grevitt MP. What is the effect of surgery on the quality of life of the adolescent with adolescent idiopathic scoliosis? A review and statistical analysis of the literature. Spine. 2013;389:786-794. PMID: 12013034143. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
797 Ryan PM, Puttler EG, Stotler WM . Role of the triradiate cartilage in predicting curve progression in adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 2007;276:671-6. PMID: 17717469. KQ1E6, KQ2E6, KQ3E6, KQ4E12, KQ5E6, KQ6E6.17717469
798 Sabirin J. and Bakri R. and Buang SN. and Abdullah AT. and Shapie A. School scoliosis screening programme: a systematic review. Medical Journal of Malaysia. 2010;654:261-267. PMID: 12011003379. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
799 Sachs B, Bradford D, Winter R Scheuermann kyphosis. Follow-up of Milwaukee-brace treatment. Journal of Bone & Joint Surgery - American Volume. 1987;691:50-7. PMID: 3100538. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3100538
800 Safikhani Z, Fakor M, Soori H . Prevalence of scoliosis in female students 11-15 years of age in Ahwaz, Iran. Neurosciences. 2006;112:97-8. PMID: 22266557. KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.22266557
801 Sahlstrand T, Sellden U. Nerve conduction velocity in patients with adolescent idiopathic scoliosis. Scandinavian Journal of Rehabilitation Medicine. 1980;121:25-6. PMID: 7384762. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.7384762
802 Sales de Gauzy J, Jouve JL, Ilharreborde B . Use of the Universal Clamp in adolescent idiopathic scoliosis. European Spine Journal. 2014;0:S446-51. PMID: 24828958. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.24828958
803 Samdani AF, Ames RJ, Kimball JS . Anterior vertebral body tethering for immature adolescent idiopathic scoliosis: one-year results on the first 32 patients. European Spine Journal. 2015;247:1533-9. PMID: 25510515. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.25510515
804 Sanders AE, Andras LM, Choi PD . Lateral Femoral Cutaneous Nerve Palsy After Spinal Fusion for Adolescent Idiopathic Scoliosis (AIS). Spine. 2016;4119:E1164-7. PMID: 27010998. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E6d.27010998
805 Sanders James O, Newton Peter O, Browne Richard H . Bracing for idiopathic scoliosis: how many patients require treatment to prevent one surgery?. Journal of Bone & Joint Surgery, American Volume. 2014;968:649-653 5p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E9d, KQ5E12, KQ6E9.
806 Sanders JO, Browne RH, McConnell SJ . Maturity assessment and curve progression in girls with idiopathic scoliosis. Journal of Bone & Joint Surgery, American Volume. 2007;1:64-73 10p. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
807 Sanders JO, Little DG, Richards BS. Prediction of the crankshaft phenomenon by peak height velocity. Spine. 1997;2212:1352-6; di. PMID: 9201839. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.9201839
808 Sanders JO, Newton PO, Browne RH . Bracing in adolescent idiopathic scoliosis, surrogate outcomes, and the number needed to treat. Journal of Pediatric Orthopedics. 2012;0:S153-7. PMID: 22890455. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22890455
809 Sanders JO, Polly Dw Jr,Cats-Baril W, Jones J . Analysis of patient and parent assessment of deformity in idiopathic scoliosis using the Walter Reed Visual Assessment Scale. Spine (03622436). 2003;2818:2158-2163. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
810 Sanders JO. and Herring JA. and Browne RH. Posterior arthrodesis and instrumentation in the immature (Risser-grade-0) spine in idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1995;771:39-45. PMID: 7822354. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7822354
811 Sangole AP, Aubin CE, Labelle H . Three-dimensional classification of thoracic scoliotic curves. Spine (03622436). 2009;341:91-99 9p. PMID: . KQ1E5, KQ2E7, KQ3E12, KQ4E12, KQ5E5, KQ6E12.
812 Sansur CA. and Smith JS. and Coe JD. and Glassman SD. and Berven SH. and Polly DWJr. and Perra JH. and Boachie-Adjei O. and Shaffrey CI. Scoliosis research society morbidity and mortality of adult scoliosis surgery. Spine (03622436). 2011;369:E593-7 1p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
813 Sapkas G, Papagelopoulos PJ, Kateros K . Prediction of Cobb angle in idiopathic adolescent scoliosis. Clinical Orthopaedics & Related Research. 2003;0411:32-9. PMID: 12782857. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.12782857
814 Sapountzi-Krepia D, Psychogiou M, Peterson D . The experience of brace treatment in children/adolescents with scoliosis. Scoliosis. 2006;10:8. PMID: 16759368. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.16759368
815 Sapountzi-Krepia DS, Valavanis J, Panteleakis GP . Perceptions of body image, happiness and satisfaction in adolescents wearing a Boston brace for scoliosis treatment. Journal of Advanced Nursing. 2001;355:683-690 8p. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
816 Sarwahi V, Horn JJ, Kulkarni PM . Minimally Invasive Surgery in Patients With Adolescent Idiopathic Scoliosis: Is it Better than the Standard Approach? A 2-Year Follow-up Study. Clinical Spine Surgery : A Spine Publication. 2016;298:331-40. PMID: 24852384. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.24852384
817 Satake K, Lenke LG, Kim YJ . Analysis of the lowest instrumented vertebra following anterior spinal fusion of thoracolumbar/lumbar adolescent idiopathic scoliosis: can we predict postoperative disc wedging?. Spine. 2005;304:418-26. PMID: 15706339. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15706339
818 Sato T, Hirano T, Ito T . Back pain in adolescents with idiopathic scoliosis: epidemiological study for 43,630 pupils in Niigata City, Japan. European Spine Journal. 2011;202:274-9. PMID: 21165657. KQ1E12, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.21165657
819 Savastano AA, Thayer JB, Gibson TK. Experiences with the Harrington Instrumentation Method in the Treatment of Idiopathic Scoliosis. A Preliminary Report. Journal of the International College of Surgeons. 1964;420:421-8. PMID: 14197964. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.14197964
820 Schlosser TP, Shah SA, Reichard SJ . Differences in early sagittal plane alignment between thoracic and lumbar adolescent idiopathic scoliosis. Spine Journal: Official Journal of the North American Spine Society. 2014;142:282-90. PMID: 24231781. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24231781
821 Schmidt AC. Halo-tibial traction combined with the Milwaukee Brace. Clinical Orthopaedics & Related Research. 1971;770:73-83. PMID: 5140462. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5140462
822 Schmitz A, Konig R, Kandyba J . Visualisation of the brace effect on the spinal profile in idiopathic scoliosis. European Spine Journal. 2005;142:138-43. PMID: 15480826. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15480826
823 Schreiber S, Parent EC, Hedden DM . The effects of a 6-month Schroth intervention for Adolescent Idiopathic Scoliosis (AIS): Preliminary analysis of an ongoing randomized controlled trial. Scoliosis. Conference: 10th International Conference on Conservative Management of Spinal Deformities - SOSORT 2013 Annual Meeting United States. Conference Start: 20130508 Conference End: 20130511. 2013;80:. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.
824 Schreiber S, Parent EC, Moez EK . The effect of Schroth exercises added to the standard of care on the quality of life and muscle endurance in adolescents with idiopathic scoliosis-an assessor and statistician blinded randomized controlled trial: ‘SOSORT 2015 Award Winner’. Scoliosis. 2015;100:24. PMID: 26413145. KQ1E12, KQ2E12, KQ3E8d, KQ4E12, KQ5E12, KQ6E6.26413145
825 Schreiber S,Parent Ec,Hedden Dm,Watkins Em,Hill Dl,Moreau M Feasibility and three months preliminary results of an RCT on the effect of Schroth exercises in adolescent idiopathic scoliosis (AIS). The 2012 SISORT booklet. 2012;00:-44. PMID: .KQ1E12, KQ2E12, KQ3E8d, KQ4E12, KQ5E12, KQ6E6.
826 Schreiber Sanja,Parent Eric C,Hedden Douglas M,Moreau Marc,Hill Doug,Lou Edmond Effect of Schroth exercises on curve characteristics and clinical outcomes in adolescent idiopathic scoliosis: protocol for a multicentre randomised controlled trial. Journal of Physiotherapy (Australian Physiotherapy Association). 2014;604:234. PMID: . KQ1E12, KQ2E12, KQ3E8d, KQ4E12, KQ5E12, KQ6E6.
827 Schulz Jacob,Asghar Jahangir,Bastrom Tracey,Shufflebarger Harry,Newton Peter O, Sturm Peter,Betz Randal R, Samdani Amer F . Optimal radiographical criteria after selective thoracic fusion for patients with adolescent idiopathic scoliosis with a C lumbar modifier: does adherence to current guidelines predict success?. Spine (03622436). 2014;3923:E1368-73 1. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
828 Schur MS, Brown JT, Kafer ER . Postoperative pulmonary function in children. Comparison of scoliosis with peripheral surgery. American Review of Respiratory Disease. 1984;1301:46-51. PMID: 6742610. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.6742610
829 Schutt RC Jr, Brown CW . Surface electrical stimulation for the treatment of scoliosis. Biomedical Sciences Instrumentation. 1982;180:83-5. PMID: 6983892. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.6983892
830 Schwab F, Dubey A, Pagala M . Adult scoliosis: a health assessment analysis by SF-36. Spine (03622436). 2003;286:602-606 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
831 Schwend RM, Hennrikus W, Hall JE . Childhood scoliosis: clinical indications for magnetic resonance imaging. Journal of Bone & Joint Surgery - American Volume. 1995;771:46-53. PMID: 7822355. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.7822355
832 Schwieger T, Campo S, Weinstein SL . Body Image and Quality of Life and Brace Wear Adherence in Females With Adolescent Idiopathic Scoliosis. Journal of Pediatric Orthopedics. 2016;15:15. PMID: 26886460. KQ1E12, KQ2E12, KQ3E9d, KQ4E6, KQ5E12, KQ6E9d.26886460
833 Schwieger T, Campo S, Weinstein S . Body image and brace wear adherence: Preliminary results from brAIST. Scoliosis. Conference: 11th International Conference on Conservative Management of Spinal Deformities - SOSORT 2014 Annual Meeting Germany. Conference Start: 20140508 Conference End: 20140510. 2014;90:. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.
834 Scoloveno MA, Yarcheski A, Mahon NE. Scoliosis treatment effects on selected variables among adolescents. Western Journal of Nursing Research. 1990;125:601-615 15. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.
835 Scott MM, Piggott H. A short-term follow-up of patients with mild scoliosis. Journal of Bone & Joint Surgery - British Volume. 1981;4:523-5. PMID: 7298676. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.7298676
836 Sevastikoglou JA, Aaro S, Elmstedt E . Bone scanning of the spine and thorax in idiopathic thoracic scoliosis. Clinical Orthopaedics & Related Research. 1980;0149:172-6. PMID: 7408298. KQ1E9, KQ2E9, KQ3E12, KQ4E12, KQ5E9, KQ6E12.7408298
837 Sha S, Zhu Z, Lam TP . Brace treatment versus observation alone for scoliosis associated with Chiari I malformation following posterior fossa decompression: a cohort study of 54 patients. European Spine Journal. 2014;236:1224-31. PMID: 24619608. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.24619608
838 Shaffrey Ellen,Smith Justin S, Lenke Lawrence G, Polly Jr David W . Defining rates and causes of mortality associated with spine surgery: comparison of 2 data collection approaches through the scoliosis research society. Spine (03622436). 2014;397:579-586 8p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5a.
839 Shah MA, Albright MB, Vogt MT . Superior mesenteric artery syndrome in scoliosis surgery: weight percentile for height as an indicator of risk. Journal of Pediatric Orthopedics. 2003;235:665-8. PMID: 12960634. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.12960634
840 Shan LQ. and Skaggs DL. and Lee C. and Kissinger C. and Myung KS. Intensive care unit versus hospital floor: a comparative study of postoperative management of patients with adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 2013;957:e40. PMID: 23553303. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23553303
841 Shannon EG. Understanding school-aged children's postoperative experience following spinal fusion with instrumentation. . 2007;:130 p-130. PMID: .KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
842 Shaughnessy WJ. Management of adolescent idiopathic scoliosis. Current Opinion in Rheumatology. 1993;53:301-8. PMID: 8512766. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.8512766
843 Shen WJ, McDowell GS, Burke SW . Routine preoperative MRI and SEP studies in adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 1996;163:350-3. PMID: 8728636. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.8728636
844 Shi Benlong,Mao Saihu,Wang Zhiwei,Lam Tsz Ping,Yu Fiona Wai Ping,Ng Bobby Kin Wah,Chu Winnie Chiu-Wing,Zhu Zezhang,Qiu Yong,Cheng Jack Chun Yiu How Does the Supine MRI Correlate With Standing Radiographs of Different Curve Severity in Adolescent Idiopathic Scoliosis?. Spine (03622436). 2015;4015:1206-1212. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
845 Shi L, Wang D, Hui SC . Volumetric changes in cerebellar regions in adolescent idiopathic scoliosis compared with healthy controls. Spine Journal: Official Journal of the North American Spine Society. 2013;1312:1904-11. PMID: 23988458. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.23988458
846 Shi Z, Wu Y, Huang J . Pulmonary function after thoracoplasty and posterior correction for thoracic scoliosis patients. International Journal Of Surgery. 2013;119:1007-9. PMID: 23747977. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.23747977
847 Shifrin LZ. Scoliosis-current concepts. Early recognition and aggressive treatment are most important. Clinical Pediatrics. 1972;1110:594-602. PMID: 5078533. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.5078533
848 Shin FT. Some anaesthetic problems in corrective spinal surgery in children in Hong Kong. Anaesthesia & Intensive Care. 1973;14:328-31. PMID: 4589117. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4589117
849 Shneerson JM, Edgar MA. Cardiac and respiratory function before and after spinal fusion in adolescent idiopathic scoliosis. Thorax. 1979;345:658-61. PMID: 515986. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.515986
850 Shneerson JM, Madgwick R. The effect of physical training on exercise ability in adolescent idiopathic scoliosis. Acta Orthop Scand. 1979;503:303-6. PMID: 474101. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.474101
851 Shneerson JM. Cardiac and respiratory responses to exercise in adolescent idiopathic scoliosis. Thorax. 1980;355:347-50. PMID: 7434284. KQ1E12, KQ2E12, KQ3E12, KQ4E6a, KQ5E12, KQ6E12.7434284
852 Sieberg Christine B, Simons Laura E, Edelstein Mark R . Pain prevalence and trajectories following pediatric spinal fusion surgery. Journal of Pain. 2013;1412:1694-1702. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E6.
853 Siller TA, Dickson JH, Erwin WD. Efficacy and cost considerations of intraoperative autologous transfusion in spinal fusion for idiopathic scoliosis with predeposited blood. Spine. 1996;217:848-52. PMID: 8779017. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.8779017
854 Simony A, Hansen EJ, Carreon LY . Health-related quality-of-life in adolescent idiopathic scoliosis patients 25 years after treatment. Scoliosis. 2015;100:22. PMID: 26180541. KQ1E12, KQ2E12, KQ3E9, KQ4E5, KQ5E12, KQ6E6c.26180541
855 Simony A, Hansen EJ, Christensen SB . Incidence of cancer in adolescent idiopathic scoliosis patients treated 25 years previously. European Spine Journal. 2016;3:3. PMID: 27592106. KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12, KQ6E12.27592106
856 Sitoula Prakash,Verma Kushagra,Holmes Jr Laurens,Gabos Peter G, Sanders James O, Yorgova Petya,Neiss Geraldine,Rogers Kenneth,Shah Suken A Prediction of Curve Progression in Idiopathic Scoliosis: Validation of the Sanders Skeletal Maturity Staging System. Spine (03622436). 2015;4013:1006-1013. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
857 Siu King Cheung C, Tak Keung Lee W, Kit Tse Y . Abnormal peri-pubertal anthropometric measurements and growth pattern in adolescent idiopathic scoliosis: a study of 598 patients. Spine. 2003;2818:2152-7. PMID: 14501928. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.14501928
858 Skelly M, Donaldson RC, Scheer GE . Dysphonias associated with spinal bracing in scoliosis. Journal of Speech & Hearing Disorders. 1971;363:368-76. PMID: 5566116. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.5566116
859 Slap GB. Adolescent medicine: attitudes and skills of pediatric and medical residents. Pediatrics. 1984;742:191-7. PMID: 6462819. KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.6462819
860 Slawson D. How effective is a community-based school scoliosis screening program?. Evidence-Based Practice. 2000;31:10-11 2p 1. PMID: 0. KQ1E2, KQ2E2, KQ3E12, KQ4E12, KQ5E2, KQ6E12.
861 Smith FM, Latchford G, Hall RM . Indications of disordered eating behaviour in adolescent patients with idiopathic scoliosis. Journal of Bone & Joint Surgery, British Volume. 2002;3:392-394 3p. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
862 Smith JS, Saulle D, Chen CJ . Rates and causes of mortality associated with spine surgery based on 108,419 procedures: a review of the Scoliosis Research Society Morbidity and Mortality Database. Spine (03622436). 2012;3723:1975-1982. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5.
863 Smith JS, Shaffrey CI, Sansur CA . Rates of infection after spine surgery based on 108,419 procedures: a report from the Scoliosis Research Society Morbidity and Mortality Committee. Spine (03622436). 2011;367:556-563 8p. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5.
864 Smith JS. and Fu KM. and Polly DWJr. and Sansur CA. and Berven SH. and Broadstone PA. and Choma TJ. and Goytan MJ. and Noordeen HH. and Knapp DRJr. and Hart RA. and Donaldson WF . Complication rates of three common spine procedures and rates of thromboembolism following spine surgery based on 108,419 procedures: a report from the Scoliosis Research Society Morbidity and Mortality Committee. Spine (03622436). 2010;3524:2140-2149. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
865 Smith PL, Donaldson S, Hedden D . Parents' and patients' perceptions of postoperative appearance in adolescent idiopathic scoliosis. Spine (03622436). 2006;3120:2367-2374. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
866 Smith RM, Dickson RA. Changes in residual volume relative to vital capacity and total lung capacity after arthrodesis of the spine in patients who have adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1994;761:153. PMID: 8288659. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.8288659
867 Smorgick Y, Mirovsky Y, Baker KC . Predictors of back pain in adolescent idiopathic scoliosis surgical candidates. Journal of Pediatric Orthopedics. 2013;333:289-92. PMID: 23482265. KQ1E12, KQ2E12, KQ3E12, KQ4E6a, KQ5E12, KQ6E12.23482265
868 Smyrnis PN, Sekouris N, Papadopoulos G. Surgical assessment of the proximal thoracic curve in adolescent idiopathic scoliosis. European Spine Journal. 2009;184:522-30. PMID: 19219467. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.19219467
869 Smyrnis PN, Valavanis J, Alexopoulos A . School screening for scoliosis in Athens. Journal of Bone & Joint Surgery - British Volume. 1979;2:215-7. PMID: 438274. KQ1E6, KQ2E7, KQ3E12, KQ4E6, KQ5E6, KQ6E12.438274
870 Smyrnis T, Antoniou D, Valavanis J . Idiopathic scoliosis: characteristics and epidemiology. Orthopedics. 1987;106:921-6. PMID: 3615286. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.3615286
871 Snyder BD, Katz DA, Myers ER . Bone density accumulation is not affected by brace treatment of idiopathic scoliosis in adolescent girls. Journal of Pediatric Orthopedics. 2005;254:423-8. PMID: 15958888. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E10.15958888
872 Soultanis KC, Payatakes AH, Chouliaras VT . Rare causes of scoliosis and spine deformity: experience and particular features. Scoliosis. 2007;20:15. PMID: 17956633. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.17956633
873 Spanyer JM, Crawford CH3rd,Canan CE . Health-related quality-of-life scores, spine-related symptoms, and reoperations in young adults 7 to 17 years after surgical treatment of adolescent idiopathic scoliosis. American Journal of Orthopedics (Chatham, Nj). 2015;441:26-31. PMID: 25566553. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E7c.25566553
874 Sperandio EF, Alexandre AS, Yi LC . Functional aerobic exercise capacity limitation in adolescent idiopathic scoliosis. Spine Journal: Official Journal of the North American Spine Society. 2014;1410:2366-72. PMID: 24486477. KQ1E12, KQ2E12, KQ3E12, KQ4E4, KQ5E12, KQ6E12.24486477
875 Sponseller PD. Bracing for adolescent idiopathic scoliosis in practice today. Journal of Pediatric Orthopedics. 2011;31:S53-60. PMID: 21173620. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21173620
876 Spoonamore MJ, Dolan LA, Weinstein SL. Use of the Rosenberger brace in the treatment of progressive adolescent idiopathic scoliosis. Spine (03622436). 2004;2913:1458-1464. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
877 Stasikelis PJ, Pugh LI, Allen BL . Surgical corrections in scoliosis: a meta-analysis. Journal of Pediatric Orthopaedics, Part B. 1998;72:111-6. PMID: 9597585. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.9597585
878 Stephen JP. Idiopathic adolescent scoliosis. Australian Family Physician. 1984;133:180-1, 184. PMID: 6743122. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.6743122
879 Stirling AJ, Howel D, Millner PA . Late-onset idiopathic scoliosis in children six to fourteen years old. A cross-sectional prevalence study. Journal of Bone & Joint Surgery - American Volume. 1996;789:1330-6. PMID: 8816647. KQ1E6, KQ2E7c, KQ3E12, KQ4E12, KQ5E6, KQ6E12.8816647
880 Stricker SJ, Sher JS. Freeze-dried cortical allograft in posterior spinal arthrodesis: use with segmental instrumentation for idiopathic adolescent scoliosis. Orthopedics. 1997;2011:1039-43. PMID: 9397432. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.9397432
881 Studer D, Awais A, Williams N . Selective fusion in adolescent idiopathic scoliosis: a radiographic evaluation of risk factors for imbalance. Journal of Childrens Orthopaedics. 2015;92:153-60. PMID: 25845647. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9b.25845647
882 Sturz H, Hinterberger J, Matzen K . Damage analysis of the Harrington rod fracture after scoliosis operation. Archives of Orthopaedic & Traumatic Surgery. 1979;9542371:113-22. PMID: 526122. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.526122
883 Subramanyam R, Schaffzin J, Cudilo EM . Systematic review of risk factors for surgical site infection in pediatric scoliosis surgery. Spine Journal: Official Journal of the North American Spine Society. 2015;156:1422-31. PMID: 25796355. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.25796355
884 Sucato DJ, Hedequist D, Karol LA. Operative correction of adolescent idiopathic scoliosis in male patients. A radiographic and functional outcome comparison with female patients. Journal of Bone & Joint Surgery - American Volume. 2004;9:2005-14. PMID: 15342764. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E5a.15342764
885 Sudo Hideki,Ito Manabu,Kaneda Kiyoshi,Shono Yasuhiro,Abumi Kuniyoshi Long-Term Outcomes of Anterior Dual-Rod Instrumentation for Thoracolumbar and Lumbar Curves in Adolescent Idiopathic Scoliosis: A Twelve to Twenty-three-Year Follow-up Study. Journal of Bone & Joint Surgery, American Volume. 2013;8:e491-8 1p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
886 Suh PB, MacEwen GD. Idiopathic scoliosis in males. A natural history study. Spine. 1988;1310:1091-5. PMID: 3206265. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.3206265
887 Sun X, Chu WC, Cheng JC . Do adolescents with a severe idiopathic scoliosis have higher locations of the conus medullaris than healthy adolescents?. Journal of Pediatric Orthopedics. 2008;286:669-73. PMID: 18724206. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.18724206
888 Sun X, Wang B, Qiu Y . Outcomes and predictors of brace treatment for girls with adolescent idiopathic scoliosis. Orthopaedic Audio-Synopsis Continuing Medical Education [Sound Recording]. 2010;24:285-90. PMID: 22009964. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22009964
889 Sun X,Liu W-J,Xu L-L,Ding Q,Mao S-H,Qian B-P,Zhu Z-Z,Qiu Y Does brace treatment impact upon the flexibility and the correctability of idiopathic scoliosis in adolescents?. European Spine Journal. 2013;222:268-73. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
890 Swisher AK. Impact of a physical rehabilitation program on the respiratory function of adolescents with idiopathic scoliosis. Cardiopulmonary Physical Therapy Journal (American Physical Therapy Association, Cardiopulmonary Section). 2006;174:138-138 1p. PMID: 0. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
891 Takayama K and Nakamura H. and Matsuda H.. Low back pain in patients treated surgically for scoliosis: longer than sixteen-year follow-up. Spine (03622436). 2009;3420:2198-2204. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
892 Takayama K and Nakamura H. and Matsuda H.. Quality of life in patients treated surgically for scoliosis: longer than sixteen-year follow-up. Spine (03622436). 2009;3420:2179-2184. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E8, KQ5E12, KQ6E8.
893 Tan KJ, Moe MM, Vaithinathan R . Curve progression in idiopathic scoliosis: follow-up study to skeletal maturity. Spine (03622436). 2009;347:697-700 4p. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
894 Tarrant RC, Queally JM, O'Loughlin PF . Preoperative curves of greater magnitude (>70degree) in adolescent idiopathic scoliosis are associated with increased surgical complexity, higher cost of surgical treatment and a delayed return to function. Irish Journal of Medical Science. 2016;1852:463-71. PMID: 26742534. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c, KQ6E9c.26742534
895 Tarrant Roslyn C, Oloughlin Padhraig F, Lynch Sam,Queally Joseph M . Timing and Predictors of Return to Short-term Functional Activity in Adolescent Idiopathic Scoliosis After Posterior Spinal Fusion: A Prospective Study. Spine (03622436). 2014;3918:1471-1478. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
896 Taylor HJ, Harding I, Hutchinson J . Identifying scoliosis in population-based cohorts: development and validation of a novel method based on total-body dual-energy x-ray absorptiometric scans. Calcified Tissue International. 2013;926:539-47. PMID: 23456028. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.23456028
897 Taylor JR, Liston CB, Twomey LT. Scoliosis: a review. Australian Journal of Physiotherapy. 1982;283:20-5. PMID: 25025846. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2, KQ6E2.25025846
898 Taylor JR, Slinger BS. Scoliosis screening and growth in Western Australian students. Medical Journal of Australia. 1980;110:475-8. PMID: 7412681. KQ1E9, KQ2E9, KQ3E12, KQ4E12, KQ5E9, KQ6E12.7412681
899 Telang SS, Suh SW, Song HR . A large adolescent idiopathic scoliosis curve in a skeletally immature patient: is early surgery the correct approach? Overview of available evidence. Journal of Spinal Disorders & Techniques. 2006;197:534-40. PMID: 17021420. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.17021420
900 Terver S, Kleinman R, Bleck EE. Growth landmarks and the evolution of scoliosis: a review of pertinent studies on their usefulness. Developmental Medicine & Child Neurology. 1980;225:675-84. PMID: 7439559. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.7439559
901 Tessakov DK. 3D brace correction of spinal deformities in growing patients with severe forms of idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;880:235-8. PMID: 15456040. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15456040
902 Theologis AA, Anaya A, Sabatini C . Surgical Consent of Children and Guardians For The Treatment of Adolescent Idiopathic Scoliosis is Incompletely Informed. Spine (Phila Pa 1976). 2015;:. PMID: 26335670. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.26335670
903 Theologis AA, Cahill P, Auriemma M . Vertebral body stapling in children younger than 10 years with idiopathic scoliosis with curve magnitude of 30degree to 39degree. Spine. 2013;3825:E1583-8. PMID: 23963018. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.23963018
904 Theologis Alexander A. and Cahill Patrick and Auriemma Mike and Betz Randal and Diab Mohammad Vertebral body stapling in children younger than 10 years with idiopathic scoliosis with curve magnitude of 30Â° to 39Â°. Spine (03622436). 2013;3825:E1583-8 1p. PMID: . KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
905 Theroux J, Grimard G, Beausejour M . Knowledge and management of Adolescent Idiopathic Scoliosis among family physicians, pediatricians, chiropractors and physiotherapists in Quebec, Canada: An exploratory study. Journal of the Canadian Chiropractic Association. 2013;573:251-9. PMID: 23997251. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.23997251
906 Theroux J, Le May S, Fortin C . Prevalence and management of back pain in adolescent idiopathic scoliosis patients: A retrospective study. Pain Research & Management. 2015;203:153-7. PMID: 25831076. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.25831076
907 Thomas KA, Cook SD, Skalley TC . Lumbar spine and femoral neck bone mineral density in idiopathic scoliosis: a follow-up study. Journal of Pediatric Orthopedics. 1992;122:235-40. PMID: 1552029. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.1552029
908 Thometz J, Liu XC, Reineck J . Changes of three-dimensional back contour following posterior fusion for idiopathic scoliosis. Studies in Health Technology & Informatics. 2006;1230:577-81. PMID: 17108490. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.17108490
909 Thometz JG, Emans JB. A comparison between spinous process and sublaminar wiring combined with Harrington distraction instrumentation in the management of adolescent idiopathic scoliosis. Journal of Pediatric Orthopedics. 1988;82:129-32. PMID: 3350944. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.3350944
910 Thompson F, Walsh M, Colville J. Moire topography: a method of screening for adolescent idiopathic scoliosis. Irish medical journal. 1985;786:162-5. PMID: 0. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
911 Thompson GH, Wilber RG, Shaffer JW . Segmental spinal instrumentation in idiopathic scoliosis. A preliminary report. Spine. 1985;107:623-30. PMID: 4071271. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.4071271
912 Thompson Mark E, Kohring Jessica M, McFann Kim,McNair Bryan,Hansen Jennifer K . Predicting excessive hemorrhage in adolescent idiopathic scoliosis patients undergoing posterior spinal instrumentation and fusion. Spine Journal. 2014;148:1392-1398. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
913 Thorsness RJ, Faust JR, Behrend CJ . Nonsurgical Management of Early-onset Scoliosis. Journal of the American Academy of Orthopaedic Surgeons. 2015;239:519-28. PMID: 26306805. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.26306805
914 Tis JE and O'Brien MF. and Newton PO. and Lenke LG. and Clements DH. and Harms J. and Betz RR. Adolescent idiopathic scoliosis treated with open instrumented anterior spinal fusion: five-year follow-up. Spine (03622436). 2010;351:64-70 7p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
915 Toledo PC, Mello DB, Araújo ME . Global Posture Reeducation effects in students with scoliosis. Fisioterapia e Pesquisa. 2011;184:329-34. PMID: 0. KQ1E12, KQ2E12, KQ3E1, KQ4E1, KQ5E12, KQ6E1.
916 Tolo V, Gillespie R. The use of shortened periods of rigid postoperative immobilization in the surgical treatment of idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1981;637:1137-45. PMID: 7276049. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.7276049
917 Tolo VT Surgical treatment of adolescent idiopathic scoliosis. Instr Course Lect. 1989;380:143-56. PMID: 2649566. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.2649566
918 Tomaszewski R, Janowska M. Psychological aspects of scoliosis surgery in children. Studies in Health Technology & Informatics. 2012;1760:428-32. PMID: 22744546. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.22744546
919 Tones M, Moss N, Polly DW . A review of quality of life and psychosocial issues in scoliosis. Spine (03622436). 2006;3126:3027-3038. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
920 Tones MJ, Moss ND. The impact of patient self assessment of deformity on HRQL in adults with scoliosis. Scoliosis. 2007;20:14. PMID: 17935634. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E12, KQ6E6.17935634
921 Torell G, Nordwall A, Nachemson A. The changing pattern of scoliosis treatment due to effective screening. Journal of Bone & Joint Surgery - American Volume. 1981;633:337-41. PMID: 7204428. KQ1E6, KQ2E6, KQ3E6, KQ4E12, KQ5E6, KQ6E6.7204428
922 Toye F, Williamson E, Williams MA . What Value Can Qualitative Research Add to Quantitative Research Design? An Example From an Adolescent Idiopathic Scoliosis Trial Feasibility Study. Qual Health Res. 2016;:. PMID: 27509903. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.27509903
923 Travaglini FH. Scoliosis: a problem of treatment. Bulletin - Hospital for Joint Diseases. 1970;312:150-69. PMID: 5491944. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.5491944
924 Trott AW. Orthopedic Problems in Adolescents. Medical Clinics of North America. 1965;490:467-77. PMID: 14281466. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.14281466
925 Tsutsui S, Pawelek J, Bastrom T . Dissecting the effects of spinal fusion and deformity magnitude on quality of life in patients with adolescent idiopathic scoliosis. Spine (03622436). 2009;3418:E653-8 1p. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
926 Ueno M, Takaso M, Nakazawa T . A 5-year epidemiological study on the prevalence rate of idiopathic scoliosis in Tokyo: school screening of more than 250,000 children. Journal of Orthopaedic Science. 2011;161:42375. PMID: 21293892. KQ1E6, KQ2E7, KQ3E12, KQ4E12, KQ5E6, KQ6E12.21293892
927 Ugwonali OF, Lomas G, Choe JC . Effect of bracing on the quality of life of adolescents with idiopathic scoliosis. Spine Journal: Official Journal of the North American Spine Society. 2004;43:254-60. PMID: 15125845. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E12, KQ6E6c.15125845
928 Unnikrishnan R, Renjitkumar J, Menon VK. Adolescent idiopathic scoliosis: Retrospective analysis of 235 surgically treated cases. Indian Journal of Orthopaedics. 2010;441:35-41. PMID: 20165675. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.20165675
929 Upadhyay SS, Ho EK, Gunawardene WM . Changes in residual volume relative to vital capacity and total lung capacity after arthrodesis of the spine in patients who have adolescent idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1993;751:46-52. PMID: 8419390. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.8419390
930 Upadhyay SS, Hsu LC, Ho EK . Disproportionate body growth in girls with adolescent idiopathic scoliosis. A longitudinal study. Spine. 1991;16:S343-7. PMID: 1785085. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.1785085
931 Upasani VV, Caltoum C, Petcharaporn M . Adolescent idiopathic scoliosis patients report increased pain at five years compared with two years after surgical treatment. Spine (03622436). 2008;3310:1107-1112. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6c.
932 Urquhart DS, Gallella S, Gidaris D . Six-year follow-up study on the effect of combined anterior and posterior spinal fusion on lung function and quality of life in young people with adolescent idiopathic scoliosis. Arch Dis Child. 2014;9910:922-926 5p. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.
933 Uyttendaele D, Lootens T, Overschelde J . Rod rotation of translation: a prospective study with matched controls in adolescent idiopathic scoliosis. Euro Spine J. 2002;110:S15. PMID: 0. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
934 Valentine LE. Alteration in the body image of adolescent females braced as a treatment for adolescent idiopathic scoliosis. 1991;0:146 p-146. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
935 Van Rhijn LW, Plasmans CM, Veraart BE. Changes in curve pattern after brace treatment for idiopathic scoliosis. Acta Orthop Scand. 2002;733:277-281 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
936 Vasiliadis E, Grivas TB, Gkoltsiou K. Development and preliminary validation of Brace Questionnaire (BrQ): a new instrument for measuring quality of life of brace treated scoliotics. Scoliosis. 2006;10:7. PMID: 16759366. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.16759366
937 Vasiliadis E, Grivas TB. Quality of life after conservative treatment of adolescent idiopathic scoliosis. Studies in Health Technology & Informatics. 2008;1350:409-13. PMID: 18401108. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18401108
938 Vedantam R, Crawford AH. The role of preoperative pulmonary function tests in patients with adolescent idiopathic scoliosis undergoing posterior spinal fusion. Spine. 1997;2223:2731-4. PMID: 9431606. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E9.9431606
939 Velezis MJ, Sturm PF, Cobey J. Scoliosis screening revisited: findings from the District of Columbia. Journal of Pediatric Orthopedics. 2002;226:788-91. PMID: 12409909. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.12409909
940 Vernacchio L, Trudell EK, Hresko MT . A quality improvement program to reduce unnecessary referrals for adolescent scoliosis. Pediatrics. 2013;1313:e912-20. PMID: 23420923. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23420923
941 Vesely DG, Blaylock HI, Harrison J. Scoliosis treatment by spinal fusion, Harrington instrumentation, and Milwaukee brace. Alabama Journal of Medical Sciences. 1979;164:370-3. PMID: 546243. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.546243
942 Viejo MAG, Perramon A, Blasco MD. Mid-term effectiveness of a new corset (CCR) for the treatment of idiopathic scoliosis. Rehabilitacion. 1998;321:25-33 9p. PMID: 107177254. KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
943 Vigneswaran HT, Grabel ZJ, Eberson CP . Surgical treatment of adolescent idiopathic scoliosis in the United States from 1997 to 2012: an analysis of 20,346 patients. Journal of Neurosurgery. Pediatrics.. 2015;163:322-8. PMID: 26114991. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.26114991
944 Vijvermans V, Fabry G, Nijs J. Factors determining the final outcome of treatment of idiopathic scoliosis with the Boston brace: a longitudinal study. Journal of Pediatric Orthopaedics, Part B. 2004;133:143-9. PMID: 15083112. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.15083112
945 Villemure I, Aubin CE, Dansereau J . Biomechanical modelling of spinal growth modulation for the study of adolescent scoliotic deformities: a feasibility study. Studies in Health Technology & Informatics. 2002;880:373-7. PMID: 15456064. KQ1E2, KQ2E2, KQ3E12, KQ4E2, KQ5E2, KQ6E12.15456064
946 Villemure I, Aubin CE, Grimard G . Evolution of 3D deformities in adolescents with progressive idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;910:54-8. PMID: 15457693. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.15457693
947 Viviani GR, Budgell L, Dok C . Assessment of accuracy of the scoliosis school screening examination. Am J Public Health. 1984;745:497-8. PMID: 6711727. KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.6711727
948 Walker AP, Dickson RA. School screening and pelvic tilt scoliosis. Lancet. 1984;28395:152-3. PMID: 6146046. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.6146046
949 Wang C, Zhao Y, He S . Effect of preoperative brace treatment on quality of life in adolescents with idiopathic scoliosis following corrective surgery. Orthopedics. 2009;328:563-563 1p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
950 Wang L, Wang YP, Yu B . Relation between self-image score of SRS-22 with deformity measures in female adolescent idiopathic scoliosis patients. Orthopaedics & traumatology, surgery & research. 2014;1007:797-801. PMID: 25282478. KQ1E12, KQ2E12, KQ3E12, KQ4E4, KQ5E12, KQ6E12.25282478
951 Wang WJ, Huang AB, Zhu ZZ . Does curve convexity affect the surgical outcomes of thoracic adolescent idiopathic scoliosis?. European journal of orthopaedic surgery & traumatologie. 2014;0:S103-10. PMID: 24532048. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.24532048
952 Wang WJ, Hung VW, Lam TP . The association of disproportionate skeletal growth and abnormal radius dimension ratio with curve severity in adolescent idiopathic scoliosis. European Spine Journal. 2010;195:726-31. PMID: 20047062. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.20047062
953 Wang WW and Xia CW. and Zhu F. and Zhu ZZ. and Wang B. and Wang SF. and Yeung BH. and Lee SK. and Cheng JC. and Qiu Y.. Correlation of Risser sign, radiographs of hand and wrist with the histological grade of iliac crest apophysis in girls with adolescent idiopathic scoliosis. Spine (03622436). 2009;3417:1849-1854. PMID: . KQ1E4, KQ2E4, KQ3E12, KQ4E12, KQ5E4, KQ6E12.
954 Wang Y, Fei Q, Qiu G . Anterior spinal fusion versus posterior spinal fusion for moderate lumbar/thoracolumbar adolescent idiopathic scoliosis: a prospective study. Spine (03622436). 2008;3320:2166-2172. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
955 Wang Y, Qiu G, Yu B . The changes of the interspace angle after anterior correction and instrumentation in adolescent idiopathic scoliosis patients. Journal of Orthopaedic Surgery. 2007;20:17. PMID: 17967174. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.17967174
956 Ward K. and Ogilvie JW. and Singleton MV. and Chettier R. and Engler G. and Nelson LM. Validation of DNA-Based Prognostic Testing to Predict Spinal Curve Progression in Adolescent Idiopathic Scoliosis. Spine (03622436). 2010;3525:E1455-64 1. PMID: . KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.
957 Watanabe K, Hasegawa K, Hirano T . Evaluation of postoperative residual spinal deformity and patient outcome in idiopathic scoliosis patients in Japan using the scoliosis research society outcomes instrument. Spine (03622436). 2007;325:550-554 5p. PMID: 0. KQ1E12, KQ2E12, KQ3E9c, KQ4E12, KQ5E12, KQ6E9.
958 Watanabe K, Hasegawa K, Hirano T . Use of the Scoliosis Research Society Outcomes Instrument to evaluate patient outcome in untreated idiopathic scoliosis patients in Japan. Part I: comparison with nonscoliosis group: preliminary/limited review in a Japanese population. Spine (03622436). 2005;3010:1197-1201. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
959 Watanabe K, Hasegawa K, Hurano T . Use of the Scoliosis Research Society Outcomes Instrument to evaluate patient outcome in untreated idiopathic scoliosis patients in Japan. Part II: relation between spinal deformity and patient outcomes. Spine (03622436). 2005;3010:1202-1205. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.
960 Watts HG, Hall JE, Stanish W. The Boston brace system for the treatment of low thoracic and lumbar scoliosis by the use of a girdle without superstructure. Clinical Orthopaedics & Related Research. 1977;0126:87-92. PMID: 598144. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.598144
961 Weatherley CR, Draycott V, O'Brien JF . The rib deformity in adolescent idiopathic scoliosis. A prospective study to evaluate changes after Harrington distraction and posterior fusion. Journal of Bone & Joint Surgery - British Volume. 1987;692:179-82. PMID: 3818745. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.3818745
962 Weber B, Smith JP, Briscoe WA . Pulmonary function in asymptomatic adolescents with idiopathic scoliosis. American Review of Respiratory Disease. 1975;1114:389-97. PMID: 235869. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.235869
963 Wei H, Xu J, Jiang Z . Effect of a Traditional Chinese Medicine combined therapy on adolescent idiopathic scoliosis: a randomized controlled trial. Journal of traditional Chinese medicine = Chung i tsa chih ying wen pan / sponsored by All-China Association of Traditional Chinese Medicine, Academy of Traditional Chinese Medicine. 2015;355:514-9. PMID: 0. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
964 Weigert Kp,Nygaard Lm,Christensen Fb,Hansen Es,Bunger C Outcome in adolescent idiopathic scoliosis after brace treatment and surgery assessed by means of the Scoliosis Research Society Instrument 24. European Spine Journal. 2006;157:1108-17. PMID: 0. KQ1E12, KQ2E12, KQ3E9b, KQ4E9b, KQ5E12, KQ6E9b.
965 Weinstein SL, Dolan LA, Spratt KF . Health and function of patients with untreated idiopathic scoliosis: a 50-year natural history study. JAMA. 2003;2895:559-67. PMID: 12578488. KQ1E12, KQ2E12, KQ3E12, KQ4E9b, KQ5E12, KQ6E12.12578488
966 Weinstein SL, Zavala DC, Ponseti IV. Idiopathic scoliosis: long-term follow-up and prognosis in untreated patients. Journal of Bone & Joint Surgery - American Volume. 1981;635:702-12. PMID: 6453874. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.6453874
967 Weinstein Sl,Dolan L Bracing in Adolescent Idiopathic Scoliosis Trial (BrAIST).Http://clinicaltrials.gov/ct2/show/NCT00448448. 2009;:. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
968 Weinstein SL. Adolescent idiopathic scoliosis: prevalence and natural history. Instr Course Lect. 1989;380:115-28. PMID: 2649564. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.2649564
969 Weinstein SL. Idiopathic scoliosis. Natural history. Spine. 1986;118:780-3. PMID: 3810292. KQ1E12, KQ2E12, KQ3E12, KQ4E6b, KQ5E12, KQ6E12.3810292
970 Weinstein SL. Natural history. Spine (03622436). 1999;2424:2592-2600. PMID: 0. KQ1E12, KQ2E12, KQ3E12, KQ4E9, KQ5E12, KQ6E12.
971 Weinstein SL and Ponseti IV.. Curve progression in idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1983;654:447-55. PMID: 6833318. KQ1E12, KQ2E12, KQ3E12, KQ4E6b, KQ5E12, KQ6E12.6833318
972 Weis JC, Betz RR, Clements DH . Prevalence of perioperative complications after anterior spinal fusion for patients with idiopathic scoliosis. J Spinal Disord. 1997;105:371-5. PMID: 9355051. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.9355051
973 Weiss H, Weiss G, Petermann F. Incidence of curvature progression in idiopathic scoliosis patients treated with scoliosis in-patient rehabilitation (SIR): an age- and sex-matched controlled study. Pediatric Rehabilitation. 2003;61:23-30 8p. PMID: 0. KQ1E12, KQ2E12, KQ3E10, KQ4E12, KQ5E12, KQ6E6.
974 Weiss H, Weiss G, Schaar H. Incidence of surgery in conservatively treated patients with scoliosis. Pediatric Rehabilitation. 2003;62:111-118 8p. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
975 Weiss H, Weiss GM. Brace treatment during pubertal growth spurt in girls with idiopathic scoliosis (IS): a prospective trial comparing two different concepts. Pediatric Rehabilitation. 2005;83:199-206 8p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.
976 Weiss HR, Bohr S, Jahnke A . Acupucture in the treatment of scoliosis - a single blind controlled pilot study. Scoliosis. 2008;30:4. PMID: 18226193. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.18226193
977 Weiss HR, Hawes MC. Adolescent idiopathic scoliosis, bracing and the Hueter-Volkmann principle. Spine Journal: Official Journal of the North American Spine Society. 2004;44:484-5; aut. PMID: 15246310. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.15246310
978 Weiss HR, Lohschmidt K, el-Obeidi N . Preliminary results and worst-case analysis of in patient scoliosis rehabilitation. Pediatric Rehabilitation. 1997;11:35-40. PMID: 9689236. KQ1E12, KQ2E12, KQ3E10, KQ4E12, KQ5E12, KQ6E6.9689236
979 Weiss HR, Reichel D, Schanz J . Deformity related stress in adolescents with AIS. Studies in Health Technology & Informatics. 2006;1230:347-51. PMID: 17108450. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.17108450
980 Weiss HR, Weiss G, Schaar HJ. Conservative management in patients with scoliosis--does it reduce the incidence of surgery?. Studies in Health Technology & Informatics. 2002;910:342-7. PMID: 15457752. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15457752
981 Weiss HR, Werkmann M. Soft braces in the treatment of Adolescent Idiopathic Scoliosis (AIS) - Review of the literature and description of a new approach. Scoliosis. 2012;71:11. PMID: 22640574. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.22640574
982 Weiss Hr,Heckel I,Stephan C Application of passive transverse forces in the rehabilitation of spinal deformities: a randomized controlled study. Studies in health technology and informatics. 2002;88:304-8. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.15456051
983 Weiss Hr,Weiss G Curvature progression in patients treated with scoliosis in-patient rehabilitation--a sex and age matched controlled study. Studies in health technology and informatics. 2002;91:352-6. PMID: 0. KQ1E12, KQ2E12, KQ3E10, KQ4E12, KQ5E12, KQ6E6.15457754
984 Weiss HR. Adolescent idiopathic scoliosis (AIS) - an indication for surgery? A systematic review of the literature. Disability & Rehabilitation. 2008;3010:799-807. PMID: 18432438. KQ1E12, KQ2E12, KQ3E10, KQ4E12, KQ5E12, KQ6E10.18432438
985 Weiss HR. Influence of an in-patient exercise program on scoliotic curve. Ital J Orthop Traumatol. 1992;183:395-406. PMID: 1308886. KQ1E12, KQ2E12, KQ3E12, KQ4E6d, KQ5E12, KQ6E12.1308886
986 Weiss HR. Is there a body of evidence for the treatment of patients with Adolescent Idiopathic Scoliosis (AIS)?. Scoliosis. 2007;20:19. PMID: 18163917. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.18163917
987 Weiss HR. The progression of idiopathic scoliosis under the influence of a physiotherapy rehabilitation programme. Physiotherapy. 1992;7811:815-821 7p. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
988 Weiss HR and Goodall D.. The treatment of adolescent idiopathic scoliosis (AIS) according to present evidence. A systematic review. European journal of physical & rehabilitation medicine.. 2008;442:177-93. PMID: 18418338. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.18418338
989 Weisz I and Jefferson RJ. and Carr AJ. and Turner-Smith AR. and McInerney A. and Houghton GR.. Back shape in brace treatment of idiopathic scoliosis. Clin Orthop Relat Res. 1989;0240:157-63. PMID: 2917429. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.2917429
990 Wessberg, Rune H, Anders N. Night Time Providence Bracing Compared to Fulltime Boston Bracing in Adolescent Idiopathic Scoliosis. A Prospective Randomized Study. Spine: Affiliated Society Meeting Abstracts.2011;:. PMID: 0. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
991 Westrick ER, Ward WT. Adolescent idiopathic scoliosis: 5-year to 20-year evidence-based surgical results. Journal of Pediatric Orthopedics. 2011;31:S61-8. PMID: 21173621. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21173621
992 Wever DJ, Tønseth KA, Veldhuizen AG . Curve progression and spinal growth in brace treated idiopathic scoliosis. Clinical Orthopaedics & Related Research,. 2000;:. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
993 Wever DJ, Tonseth KA, Veldhuizen AG. Curve progression and spinal growth in brace treated idiopathic scoliosis. Studies in Health Technology & Informatics. 2002;910:387-92. PMID: 15457762. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.15457762
994 Wickers FC, Bunch WH, Barnett PM. Psychological factors in failure to wear the Milwaukee brace for treatment of idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1977;0126:62-6. PMID: 598141. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.598141
995 Wiegersma PA, Hofman A, Zielhuis GA. The effect of school screening on surgery for adolescent idiopathic scoliosis. European Journal of Public Health. 1998;83:237-240 4p. PMID: 0. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.
996 Wiley JW, Thomson JD, Mitchell TM . Effectiveness of the Boston brace in treatment of large curves in adolescent idiopathic scoliosis. Spine (03622436). 2000;2518:2326-2332. PMID: 0. KQ1E12, KQ2E12, KQ3E9d, KQ4E12, KQ5E12, KQ6E6.
997 Will RE. and Stokes IA. and Qiu X. and Walker MR. and Sanders JO. Cobb angle progression in adolescent scoliosis begins at the intervertebral disc. Spine (03622436). 2009;3425:2782-2786. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
998 Willems PC. and Elmans L. and Anderson PG. and Jacobs WC. and van der Schaaf DB. and de Kleuver M. The value of a pantaloon cast test in surgical decision making for chronic low back pain patients: a systematic review of the literature supplemented with a prospective cohort study. European Spine Journal. 2006;1510:1487-1494. PMID: 12006009053. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.
999 Willers U, Normelli H, Aaro S . Long-term results of Boston brace treatment on vertebral rotation in idiopathic scoliosis. Spine (Phila Pa 1976). 1993;184:432-5. PMID: 8470002. KQ1E12, KQ2E12, KQ3E9, KQ4E6a, KQ5E12, KQ6E12.8470002
1000 Willers U. and Hedlund R. and Aaro S. and Normelli H. and Westman L. Long-term results of Harrington instrumentation in idiopathic scoliosis. Spine (Phila Pa 1976). 1993;186:713-7. PMID: 8516700. KQ1E12, KQ2E12, KQ3E8, KQ4E8, KQ5E12, KQ6E8.8516700
1001 Williams Mark A, Heine Peter J, Williamson Esther M . Active Treatment for Idiopathic Adolescent Scoliosis (ACTIvATeS): a feasibility study. Health Technology Assessment. 2015;1942:1-242 242p. PMID: . KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.
1002 Willner S, Uden A. A prospective prevalence study of scoliosis in Southern Sweden. Acta Orthop Scand. 1982;532:233-7. PMID: 7136569. KQ1E6, KQ2E7c, KQ3E12, KQ4E12, KQ5E6, KQ6E12.7136569
1003 Willner S. Effect of the Boston thoracic brace on the frontal and sagittal curves of the spine. Acta Orthop Scand. 1984;554:457-60. PMID: 6475514. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.6475514
1004 Willner S. Growth in height of children with scoliosis. Acta Orthop Scand. 1974;456:854-66. PMID: 4463687. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.4463687
1005 Willner S. Moire topography--a method for school screening of scoliosis. Archives of Orthopaedic & Traumatic Surgery. 1979;953:181-5. PMID: 547958. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.547958
1006 Wilson PL, Newton PO, Wenger DR . A multicenter study analyzing the relationship of a standardized radiographic scoring system of adolescent idiopathic scoliosis and the Scoliosis Research Society outcomes instrument. Spine. 2002;2718:2036-40. PMID: 12634565. KQ1E12, KQ2E12, KQ3E6, KQ4E6, KQ5E12, KQ6E6.12634565
1007 Wilson RL, Levine DB, Doherty JH Surgical treatment of idiopathic scoliosis. Clinical Orthopaedics & Related Research. 1971;810:34-47. PMID: 5133042. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.5133042
1008 Winiarski A, Zarzycki D, Koniarski A . The natural history of idiopathic scoliosis. Ortopedia Traumatologia Rehabilitacja. 2005;71:7-Jan. PMID: 17675949. KQ1E12, KQ2E12, KQ3E12, KQ4E1, KQ5E12, KQ6E12.17675949
1009 Winter RB, Lonstein JE. A meta-analysis of the literature on the issue of selective thoracic fusion for the King-Moe type II curve pattern in adolescent idiopathic scoliosis. Spine. 2003;289:948-52. PMID: 12942014. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.12942014
1010 Winter RB, Lovell WW, Moe JH. Excessive thoracic lordosis and loss of pulmonary function in patients with idiopathic scoliosis. Journal of Bone & Joint Surgery - American Volume. 1975;577:972-7. PMID: 1184646. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E8b.1184646
1011 Winter RB, Moe JH. Idiopathic scoliosis. Current concepts in the treatment. Minnesota Medicine. 1972;556:529-35. PMID: 4555908. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.4555908
1012 Winter RB. A tale of two brothers: ultra-long-term follow-up of juvenile idiopathic scoliosis. Journal of Spinal Disorders & Techniques. 2004;175:446-50. PMID: 15385887. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.15385887
1013 Winter RB. Spine deformity in children: Current concepts of diagnosis and treatment. Pediatric Annals. 1976;54:95-112. PMID: 817255. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.817255
1014 Winter RB. and Banta JV. and Engler G. Screening for scoliosis. JAMA. 1995;2733:185-6. PMID: 7807649. KQ1E6, KQ2E9, KQ3E12, KQ4E12, KQ5E9, KQ6E12.7807649
1015 Wnuk B, Blicharska I, Blaszczak E . The Impact of the Derotational Mobilization of Manual Therapy According to Kaltenborn-Evjenth on the Angle of Trunk Rotation in Patients with Adolescent Idiopathic Scoliosis - Pilot Study, Direct Observation. Ortopedia Traumatologia Rehabilitacja. 2015;174:343-50. PMID: 26468171. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E6.26468171
1016 Wong GT, Yuen VM, Chow BF . Persistent pain in patients following scoliosis surgery. European Spine Journal. 2007;1610:1551-6. PMID: 17410382. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.17410382
1017 Wong HK, Tan KJ. The natural history of adolescent idiopathic scoliosis. Indian Journal of Orthopaedics. 2010;441:42626. PMID: 20165671. KQ1E12, KQ2E12, KQ3E12, KQ4E2, KQ5E12, KQ6E12.20165671
1018 Wong MS, Evans JH. Biomechanical evaluation of the Milwaukee brace. Prosthetics & Orthotics International. 1998;221:54-67. PMID: 9604276. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.9604276
1019 Wong MS, Lee JT, Luk KD . Effect of different casting methods on adolescent idiopathic scoliosis. Prosthetics & Orthotics International. 2003;272:121-31. PMID: 14571942. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.14571942
1020 Wong MS, Liu WC. Critical review on non-operative management of adolescent idiopathic scoliosis. Prosthetics & Orthotics International. 2003;273:242-53. PMID: 14727706. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.14727706
1021 Wong Ms,Cheng Jc,Lo Kh A comparison of treatment effectiveness between the CAD/CAM method and the manual method for managing adolescent idiopathic scoliosis. Prosthetics and orthotics international. 2005;291:105-11. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
1022 Wood G. Brace modifications that can result in improved curve correction in idiopathic scoliosis. Scoliosis. 2014;91:2. PMID: 24593984. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.24593984
1023 Wright J, Herbert MA, Velazquez R . Morphologic and histochemical characteristics of skeletal muscle after long-term intramuscular electrical stimulation. Spine. 1992;177:767-70. PMID: 1502640. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.1502640
1024 Xu L, Qiu X, Sun X . Potential genetic markers predicting the outcome of brace treatment in patients with adolescent idiopathic scoliosis. European Spine Journal. 2011;2010:1757-64. PMID: 21691901. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.21691901
1025 Yagi M. and Hasegawa J. and Nagoshi N. and Iizuka S. and Kaneko S. and Fukuda K. and Takemitsu M. and Shioda M. and Machida M. Does the intraoperative tranexamic Acid decrease operative blood loss during posterior spinal fusion for treatment of adolescent idiopathic scoliosis?. Spine (03622436). 2012;3721:E1336-42 1. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
1026 Yagi Mitsuru and Takemitsu Masakazu and Machida Masafumi Chest Cage Angle Difference and Rotation of Main Thoracic Curve are Independent Risk Factors of Postoperative Shoulder Imbalance in Surgically Treated Patients With Adolescent Idiopathic Scoliosis. Spine (03622436). 2013;3819:E1209-15 1. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
1027 Yamamoto S, Shigematsu H, Kadono F . Adolescent Scoliosis Screening in Nara City Schools: A 23-Year Retrospective Cross-Sectional Study. Asian Spine Journal. 2015;93:407-15. PMID: 26097656. KQ1E6, KQ2E7a, KQ3E12, KQ4E12, KQ5E6, KQ6E12.26097656
1028 Yamauchi Y,Asaka Y,Chen Ws,Tsuji T,Yamaguchi T,Tsuruoka H Follow-up results of brace treatment of adolescent idiopathic scoliosis. Journal of the Japanese Orthopaedic Association. 1986;6011:1079-85. PMID: 0. KQ1E12, KQ2E12, KQ3E1, KQ4E12, KQ5E12, KQ6E1.
1029 Yang JH, Bhandarkar AW, Modi HN . Short apical rib resections thoracoplasty compared to conventional thoracoplasty in adolescent idiopathic scoliosis surgery. European Spine Journal. 2014;2312:2680-8. PMID: 24719039. KQ1E12, KQ2E12, KQ3E5, KQ4E12, KQ5E12, KQ6E5.24719039
1030 Yang JH, Bhandarkar AW, Rathanvelu B . Does delaying surgery in immature adolescent idiopathic scoliosis patients with progressive curve, lead to addition of fusion levels?. European Spine Journal. 2014;2312:2672-9. PMID: 24947183. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.24947183
1031 Yankey J, Dolan L, Clarke W . Practical implications of inter-rater agreement in a randomized controlled clinical trial. Clinical trials (London, England). 2010;74:436. PMID: 0. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.
1032 Yerger B Jr. Idiopathic scoliosis. Journal of the Mississippi State Medical Association. 1976;1711:321-4. PMID: 978720. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.978720
1033 Yim AP, Yeung HY, Hung VW . Abnormal skeletal growth patterns in adolescent idiopathic scoliosis-a longitudinal study until skeletal maturity. Spine (03622436). 2012;3718:E1148-54 1. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.
1034 Yim AP, Yeung HY, Hung VW . Abnormal skeletal growth patterns in adolescent idiopathic scoliosis--a longitudinal study until skeletal maturity. Spine. 2012;3718:E1148-54. PMID: 22565390. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.22565390
1035 Ylikoski M,Peltonen J,Poussa M Biological factors and predictability of bracing in adolescent idiopathic scoliosis. Journal of Pediatric Orthopaedics. 1989;96:680-3. PMID: . KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
1036 Ylikoski M. Growth and progression of adolescent idiopathic scoliosis in girls. Journal of Pediatric Orthopaedics, Part B. 2005;145:320-4. PMID: 16093941. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.16093941
1037 Ylikoski M. Spinal growth and progression of adolescent idiopathic scoliosis. European Spine Journal. 1993;14:236-9. PMID: 20054924. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.20054924
1038 Yoshihara Hiroyuki and Yoneoka Daisuke National Trends in Spinal Fusion for Pediatric Patients With Idiopathic Scoliosis: Demographics, Blood Transfusions, and In-hospital Outcomes. Spine (03622436). 2014;3914:1144-1150. PMID: . KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E5a.
1039 Young M, Hill DL, Zheng R . Reliability and accuracy of ultrasound measurements with and without the aid of previous radiographs in adolescent idiopathic scoliosis (AIS). European Spine Journal. 2015;247:1427-33. PMID: 25753005. KQ1E7, KQ2E7, KQ3E12, KQ4E12, KQ5E7, KQ6E12.25753005
1040 Youngman PM, Edgar MA. Posterior spinal fusion and instrumentation in the treatment of adolescent idiopathic scoliosis. Annals of the Royal College of Surgeons of England. 1985;675:313-7. PMID: 4051428. KQ1E12, KQ2E12, KQ3E8, KQ4E12, KQ5E12, KQ6E8.4051428
1041 Yrjonen T, Ylikoski M. Effect of growth velocity on the progression of adolescent idiopathic scoliosis in boys. Journal of Pediatric Orthopaedics, Part B. 2006;155:311-5. PMID: 16891955. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.16891955
1042 Yrjonen T,Ylikoski M,Schlenzka D,Kinnunen R,Poussa M Effectiveness of the Providence nighttime bracing in adolescent idiopathic scoliosis: A comparative study of 36 female patients. European Spine Journal. 2006;157:1139-43. PMID: 0. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.
1043 Yu B, Wang Y, Qiu G, . Effect of preoperative brace treatment on the mental health scores of SRS-22 and SF-36 questionnaire in surgically treated adolescent idiopathic scoliosis patients. Journal of Spinal Disorders & Techniques. 2013;:. PMID: 24281188. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.24281188
1044 Yu B, Wang Y, Qiu G . The influence of preoperative brace treatment on the pulmonary function test in female adolescent idiopathic scoliosis. Journal of Spinal Disorders & Techniques. 2013;266:E254-8. PMID: 23429322. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.23429322
1045 Yu Xuerong,Xiao Han, Wang Ruiying,Huang Yuguang Prediction of massive blood loss in scoliosis surgery from preoperative variables. Spine (03622436). 2013;384:350-355 6p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
1046 Zaba R. Influence of intensive movement rehabilitation in scout camps on ventilatory parameters of the respiratory tract in children with mild idiopathic scoliosis from highly polluted areas. Wiadomosci Lekarskie. 2002;:1003-8. PMID: 17474635. KQ1E12, KQ2E12, KQ3E12, KQ4E6, KQ5E12, KQ6E12.17474635
1047 Zaborowska-Sapeta K, Kowalski IM, Kotwicki T . Effectiveness of Cheneau brace treatment for idiopathic scoliosis: prospective study in 79 patients followed to skeletal maturity. Scoliosis. 2011;61:2. PMID: 21266084. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.21266084
1048 Zagra A, Lamartina C, Zerbi A The Risser plaster corset as the only method of correction in the surgical treatment of scoliosis. A study of 150 cases. Italian Journal of Orthopaedics & Traumatology. 1985;111:67-73. PMID: 4019166. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.4019166
1049 Zaina F, Donzelli S, Lusini M . Adolescent idiopathic scoliosis and eating disorders: is there a relation? Results of a cross-sectional study. Research in Developmental Disabilities. 2013;344:1119-24. PMID: 23357674. KQ1E12, KQ2E12, KQ3E12, KQ4E6b, KQ5E12, KQ6E12.23357674
1050 Zaina F, Donzelli S, Lusini M . Swimming and spinal deformities: a cross-sectional study. Journal of Pediatrics. 2015;1661:163-7. PMID: 25444007. KQ1E6, KQ2E6, KQ3E12, KQ4E12, KQ5E6, KQ6E12.25444007
1051 Zavatsky JM, Peters AJ, Nahvi FA . Disease severity and treatment in adolescent idiopathic scoliosis: the impact of race and economic status. Spine Journal: Official Journal of the North American Spine Society. 2015;155:939-43. PMID: 24099683. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6.24099683
1052 Zebracki K, Thawrani D, Oswald TS . Predictors of emotional functioning in youth after surgical correction of idiopathic scoliosis. Journal of Pediatric Orthopedics. 2013;336:624-7. PMID: 23774201. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.23774201
1053 Zein NN, Perrault J, Camilleri M Recurrent vomiting following Harrington rod instrumentation of the spine. Journal of Pediatric Gastroenterology & Nutrition. 1996;223:318-20. PMID: 8708888. KQ1E12, KQ2E12, KQ3E2, KQ4E12, KQ5E12, KQ6E2.8708888
1054 Zhang H, Sucato DJ. Regional differences in anatomical landmarks for placing anterior instrumentation of the thoracic spine in both normal patients and patients with adolescent idiopathic scoliosis. Spine. 2006;312:183-9. PMID: 16418638. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.16418638
1055 Zhang J, He D, Gao J . Changes in Life Satisfaction and Self-esteem in Patients with Adolescent Idiopathic Scoliosis With and Without Surgical Intervention. Spine (03622436). 2011;369:741-745 5p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
1056 Zhang J, Lou E, Le LH . Automatic Cobb measurement of scoliosis based on fuzzy Hough transform with vertebral shape prior. Journal of Digital Imaging. 2009;5:0. PMID: . KQ1E5, KQ2E5, KQ3E12, KQ4E12, KQ5E5, KQ6E12.
1057 Zhang J, Wang D, Chen Z . Decrease of self-concept in adolescent patients with mild to moderate scoliosis after conservative treatment. Spine (03622436). 2011;3615:E1004-8 1p. PMID: . KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
1058 Zhang Y, Yang Y, Dang X . Factors relating to curve progression in female patients with adolescent idiopathic scoliosis treated with a brace. European Spine Journal. 2015;242:244-8. PMID: 25424687. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E6c.25424687
1059 Zheng X, Sun X, Qian B . Evolution of the curve patterns during brace treatment for adolescent idiopathic scoliosis. European Spine Journal. 2012;216:1157-64. PMID: 22430541. KQ1E12, KQ2E12, KQ3E9, KQ4E12, KQ5E12, KQ6E9.22430541
1060 Zhu Z, Qiu Y, Wang B . Superior mesenteric artery syndrome following scoliosis surgery: its risk indicators and treatment strategy. Studies in Health Technology & Informatics. 2006;1230:610-4. PMID: 17108497. KQ1E12, KQ2E12, KQ3E6, KQ4E12, KQ5E12, KQ6E6.17108497
1061 Zhu Z, Xu L, Sun X . Is Brace Treatment Appropriate for Adolescent Idiopathic Scoliosis Patients Refusing Surgery with COBB Angle Between 40 and 50 Degrees. Clinical Spine Surgery : A Spine Publication. 2016;18:18. PMID: 27196136. KQ1E12, KQ2E12, KQ3E4, KQ4E12, KQ5E12, KQ6E4.
1062 Zorab PA. Proceedings: Prognosis for life in childhood scoliosis. Arch Dis Child. 1973;4810:824-5. PMID: 4749689. KQ1E12, KQ2E12, KQ3E12, KQ4E5, KQ5E12, KQ6E12.4749689