# Appendix B Ongoing Studies

We identified two potentially relevant ongoing or recently completed randomized clinical trials (RCTs) through two registries: ClinicalTrials.gov (http://clinicaltrials.gov), and the World Health Organization's International Clinical Trials Registry Platform (http://www.who.int/ictrp).

The “Multicenter Schroth Exercise Trial for Scoliosis,” or MultiSETS (NCT01610908),^1^ is a Canadian RCT of exercise for treatment of adolescent idiopathic scoliosis (AIS). The study will examine the effectiveness of the Schroth approach, which uses scoliosis-specific exercises to strengthen postural muscles and improve posture motor control. The study population is female adolescents with AIS aged 10 to 16 who have not yet reached skeletal maturity (Risser sign 0 to 3). One group is receiving usual care plus a 6-month Schroth exercise program involving five individual sessions with a Schroth therapist, daily exercises to complete at home, and weekly group therapy sessions. The control group will receive usual care. The final data collection was expected to occur in August 2016, and the estimated study completion date is in January 2017.

Another ongoing study, called “CONservative TReatment for Adolescent Idiopathic Scoliosis,” or CONTRAIS (NCT01761305),^2, 3^ is a Swedish RCT designed to compare the effectiveness of nighttime bracing, scoliosis-specific exercises, and physical activity in adolescents with AIS. The study population is male and female adolescents with AIS aged 9 to 17 who have not yet reached skeletal maturity. Patients will be randomized into one of three groups. All groups will receive a prescription for physical activity; one group additionally will engage in scoliosis-specific exercises, the second group additionally will receive nighttime bracing, and the third group (physical activity-only) will serve as the comparator. The final data collection is expected to occur in January 2019, and the estimated study completion date is December 2021.

## References

1 Multicenter Schroth Exercise Trial for Scoliosis (MultiSETS). Bethesda (MD): National Library of Medicine (US) [2016 August 26]. https://clinicaltrials.gov/ct2/show/record/NCT01610908.
2 Trial on Three Treatments for Scoliosis (CONTRAIS). Bethesda (MD): National Library of Medicine (US) [2016 August 26]. https://clinicaltrials.gov/ct2/show/NCT01761305.
3 Abbott A, Moller H, Gerdhem P. CONTRAIS: CONservative TReatment for Adolescent Idiopathic Scoliosis: a randomised controlled trial protocol. BMC musculoskeletal disorders. 2013;14:261. PMID: 24007599.24007599