# Appendix A Detailed Methods

## Search Strategy

Adolescent Idiopathic Scoliosis: Search to identify existing systematic reviews

Cochrane Database of Systematic Reviews (Issue 5 of 12, May 2015)

#1 | (scoliosis or scolioses):ti,ab,kw
#2 | (idiopathic or ideopathic):ti,ab,kw
#3 | (caus* or etiolog* or aetiolog*):ti,ab,kw near/3 (unknow* or undetermin* or undiscover*):ti,ab,kw
#4 | #2 or #3
#5 | (child* or teen or teens or teenage* or adolescen* or youth or youths or “young people” or pediatric* or paediatric* or toddler* or school* or girl* or boy*):ti,ab,kw
#6 | #1 and #4 and #5 Publication Year from 2004 to 2015, in Cochrane Reviews (Reviews and Protocols)

Database of Abstracts of Reviews of Effects via Centre for Reviews and Dissemination

Line | Search
1 | (scoliosis or scolioses) IN DARE FROM 2004 TO 2015
2 | (child* or teen or teens or teenage* or adolescen* or youth or youths or “young people” or pediatric* or paediatric* or toddler* or school* or girl* or boy*) IN DARE FROM 2004 TO 2015
3 | #1 AND #2

Health Technology Assessment via Centre for Reviews and Dissemination

Line | Search
1 | (scoliosis or scolioses) IN HTA FROM 2004 TO 2015

OVID MEDLINE search strategy

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) <1946 to Present>, Ovid MEDLINE(R) Daily Update <May 11, 2015>

Search Strategy:

--------------------------------------------------------------------------------------

1. Scoliosis/
2. (scoliosis or scolioses).ti.
3. 1 or 2
4. idiopathic.ti,ab.
5. ideopathic.ti,ab.
6. ((caus* or etiolog* or aetiolog*) adj3 (unknow* or undetermin* or undiscover*)).ti,ab.
7. 4 or 5 or 6
8. Child/
9. Child, Preschool/
10. Adolescent/
11. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti.
12. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti,ab.
13. limit 12 to in process
14. 8 or 9 or 10 or 11 or 13
15. 3 and 7 and 14
16. limit 15 to (english language and yr=”2004 -Current”)
17. limit 16 to systematic reviews
18. remove duplicates from 17

PubMed search strategy [publisher-supplied references only]

Search | Query
[underlined: #8] | Search #6 AND systematic[sb] AND publisher[sb] AND English[language] Filters: Publication date from 2004/01/01 to 2015/12/31
[underlined: #7] | Search #6 AND systematic[sb] AND publisher[sb] AND English[language]
[underlined: #6] | Search #1 AND #4 AND #5
[underlined: #5] | Search child*[tiab] OR teen[tiab] OR teens[tiab] OR teenage*[tiab] OR adolescen*[tiab] OR youth[tiab] OR youths[tiab] OR “young people”[tiab] OR “young adult”[tiab] OR “young adults”[tiab] OR pediatric*[tiab] OR paediatric*[tiab] OR toddler*[tiab] OR school*[tiab] OR boy*[tiab] OR girl*[tiab]
[underlined: #4] | Search #2 OR #3
[underlined: #3] | Search “unknown cause”[tiab] OR “unknown causes”[tiab] OR “unknown etiology”[tiab] OR “unknown etiologies”[tiab] OR “unknown etiological”[tiab] OR “undetermined cause”[tiab] OR “undetermined causes”[tiab] OR “undetermined etiology”[tiab] OR “undetermined etiologies”[tiab] OR “undetermined etiological”[tiab] OR “undiscovered cause”[tiab] OR “undiscovered causes”[tiab] OR “undiscovered etiology”[tiab] OR “undiscovered etiologies”[tiab] OR “undiscovered etiological”[tiab] OR “unknown aetiology”[tiab] OR “unknown aetiologies”[tiab] OR “unknown aetiological”[tiab] OR “undetermined aetiology”[tiab] OR “undetermined aetiologies”[tiab] OR “undetermined aetiological”[tiab] OR “undiscovered aetiology”[tiab] OR “undiscovered aetiologies”[tiab] OR “undiscovered aetiological”[tiab]
[underlined: #2] | Search idiopathic[tiab] OR ideopathic[tiab]
[underlined: #1] | Search scoliosis[tiab] OR scolioses[tiab]

Adolescent Idiopathic Scoliosis | Search Strategies

Sources Searched
Cochrane Central Register of Clinical Trials
OVID Medline
ERIC (Eric.ed.gov)
PUBMED, publisher-supplied
CINAHL

Key:

/ = MeSH subject heading

* = truncation

ab = word in abstract

adj# = adjacent within x number of words

ae = adverse effects

co= complications

in= injuries

po= poisoning

re= radiation effects

mo= mortality

hw = subject heading word

tw= text word

kw= keyword

N# = adjacent within x number of words

ti = word in title

MW= MeSH word (used for floating subheadings in CINAHL)

Cochrane Central Register of Controlled Trials

Issue 9 of 12, September 2016

- #1 (scolio*):ti,ab,kw
- #2 (child* or teen or teens or teenage* or adolescen* or youth* or “young people” or “young adult” or “young adults” or pediatric* or paediatric* or toddler* or school* or girl* or boy*):ti,ab,kw
- #3 #1 and #2 Publication Year from 1966 to 2016, in Trials

Database: Ovid MEDLINE(R) Epub Ahead of Print <October 12, 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 07, 2016>, Ovid MEDLINE(R) <1946 to October Week 1 2016>, Ovid MEDLINE(R) Daily Update <October 03, 2016>

Search Strategy:

KQ1 & KQ2

What is the evidence that screening for adolescent idiopathic scoliosis improves a) health outcomes and b) degree of curve in childhood?

What is the accuracy of screening for adolescent idiopathic scoliosis?

-----------------------------------------------------------------------------

1. Scoliosis/
2. scolio*.ti,ab.
3. 1 or 2
4. Child/
5. Child, Preschool/
6. Adolescent/
7. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti,ab.
8. 4 or 5 or 6 or 7
9. Mass Screening/
10. screen*.ti,ab.
11. detect*.ti,ab.
12. forward bend*.ti,ab.
13. surface topograph*.ti,ab.
14. plumb line*.ti,ab.
15. ((spine or spinal or back) adj3 contour).ti,ab.
16. scoliomet*.ti,ab.
17. inclinomet*.ti,ab.
18. cobb angle*.ti,ab.
19. Moire Topography/
20. moire.ti,ab.
21. X-Rays/
22. (x ray* or xray*).ti,ab.
23. Radiography/
24. radiograph*.ti,ab.
25. Imaging, Three-Dimensional/
26. (three dimension* or 3d or 3 dimension*).ti,ab.
27. Image Processing, Computer-Assisted/
28. Photogrammetry/
29. photogram*.ti,ab.
30. Radiostereometric Analysis/
31. (stereoradio* or radiostereo* or stereophoto* or photostereo* or stereoscop*).ti,ab.
32. Image Interpretation, Computer-Assisted/
33. Radiographic Image Interpretation, Computer-Assisted/
34. Radiographic Image Enhancement/
35. Tomography, X-Ray Computed/
36. (formetric* or biplanar* or digital slot* or auscan*).ti,ab.
37. 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
38. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
39. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
40. Random*.ti,ab.
41. control groups/ or double-blind method/ or single-blind method/
42. clinical trial*.ti,ab.
43. controlled trial*.ti,ab.
44. meta analy*.ti,ab.
45. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
46. cohort.ti,ab.
47. longitudinal.ti,ab.
48. (follow up or followup).ti,ab.
49. Registries/
50. (registr* or register*).ti,ab.
51. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50
52. 3 and 8 and 37 and 51
53. remove duplicates from 52
54. limit 53 to english language
55. Animals/ not (Humans/ and Animals/)
56. 54 not 55

Database: Ovid MEDLINE(R) Epub Ahead of Print <October 12, 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 07, 2016>, Ovid MEDLINE(R) <1946 to October Week 1 2016>, Ovid MEDLINE(R) Daily Update <October 03, 2016>

Search Strategy:

KQ3

What are the harms of screening for adolescent idiopathic scoliosis?

_______________________________________________________________

1. Scoliosis/
2. scolio*.ti,ab.
3. 1 or 2
4. Child/
5. Child, Preschool/
6. Adolescent/
7. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti,ab.
8. 4 or 5 or 6 or 7
9. Mass Screening/
10. screen*.ti,ab.
11. detect*.ti,ab.
12. forward bend*.ti,ab.
13. surface topograph*.ti,ab.
14. plumb line*.ti,ab.
15. ((spine or spinal or back) adj3 contour).ti,ab.
16. scoliomet*.ti,ab.
17. inclinomet*.ti,ab.
18. cobb angle*.ti,ab.
19. Moire Topography/
20. moire.ti,ab.
21. X-Rays/
22. (x ray* or xray*).ti,ab.
23. Radiography/
24. radiograph*.ti,ab.
25. Imaging, Three-Dimensional/
26. (three dimension* or 3d or 3 dimension*).ti,ab.
27. Image Processing, Computer-Assisted/
28. Photogrammetry/
29. photogram*.ti,ab.
30. Radiostereometric Analysis/
31. (stereoradio* or radiostereo* or stereophoto* or photostereo* or stereoscop*).ti,ab.
32. Image Interpretation, Computer-Assisted/
33. Radiographic Image Interpretation, Computer-Assisted/
34. Radiographic Image Enhancement/
35. Tomography, X-Ray Computed/
36. (formetric* or biplanar* or digital slot* or auscan*).ti,ab.
37. 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
38. Mortality/
39. Morbidity/
40. Death/
“ Drug-Related Side Effects and Adverse Reactions”/
42. safety.ti,ab.
43. harm*.ti,ab.
44. mortal*.ti,ab.
45. toxic*.ti,ab.
46. complicat*.ti,ab.
47. (death or deaths).ti,ab.
48. (adverse adj2 (interaction* or response* or effect* or event* or reaction* or outcome*)).ti,ab.
49. adverse effects.fs.
50. toxicity.fs.
51. mortality.fs.
52. complications.fs.
53. label*.ti,ab.
54. Radiation Injuries/
55. radiation.ti,ab.
56. psycho*.ti,ab.
57. (social* or socio* or societ* or cultur*).ti,ab.
58. Self Concept/
59. Self Efficacy/
60. (self adj3 (aware* or percept* or perceiv* or imag* or doubt* or concept* or critic*)).ti,ab.
61. Body Image/
62. (body adj3 imag*).ti,ab.
63. (isolat* or lonely or loneliness).ti,ab.
64. Bullying/
65. Aggression/
66. (bully* or bullie* or aggressiv* or aggression* or teas* or harass*).ti,ab.
“ Conflict (Psychology)”/
68. conflict*.ti,ab.
69. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68
70. 3 and 8 and 37 and 69
71. remove duplicates from 70
72. limit 71 to english language
73. Animals/ not (Humans/ and Animals/)
74. 72 not 73

Database: Ovid MEDLINE(R) Epub Ahead of Print <October 12, 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 07, 2016>, Ovid MEDLINE(R) <1946 to October Week 1 2016>, Ovid MEDLINE(R) Daily Update <October 03, 2016>

Search Strategy:

KQ4

What is the evidence that treatment of people with screening-relevant adolescent idiopathic scoliosis improves a) health outcomes and b) degree of curve in childhood or adulthood?

_______________________________________________________________________

1. Scoliosis/
2. scolio*.ti,ab.
3. 1 or 2
4. Child/
5. Child, Preschool/
6. Adolescent/
7. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti,ab.
8. 4 or 5 or 6 or 7
9. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
10. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
11. Random*.ti,ab.
12. control groups/ or double-blind method/ or single-blind method/
13. clinical trial*.ti,ab.
14. controlled trial*.ti,ab.
15. meta analy*.ti,ab.
16. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
17. cohort.ti,ab.
18. longitudinal.ti,ab.
19. (follow up or followup).ti,ab.
20. Registries/
21. (registr* or register*).ti,ab.
22. 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. Watchful Waiting/
24. observ*.ti,ab.
25. Braces/
26. (brace or braces or bracing or braced).ti,ab.
27. Surgical Procedures, Operative/
28. surg*.ti,ab.
29. operat*.ti,ab.
30. realign*.ti,ab.
31. Spinal Fusion/
32. (spondylodesis or spondylodeses or spondylosyndesis or spondylosyndeses).ti,ab.
33. (fusion* adj3 (spine or spinal)).ti,ab.
34. (instrument* adj3 (spine or spinal)).ti,ab.
35. harrington*.ti,ab.
36. Bone Screws/
37. Pedicle Screws/
38. screw*.ti,ab.
39. Bone Wires/
40. (wire or wires or wiring or wired).ti,ab.
41. Bone Nails/
42. nail*.ti,ab.
43. Bone Plates/
44. (plate* or plating).ti,ab.
45. Suture Anchors/
46. Internal Fixators/
47. sublaminar.ti,ab.
48. kirschner.ti,ab.
49. hook*.ti,ab.
50. Casts, Surgical/
51. cast*.ti,ab.
52. Splints/
53. splint*.ti,ab.
54. External Fixators/
55. Immobilization/
56. (immobil* or stabil*).ti,ab.
57. Restraint, Physical/
58. Orthopedics/
59. Orthopedic Procedures/
60. Manipulation, Orthopedic/
61. Orthopedic Fixation Devices/
62. (orthoped* or orthopaed*).ti,ab.
63. Orthotic Devices/
64. orthotic*.ti,ab.
65. Electric Stimulation Therapy/
66. (electric* adj3 stimulat*).ti,ab.
67. electrotherap*.ti,ab.
68. Spinal Cord Stimulation/
69. Exercise/
70. Exercise Movement Techniques/
71. Dance Therapy/
72. Exercise Therapy/
73. Motion Therapy, Continuous Passive/
74. Muscle Stretching Exercises/
75. Plyometric Exercise/
76. Resistance Training/
77. Movement/
78. (exercis* or movement* or motion*).ti,ab.
79. Locomotion/
80. Walking/
81. Running/
82. Jogging/
83. (run* or walk* or jog*).ti,ab.
84. Musculoskeletal Manipulations/
85. ((muscu* or muscle) adj3 manip*).ti,ab.
86. Kinesiology, Applied/
87. Manipulation, Chiropractic/
88. Manipulation, Osteopathic/
89. Manipulation, Spinal/
90. Therapy, Soft Tissue/
91. Acupressure/
92. Massage/
93. Acupuncture Therapy/
94. Electroacupuncture/
95. (kinesiolog* or kinesiotherap* or chiropract* or osteopath* or acupres* or massag* or electroacupunctur* or acupunctur*).ti,ab.
96. Rehabilitation/
97. rehabilit*.ti,ab.
98. Early Ambulation/
99. Physical Therapy Modalities/
100. physical therap*.ti,ab.
101. physiotherap*.ti,ab.
102. Balneology/
103. Hydrotherapy/
104. (balneo* or hydrotherap*).ti,ab.
105. (water adj3 therap*).ti,ab.
106. Swimming/
107. swim*.ti,ab.
108. (tape or tapes or taped or taping).ti,ab.
109. or/23-108
110. 3 and 8 and 22 and 109
111. Scoliosis/dt [Drug Therapy]
112. Scoliosis/pc [Prevention & Control]
113. Scoliosis/rt [Radiotherapy]
114. Scoliosis/rh [Rehabilitation]
115. Scoliosis/su [Surgery]
116. Scoliosis/th [Therapy]
117. or/111-116
118. 8 and 22 and 117
119. 110 or 118
120. remove duplicates from 119
121. limit 120 to english language
122. Animals/ not (Humans/ and Animals/)
123. 121 not 122

Database: Ovid MEDLINE(R) Epub Ahead of Print <October 12, 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 07, 2016>, Ovid MEDLINE(R) <1946 to October Week 1 2016>, Ovid MEDLINE(R) Daily Update <October 03, 2016>

Search Strategy:

KQ5

What are the harms of treatment for persons with screening-relevant adolescent idiopathic scoliosis?

_______________________________________________________________________

1. Scoliosis/
2. scolio*.ti,ab.
3. 1 or 2
4. Child/
5. Child, Preschool/
6. Adolescent/
7. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti,ab.
8. 4 or 5 or 6 or 7
9. Watchful Waiting/
10. observ*.ti,ab.
11. Braces/
12. (brace or braces or bracing or braced).ti,ab.
13. Surgical Procedures, Operative/
14. surg*.ti,ab.
15. operat*.ti,ab.
16. realign*.ti,ab.
17. Spinal Fusion/
18. (spondylodesis or spondylodeses or spondylosyndesis or spondylosyndeses).ti,ab.
19. (fusion* adj3 (spine or spinal)).ti,ab.
20. (instrument* adj3 (spine or spinal)).ti,ab.
21. harrington*.ti,ab.
22. Bone Screws/
23. Pedicle Screws/
24. screw*.ti,ab.
25. Bone Wires/
26. (wire or wires or wiring or wired).ti,ab.
27. Bone Nails/
28. nail*.ti,ab.
29. Bone Plates/
30. (plate* or plating).ti,ab.
31. Suture Anchors/
32. Internal Fixators/
33. sublaminar.ti,ab.
34. kirschner.ti,ab.
35. hook*.ti,ab.
36. Casts, Surgical/
37. cast*.ti,ab.
38. Splints/
39. splint*.ti,ab.
40. External Fixators/
41. Immobilization/
42. (immobil* or stabil*).ti,ab.
43. Restraint, Physical/
44. Orthopedics/
45. Orthopedic Procedures/
46. Manipulation, Orthopedic/
47. Orthopedic Fixation Devices/
48. (orthoped* or orthopaed*).ti,ab.
49. Orthotic Devices/
50. orthotic*.ti,ab.
51. Electric Stimulation Therapy/
52. (electric* adj3 stimulat*).ti,ab.
53. electrotherap*.ti,ab.
54. Spinal Cord Stimulation/
55. Exercise/
56. Exercise Movement Techniques/
57. Dance Therapy/
58. Exercise Therapy/
59. Motion Therapy, Continuous Passive/
60. Muscle Stretching Exercises/
61. Plyometric Exercise/
62. Resistance Training/
63. Movement/
64. (exercis* or movement* or motion*).ti,ab.
65. Locomotion/
66. Walking/
67. Running/
68. Jogging/
69. (run* or walk* or jog*).ti,ab.
70. Musculoskeletal Manipulations/
71. ((muscu* or muscle) adj3 manip*).ti,ab.
72. Kinesiology, Applied/
73. Manipulation, Chiropractic/
74. Manipulation, Osteopathic/
75. Manipulation, Spinal/
76. Therapy, Soft Tissue/
77. Acupressure/
78. Massage/
79. Acupuncture Therapy/
80. Electroacupuncture/
81. (kinesiolog* or kinesiotherap* or chiropract* or osteopath* or acupres* or massag* or electroacupunctur* or acupunctur*).ti,ab.
82. Rehabilitation/
83. rehabilit*.ti,ab.
84. Early Ambulation/
85. Physical Therapy Modalities/
86. physical therap*.ti,ab.
87. physiotherap*.ti,ab.
88. Balneology/
89. Hydrotherapy/
90. (balneo* or hydrotherap*).ti,ab.
91. (water adj3 therap*).ti,ab.
92. Swimming/
93. swim*.ti,ab.
94. (tape or tapes or taped or taping).ti,ab.
95. or/9-94
96. 3 and 8 and 95
97. Scoliosis/dt [Drug Therapy]
98. Scoliosis/pc [Prevention & Control]
99. Scoliosis/rt [Radiotherapy]
100. Scoliosis/rh [Rehabilitation]
101. Scoliosis/su [Surgery]
102. Scoliosis/th [Therapy]
103. or/97-102
104. 103 and 8
105. 96 or 104
106. Mortality/
107. Morbidity/
108. Death/
“ Drug-Related Side Effects and Adverse Reactions”/
110. safety.ti,ab.
111. harm*.ti,ab.
112. mortal*.ti,ab.
113. toxic*.ti,ab.
114. complication*.ti,ab.
115. (death or deaths).ti,ab.
116. (adverse adj2 (interaction* or response* or effect* or event* or reaction* or outcome*)).ti,ab.
117. adverse effects.fs.
118. toxicity.fs.
119. mortality.fs.
120. complications.fs.
121. Pain/
122. Acute Pain/
123. Back Pain/
124. Failed Back Surgery Syndrome/
125. Low Back Pain/
126. pain*.ti,ab.
127. backache*.ti,ab.
128. back ache*.ti,ab.
129. Intraoperative Complications/
130. Blood Loss, Surgical/
131. Postoperative Hemorrhage/
132. (blood* or bleed* or hemorrhag*or haemorrhag*).ti,ab.
133. Intraoperative Awareness/
134. Malignant Hyperthermia/
135. Postoperative Complications/
“ delayed emergence from anesthesia”/
137. Pain, Postoperative/
“ Postoperative Nausea and Vomiting”/
139. (nause* or vomit* or emetic or emesis).ti,ab.
140. shock, surgical/
141. shock.ti,ab.
142. Surgical Wound Dehiscence/
143. Surgical Wound Infection/
144. infect*.ti,ab.
145. Vasoplegia/
“ Recovery of Function”/
147. ((decrease* or diminish* or reduc* or minim* or compromis* or lack* or lower* or improper* or incomplet* or damag* or limit*) adj3 function*).ti,ab.
148. mobility limitation/
149. psycho*.ti,ab.
150. or/106-149
151. 105 and 150
152. remove duplicates from 151
153. limit 152 to english language
154. Animals/ not (Humans/ and Animals/)
155. 153 not 154

Database: Ovid MEDLINE(R) Epub Ahead of Print <October 12, 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 07, 2016>, Ovid MEDLINE(R) <1946 to October Week 1 2016>, Ovid MEDLINE(R) Daily Update <October 03, 2016>

Search Strategy:

KQ6

What is the association between cobb angle in adolescence and health outcomes in adulthood?

_______________________________________________________________________

1. Scoliosis/
2. scolio*.ti,ab.
3. 1 or 2
4. Child/
5. Child, Preschool/
6. Adolescent/
7. (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or young adult* or pediatric* or paediatric* or toddler* or school* or girl* or boy*).ti,ab.
8. 4 or 5 or 6 or 7
9. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
10. cohort.ti,ab.
11. longitudinal.ti,ab.
12. (follow up or followup).ti,ab.
13. Registries/
14. (registr* or register*).ti,ab.
15. (evolv* or evolu*).ti,ab.
16. natural histor*.ti,ab.
17. (curv* adj3 (progress* or develop*)).ti,ab.
18. 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17
19. 3 and 8 and 18
20. remove duplicates from 19
21. limit 20 to english language
22. Animals/ not (Humans/ and Animals/)
23. 21 not 22

ERIC http://eric.ed.gov/

Scoliosis OR scolioses OR scoliotic OR scoliosies OR scoliosi

PubMed Publisher-Supplied

Search | Query
[underlined: #5] | Search #3 AND #4
[underlined: #4] | Search publisher[sb]
[underlined: #3] | Search #1 AND #2
[underlined: #2] | Search child*[tiab] OR teen[tiab] OR teens[tiab] OR teenage*[tiab] OR adolescen*[tiab] OR youth*[tiab] OR “young people”[tiab] OR”young adult”[tiab] OR “young adults”[tiab] OR pediatric*[tiab] OR paediatric*[tiab] OR toddler*[tiab] OR school*[tiab] OR girl*[tiab] OR boy*[tiab]
[underlined: #1] | Search scolio*[tiab]

CINAHL

# | Query
S111 | S22 OR S110
S110 | S13 AND S109
S109 | (S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 OR S67 OR S68 OR S69 OR S70 OR S71 OR S72 OR S73 OR S74 OR S75 OR S76 OR S77 OR S78 OR S79 OR S80 OR S81 OR S82 OR S83 OR S84 OR S85 OR S86 OR S87 OR S88 OR S89 OR S90 OR S91 OR S92 OR S93 OR S94 OR S95 OR S96 OR S97 OR S98 OR S99 OR S100 OR S101 OR S102 OR S103 OR S104 OR S105 OR S106 OR S107 OR S108)
S108 | (decrease* OR diminish* OR reduc* OR minim* OR compromis* OR lack* OR lower* OR improper* OR incomplet* OR damag* OR limit*) N3 (function* OR mobil*)
S107 | (MH “Functional Status”)
S106 | AB infect*
S105 | TI infect*
S104 | (MH “Surgical Wound Infection”)
S103 | (MH “Surgical Wound Dehiscence”)
S102 | AB shock
S101 | TI shock
S100 | (MH “Shock, Surgical”)
S99 | AB (nause* or vomit* or emetic or emesis)
S98 | TI (nause* or vomit* or emetic or emesis)
S97 | (MH “Nausea and Vomiting”)
S96 | (MH “Treatment Related Pain”)
S95 | (MH “Chronic Pain”)
S94 | (MH “Postoperative Pain”)
S93 | (MH “Postoperative Complications”)
S92 | (MH “Malignant Hyperthermia”)
S91 | (MH “Intraoperative Awareness”)
S90 | AB (blood* or bleed* or hemorrhag*or haemorrhag*)
S89 | TI (blood* or bleed* or hemorrhag*or haemorrhag*)
S88 | (MH “Postoperative Hemorrhage”)
S87 | (MH “Blood Loss, Surgical”)
S86 | (MH “Intraoperative Complications”)
S85 | AB (pain* OR backache* OR “back ache*”)
S84 | TI (pain* OR backache* OR “back ache*”)
S83 | (MH “Failed Back Surgery Syndrome”)
S82 | (MH “Low Back Pain”)
S81 | (MH “Back Pain”)
S80 | (MH “Pain”)
S79 | (TI conflict*) OR (AB conflict*)
S78 | (MH “Conflict (Psychology)”)
S77 | AB (bully* or bullie* or aggressiv* or aggression* or teas* or harass* or abus*)
S76 | TI (bully* or bullie* or aggressiv* or aggression* or teas* or harass* or abus*)
S75 | (MH “Verbal Abuse”)
S74 | (MH “Student Abuse”)
S73 | (MH “Aggression”)
S72 | (MH “Bullying”)
S71 | AB (isolat* OR lonely OR loneliness)
S70 | TI (isolat* OR lonely OR loneliness)
S69 | AB (disfigur*)
S68 | TI (disfigur*)
S67 | AB (body N3 imag*)
S66 | TI (body N3 imag*)
S65 | (MH “Disfigurement”)
S64 | (MH “Personal Appearance”)
S63 | (MH “Body Image”)
S62 | (MH “Self-Efficacy”)
S61 | (MH “Self Concept”)
S60 | MW “mo”
S59 | MW “re”
S58 | MW “po”
S57 | MW “in”
S56 | MW “co”
S55 | MW “ae”
S54 | AB complicat*
S53 | TI complicat*
S52 | TI (radio* OR radiation*)
S51 | AB (radio* OR radiation*)
S50 | (MH “Radiodermatitis”)
S49 | (MH “Radiation Pneumonitis”)
S48 | (MH “Osteoradionecrosis”)
S47 | (MH “Neoplasms, Radiation-Induced”)
S46 | (MH “Leukemia, Radiation-Induced”)
S45 | (MH “Acute Radiation Syndrome”)
S44 | (MH “Abnormalities, Radiation-Induced”)
S43 | (MH “Radiation Injuries”)
S42 | AB (social* OR socio* or societ* or cultur*)
S41 | TI (social* OR socio* or societ* or cultur*)
S40 | AB (psycho*)
S39 | TI (psycho*)
S38 | AB (label*)
S37 | TI (label*)
S36 | AB (adverse N2 (interaction* OR response* OR effect* OR event* OR reaction* OR outcome*)
S35 | TI (adverse N2 (interaction* OR response* OR effect* OR event* OR reaction* OR outcome*)
S34 | AB (toxic*)
S33 | TI (toxic*)
S32 | AB (harm*)
S31 | TI (harm*)
S30 | AB (safety)
S29 | TI (safety)
S28 | AB (morbid* OR mortal* OR death*)
S27 | TI (morbid* OR mortal* OR death*)
S26 | (MH “Death”)
S25 | (MH “Child Mortality”)
S24 | (MH “Mortality”)
S23 | (MH “Morbidity”)
S22 | S13 AND S21
S21 | S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20
S20 | TI ((“comparison group*” or “control group*”)) OR AB ((“comparison group*” or “control group*”))
S19 | TI (“controlled before and after”) OR AB (“controlled before and after”)
S18 | TI “controlled before after” OR AB “controlled before after”
S17 | (TX cohort OR TI longitudinal OR AB longitudinal TI “follow up” OR AB “follow up” OR TI followup OR AB followup OR TI registr* OR AB registr* TI register* OR AB register* OR TI evolv* OR AB evolv* OR TI evolu* OR AB evolu* OR TI “natural histor*” OR AB “natural histor*”)
S16 | (MH “Clinical Trial Registry”)
S15 | (MH “Prospective Studies”) OR (MH “Concurrent Prospective Studies”) OR (MH “Noncurrent Prospective Studies”) OR (MH “Correlational Studies”) OR (MH “Retrospective Panel Studies”)
S14 | (MH “Meta Analysis”) OR (MH “Control Group”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Triple-Blind Studies”) OR (MH “Randomized Controlled Trials”) OR (MH “Clinical Trials”) OR (MH “Random Assignment”) OR (AB clinical n1 trial*) OR (AB controlled n1 trial*) OR (TI clinical n1 trial*) OR (TI controlled n1 trial*) OR (PT Clinical trial) OR (PT randomized controlled trial)
S13 | S11 OR S12
S12 | (MH “Scoliosis, Idiopathic, Adolescent”)
S11 | (S4 AND S10)
S10 | S5 OR S6 OR S7 OR S8 OR S9
S9 | AB (child* OR teen OR teens OR teenage* OR adolescen* OR youth OR youths OR “young people” OR “young adult*” OR pediatric* OR paediatric* OR toddler* OR school* OR girl* OR boy*)
S8 | TI (child* OR teen OR teens OR teenage* OR adolescen* OR youth OR youths OR “young people” OR “young adult*” OR pediatric* OR paediatric* OR toddler* OR school* OR girl* OR boy*)
S7 | (MH “Child, Preschool”)
S6 | (MH “Child”)
S5 | (MH “Adolescence”)
S4 | (S1 OR S2 OR S3)
S3 | AB (scolio*)
S2 | TI (scolio*)
S1 | (MH “Scoliosis”)

Appendix A Figure 1 Literature Flow Diagram

Abbreviation: KQ=key question.

Appendix A Figure 1 is a flow chart that summarizes the search and selection of articles. There were 10,515 citations identified through literature databases. An additional 45 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 8,230 unique citations were screened at the title/abstract stage. The full text of 1,088 citations were examined for inclusion for one or more of the six Key Questions.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Population | KQs 1, 2, 5: Asymptomatic children and adolescents ages 10 to 18 years KQs 3, 6: Screen-detected^*^ children and adolescents age 10 to 18 years diagnosed with adolescent idiopathic scoliosis that has a Cobb angle of 10° to 50° KQ 4: Screen-detected children and adolescents ages 10 to 18 years who are diagnosed with adolescent idiopathic scoliosis that has a Cobb angle of ≥10° | Persons with scoliosis of:; - Neuromuscular etiology (e.g., cerebral palsy, myelomeningocele, muscular dystrophy, spinal muscular atrophy, spina bifida, spinal cord injuries); - Congenital etiology (e.g., hemivertebrae, failure of segmentation); - Mesenchymal/syndromic etiology (e.g., Marfan syndrome, mucopolysaccharidosis, osteogenesis imperfecta, inflammatory diseases, postoperative); - Early-onset idiopathic etiology (infantile [ages 0 to 3 years] or juvenile [ages 4 to 9 years])
Settings | - Primary care or generalizable to primary care; - School-based screening programs; - Countries categorized “High” on the Human Development Index (United Nations Development Programme)^1^ | Specialty care (e.g., surgical clinics and clinics for conditions known to be associated with scoliosis) and other settings with a symptomatic population
Screening tests | KQs 1, 2, 5: Forward bend test (with or without scoliometer/inclinometer), surface topography, or other methods (e.g., back-contour device), followed by X-ray for confirmation | KQs 1, 2, 5: X-ray alone; studies where screening is completed by a single practitioner or where screening practitioner is not described; where referral criteria is not quantitatively described; or where the flow of participants through screening program incompletely described
Treatments | KQs 3, 6:; - Surgery; - Nonoperative treatment, including but not limited to: bracing, physical/ exercise therapy | KQs 3, 6:; - Study treatments conducted by a single practitioner (surgeon, therapist, or bracer); - Population treated with exclusively Harrington rod instrumentation, Milwaukee brace (unless long-term followup study), or electrical surface stimulation
Comparison | KQs 1, 2, 5: Usual care KQs 3, 6: Observation, usual care | KQs 3, 6:; - Comparative effectiveness studies; - Studies with a comparison group that was determined post-hoc (e.g., compliant vs. noncompliant); KQ 4: People without AIS (healthy controls)
Outcomes | Intermediate outcome in childhood or adulthood: Severity of spinal curvature Health outcomes in childhood or adulthood six months or more after surgery or treatment initiation:; - Morbidity (e.g., pulmonary symptoms, hypertension, lumbar radiculopathy, mortality); - Quality of life; - Pain; - Functional outcomes | KQ 4:; - Studies that do not report adult health outcomes; - Studies that report only spinal curve in adulthood with no adult health outcomes
Harms | Any screening or treatment harm present at 6 months or more after screening, surgery, or treatment initiation including but not limited to: physiologic harm, psychosocial harm, labeling or radiation exposure Mortality or neurologic damage at any time point | Function, pain (these are considered outcomes, not harms), loss of correction, re-operation Harms that cannot be attributed to screening (KQ5) or treatment (KQ6)
Study design | KQs 1–4: Randomized clinical trials; controlled trials; cohort studies; registry-based observational studies KQs 5, 6: Randomized clinical trials; controlled trials; cohort studies; registry-based observational studies case series, case-control | All KQs:; - Studies rated as poor quality; case reports; cross-sectional studies; KQs 1–4: Case series; cost-effectiveness studies; qualitative study designs

* Operationalized as screen “detectable,” meaning the study has data on the population before curve reached 45°–50° (for example, bracing before surgery).

Abbreviations: KQ=key question; AIS=adolescent idiopathic scoliosis.

Appendix A Table 2 Quality Assessment Criteria

Study Design | Quality criteria
Randomized controlled trials USPSTF methods^2^ | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid, and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^3^ | - Was the cohort systematically selected to avoid bias?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid, and reliable?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?

Abbreviations: USPSTF = U.S. Preventive Services Task Force

## References

1 United Nations Development Programme. Human Development Index: 2015 Rankings. United Nations Development Programme [2015]. http://hdr.undp.org/en/2015-report.
2 United States Preventive Services Task Force. US Preventive Services Task Force Procedure Manual. 2015.
3 Wells G, Shea B, O'connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000.