# References

1 Moyer VA. Menopausal hormone therapy for the primary prevention of chronic conditions: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Jan 1;158(1):47-54. doi: 1384872 [pii]; 10.7326/0003-4819-158-1-201301010-00553 [doi]. PMID: 23090711.23090711
2 Col NF; Fairfield KM; Ewan-Whyte C; Miller H. In the clinic. Menopause. Ann Intern Med. 2009 Apr 7;150(7):ITC4-1-15; quiz ITC4-6. PMID: 19349628.19349628
3 Harlow SD; Gass M; Hall JE; Lobo R; Maki P; Rebar RW; Sherman S; Sluss PM; de Villiers TJ; Group SC. Executive summary of the Stages of Reproductive Aging Workshop + 10: addressing the unfinished agenda of staging reproductive aging. Menopause. 2012 Apr;19(4):387-95. doi: 10.1097/gme.0b013e31824d8f40. PMID: 22343510.22343510
4 Hu FB; Grodstein F; Hennekens CH; Colditz GA; Johnson M; Manson JE; Rosner B; Stampfer MJ. Age at natural menopause and risk of cardiovascular disease. Arch Intern Med. 1999 May 24;159(10):1061-6. PMID: 10335682.10335682
5 Mondul AM; Rodriguez C; Jacobs EJ; Calle EE. Age at natural menopause and cause-specific mortality. Am J Epidemiol. 2005 Dec 1;162(11):1089-97. doi: 10.1093/aje/kwi324. PMID: 16221806.16221806
6 Derby CA; Crawford SL; Pasternak RC; Sowers M; Sternfeld B; Matthews KA. Lipid changes during the menopause transition in relation to age and weight: the Study of Women's Health Across the Nation. Am J Epidemiol. 2009 Jun 1;169(11):1352-61. doi: 10.1093/aje/kwp043. PMID: 19357323.19357323
7 Stampfer MJ; Colditz GA; Willett WC; Manson JE; Rosner B; Speizer FE; Hennekens CH. Postmenopausal estrogen therapy and cardiovascular disease. Ten-year follow-up from the nurses' health study. N Engl J Med. 1991 Sep 12;325(11):756-62. doi: 10.1056/NEJM199109123251102. PMID: 1870648.1870648
8 Grady D; Rubin SM; Petitti DB; Fox CS; Black D; Ettinger B; Ernster VL; Cummings SR. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992 Dec 15;117(12):1016-37. PMID: 1443971.1443971
9 Stampfer MJ; Colditz GA. Estrogen replacement therapy and coronary heart disease: a quantitative assessment of the epidemiologic evidence. Prev Med. 1991 Jan;20(1):47-63. PMID: 1826173.1826173
10 McKinlay SM. The normal menopause transition: an overview. Maturitas. 1996 Mar;23(2):137-45. PMID: 8735352.8735352
11 Nelson LM. Clinical practice. Primary ovarian insufficiency. N Engl J Med. 2009 Feb 5;360(6):606-14. doi: 10.1056/NEJMcp0808697. PMID: 19196677.19196677
12 Pinkerton JV; Stovall DW. Reproductive aging, menopause, and health outcomes. Ann N Y Acad Sci. 2010 Aug;1204:169-78. doi: 10.1111/j.1749-6632.2010.05526.x. PMID: 20738288.20738288
13 Social Security Administration. Acturarial Life Table. Period Life Table, 2010. Washington, DC: Social Security Administration. http://www.ssa.gov/oact/STATS/table4c6.html. Accessed on April 24, 2015.
14 Stone NJ; Robinson JG; Lichtenstein AH; Bairey Merz CN; Blum CB; Eckel RH; Goldberg AC; Gordon D; Levy D; Lloyd-Jones DM; McBride P; Schwartz JS; Shero ST; Smith SC, Jr,; Watson K; Wilson PW; American College of Cardiology/American Heart Association Task Force on Practice Guidelines. 2013 ACC/AHA guideline on the treatment of blood cholesterol to reduce atherosclerotic cardiovascular risk in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2889. doi: 10.1161/01.cir.0000437738.63853.7a.24239923
15 Colditz GA; Willett WC; Stampfer MJ; Rosner B; Speizer FE; Hennekens CH. Menopause and the risk of coronary heart disease in women. N Engl J Med. 1987 Apr 30;316(18):1105-10. doi: 10.1056/NEJM198704303161801. PMID: 3574358.3574358
16 U.S. Food and Drug Administration. Estrogen and Estrogen with Progestin Therapies for Postmenopausal Women. 2011. http://www.fda.gov/Drugs/DrugSafety/InformationbyDrugClass/ucm135318.htm. Accessed on 15 November 2011.
17 U.S. Food and Drug Administration. Questions and Answers for Estrogen and Estrogen with Progestin Therapies for Postmenopausal Women (Updated). Silver Spring, MD: U.S. Food and Drug Administration; 2016. http://www.fda.gov/Drugs/DrugSafety/InformationbyDrugClass/ucm135339.htm. Accessed on April 22, 2016.
18 U.S. Food and Drug Administration. Menopause--Medicines to Help You. Silver Spring, MD: U.S. Food and Drug Administration. http://www.fda.gov/ForConsumers/ByAudience/ForWomen/ucm118627.htm. Accessed on April 24, 2015.
19 Boardman Henry MP; Hartley L; Eisinga A; Main C; Roqué i Figuls M; Bonfill Cosp X; Gabriel Sanchez R; Knight B. Hormone therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015.
20 Grant MD; Marbella A; Wang AT; Pines E; Hoag J; Bonnell C; Ziegler KM; Aronson N. Menopausal Symptoms: Comparative Effectiveness of Therapies Comparative Effectiveness Review No. 147. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.). AHRQ Publication No. 15-EHC005-EF. Rockville, MD: Agency for Healthcare Research and Quality; March 2015. www.effectivehealthcare.ahrq.gov/reports/final.cfm
21 Lukes A. Evolving issues in the clinical and managed care settings on the management of menopause following the women's health initiative. J Manag Care Pharm. 2008 Apr;14(3 Suppl):7-13. PMID: 18439061.18439061
22 Brett KM; Chong Y. Hormone Replacement Therapy: Knowledge and Use in the United States. Hyattsville, MD: National Center for Health Statistics; 2001.
23 Rossouw JE; Anderson GL; Prentice RL; LaCroix AZ; Kooperberg C; Stefanick ML; Jackson RD; Beresford SA; Howard BV; Johnson KC; Kotchen JM; Ockene J. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA. 2002 Jul 17;288(3):321-33. PMID: 12117397.12117397
24 Anderson GL; Limacher M; Assaf AR; Bassford T; Beresford SAA; Black H; Bonds D; Brunner R; Brzyski R; Caan B; Chlebowski R; Curb D; Gass M; Hays J; Heiss G; Hendrix S; Howard BV; Hsia J; Hubbell A; Jackson R; Johnson KC; Judd H; Kotchen JM; Kuller L; LaCroix AZ; Lane D; Langer RD; Lasser N; Lewis CE; Manson J; Margolis K; Ockene J; O'Sullivan MJ; Phillips L; Prentice RL; Ritenbaugh C; Robbins J; Rossouw JE; Sarto G; Stefanick ML; Van Horn L; Wactawski-Wende J; Wallace R; Wassertheil-Smoller S; Women's Health Initiative Steering Committee. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. JAMA. 2004 Apr 14;291(14):1701-12. PMID: 15082697.15082697
25 Sprague BL; Trentham-Dietz A; Cronin KA. A sustained decline in postmenopausal hormone use: results from the National Health and Nutrition Examination Survey, 1999-2010. Obstet Gynecol. 2012 Sep;120(3):595-603. doi: 10.1097/AOG.0b013e318265df42. PMID: 22914469.22914469
26 American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 565: Hormone therapy and heart disease. Obstet Gynecol. 2013 Jun;121(6):1407-10. doi: 10.1097/01.AOG.0000431053.33593.2d. PMID: 23812486.23812486
27 Goodman NF; Cobin RH; Ginzburg SB; Katz IA; Woode DE American Association of Clinical Endocrinologists Medical Guidelines for Clinical Practice for the diagnosis and treatment of menopause. Endocr Pract. 2011 Nov-Dec;17 Suppl 6:1-25. PMID: 22193047.22193047
28 Whitmer RA; Quesenberry CP; Zhou J; Yaffe K. Timing of hormone therapy and dementia: the critical window theory revisited. Ann Neurol. 2011 Jan;69(1):163-9. doi: 10.1002/ana.22239. PMID: 21280086.21280086
29 Hodis HN; Mack WJ; Henderson VW; Shoupe D; Budoff MJ; Hwang-Levine J; Li Y; Feng M; Dustin L; Kono N; Stanczyk FZ; Selzer RH; Azen SP. Vascular Effects of Early versus Late Postmenopausal Treatment with Estradiol. N Engl J Med. 2016 Mar 31;374(13):1221-31. doi: 10.1056/NEJMoa1505241 [doi]. PMID: 27028912.27028912
30 Williams JK; Anthony MS; Honore EK; Herrington DM; Morgan TM; Register TC; Clarkson TB. Regression of atherosclerosis in female monkeys. Arterioscler Thromb Vasc Biol. 1995 Jul;15(7):827-36. PMID: 7600113.7600113
31 Stampfer MJ; Willett WC; Colditz GA; Rosner B; Speizer FE; Hennekens CH. A prospective study of postmenopausal estrogen therapy and coronary heart disease. N Engl J Med. 1985 Oct 24;313(17):1044-9. doi: 10.1056/NEJM198510243131703. PMID: 4047106.4047106
32 Grodstein F; Manson JE; Colditz GA; Willett WC; Speizer FE; Stampfer MJ. A prospective, observational study of postmenopausal hormone therapy and primary prevention of cardiovascular disease. Ann Intern Med. 2000 Dec 19;133(12):933-41. PMID: 11119394.11119394
33 Salpeter SR; Walsh JM; Greyber E; Ormiston TM; Salpeter EE. Mortality associated with hormone replacement therapy in younger and older women: a meta-analysis. J Gen Intern Med. 2004 Jul;19(7):791-804. doi: 10.1111/j.1525-1497.2004.30281.x. PMID: 15209595.15209595
34 Rocca WA; Grossardt BR; Shuster LT. Oophorectomy, estrogen, and dementia: a 2014 update. Mol Cell Endocrinol. 2014 May 25;389(1-2):7-12. doi: S0303-7207(14)00033-1 [pii]; 10.1016/j.mce.2014.01.020 [doi]. PMID: 24508665.24508665
35 Rossouw JE; Prentice RL; Manson JE; Wu L; Barad D; Barnabei VM; Ko M; LaCroix AZ; Margolis KL; Stefanick ML. Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause.[Erratum appears in JAMA. 2008 Mar 26;299(12):1426]. JAMA. 2007 Apr 4;297(13):1465-77. PMID: 17405972.17405972
36 American Congress of Obstetricians and Gynecologists. ACOG Committee Opinion No. 565: Hormone therapy and heart disease. Obstet Gynecol. 2013 Jun;121(6):1407-10. doi: 10.1097/01.AOG.0000431053.33593.2d. PMID: 23812486.23812486
37 North American Menopause Society. The 2012 hormone therapy position statement of: The North American Menopause Society. Menopause. 2012 Mar;19(3):257-71. doi: 10.1097/gme.0b013e31824b970a. PMID: 22367731.22367731
38 U.S. Preventive Services Task Force. Methods and Processes. Rockville, MD: U.S. Preventive Services Task Force; 2016. http://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes Accessed on 23 May, 2016.
39 Nelson HD; Walker M; Zakher B; Mitchell J. Menopausal Hormone Therapy for the Primary Prevention of Chronic Conditions: Systematic Review to Update the 2002 and 2005 U.S. Preventive Services Task Force Recommendations Evidence Synthesis No. 93. AHRQ Pub No. 12-05168-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; May 2012.
40 Marjoribanks J; Farquhar C; Roberts H; Lethaby A. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2012;7:CD004143. doi: 10.1002/14651858.CD004143.pub4 [doi]. PMID: 22786488.22786488
41 Gu H; Zhao X; Yang Y; Lv X. Risk of stroke in healthy postmenopausal women during and after hormone therapy: a meta-analysis. Menopause. 2014 Nov;21(11):1204-10. doi: 10.1097/GME.0000000000000227 [doi]. PMID: 24686450.24686450
42 United Nations Development Programme. Human Development Report 2015. Work for Human Development. New York: United Nations Development Programme; 2015. http://hdr.undp.org/sites/default/files/2015_human_development_report.pdf. Accessed on April 4, 2016.
43 Harris RP; Helfand M; Woolf SH; Lohr KN; Mulrow CD; Teutsch SM; Atkins D. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. PMID: 11306229.11306229
44 West SL; Gartlehner G; Mansfield AJ; Poole C; Tant E; Lenfestey N; Lux LJ; Amoozegar J; Morton SC; Carey TC; Viswanathan M; Lohr KN. Comparative Effectiveness Review Methods: Clinical Heterogeneity Methods Research Paper. AHRQ Publication No 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; Sep 2010. http://effectivehealthcare.ahrq.gov/
45 Sutton A; Abrams KR; Jones DR; Sheldon T; Song F. Methods for Meta-Analysis in Medical Research. Chichester: John Wiley & Sons, Ltd.; 2014.
46 Higgins JP; Thompson SG; Deeks JJ; Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557-60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
47 Higgins JP; Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539-58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
48 Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]. The Cochrane Collaboration; 2011. www.cochrane-handbook.org. Accessed on April 11, 2016.
49 Rucker G; Schwarzer G; Carpenter JR; Schumacher M. Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. doi: 10.1186/1471-2288-8-79. PMID: 19036172.19036172
50 Berkman ND; Lohr KN; Ansari MT; Balk EM; Kane R; McDonagh M; Morton SC; Viswanathan M; Bass EB; Butler M; Gartlehner G; Hartling L; McPheeters M; Morgan LC; Reston J; Sista P; Whitlock E; Chang S. Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312-24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
51 Guyatt GH; Oxman AD; Vist G; Kunz R; Brozek J; Alonso-Coello P; Montori V; Akl EA; Djulbegovic B; Falck-Ytter Y; Norris SL; Williams JW, Jr.; Atkins D; Meerpohl J; Schunemann HJ. GRADE guidelines: 4. Rating the quality of evidence--study limitations (risk of bias). J Clin Epidemiol. 2011 Apr;64(4):407-15. doi: 10.1016/j.jclinepi.2010.07.017. PMID: 21247734.21247734
52 Guyatt GH; Oxman AD; Kunz R; Woodcock J; Brozek J; Helfand M; Alonso-Coello P; Glasziou P; Jaeschke R; Akl EA; Norris S; Vist G; Dahm P; Shukla VK; Higgins J; Falck-Ytter Y; Schunemann HJ; Group GW. GRADE guidelines: 7. Rating the quality of evidence--inconsistency. J Clin Epidemiol. 2011 Dec;64(12):1294-302. doi: 10.1016/j.jclinepi.2011.03.017. PMID: 21803546.21803546
53 Guyatt GH; Oxman AD; Kunz R; Brozek J; Alonso-Coello P; Rind D; Devereaux PJ; Montori VM; Freyschuss B; Vist G; Jaeschke R; Williams JW, Jr.; Murad MH; Sinclair D; Falck-Ytter Y; Meerpohl J; Whittington C; Thorlund K; Andrews J; Schunemann HJ. GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. 2011 Dec;64(12):1283-93. doi: 10.1016/j.jclinepi.2011.01.012. PMID: 21839614.21839614
54 Guyatt GH; Oxman AD; Kunz R; Woodcock J; Brozek J; Helfand M; Alonso-Coello P; Falck-Ytter Y; Jaeschke R; Vist G; Akl EA; Post PN; Norris S; Meerpohl J; Shukla VK; Nasser M; Schunemann HJ; Group GW. GRADE guidelines: 8. Rating the quality of evidence--indirectness. J Clin Epidemiol. 2011 Dec;64(12):1303-10. doi: 10.1016/j.jclinepi.2011.04.014. PMID: 21802903.21802903
55 Balshem H; Helfand M; Schunemann HJ; Oxman AD; Kunz R; Brozek J; Vist GE; Falck-Ytter Y; Meerpohl J; Norris S; Guyatt GH. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011 Apr;64(4):401-6. doi: 10.1016/j.jclinepi.2010.07.015. PMID: 21208779.21208779
56 Guyatt GH; Oxman AD; Sultan S; Glasziou P; Akl EA; Alonso-Coello P; Atkins D; Kunz R; Brozek J; Montori V; Jaeschke R; Rind D; Dahm P; Meerpohl J; Vist G; Berliner E; Norris S; Falck-Ytter Y; Murad MH; Schunemann HJ; Group GW. GRADE guidelines: 9. Rating up the quality of evidence. J Clin Epidemiol. 2011 Dec;64(12):1311-6. doi: 10.1016/j.jclinepi.2011.06.004. PMID: 21802902.21802902
57 Mosekilde L; Beck-Nielsen H; Sorensen OH; Nielsen SP; Charles P; Vestergaard P; Hermann AP; Gram J; Hansen TB; Abrahamsen B; Ebbesen EN; Stilgren L; Jensen LB; Brot C; Hansen B; Tofteng CL; Eiken P; Kolthoff N. Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women - results of the Danish Osteoporosis Prevention Study. Maturitas. 2000 Oct 31;36(3):181-93. PMID: 11063900.11063900
58 Schierbeck LL; Rejnmark L; Tofteng CL; Stilgren L; Eiken P; Mosekilde L; Kober L; Jensen JE. Effect of hormone replacement therapy on cardiovascular events in recently postmenopausal women: randomised trial. BMJ. 2012;345:e6409. PMID: 23048011.23048011
59 Tierney MC; Oh P; Moineddin R; Greenblatt EM; Snow WG; Fisher RH; Iazzetta J; Hyslop PS; MacLusky NJ. A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009 Aug;34(7):1065-74. doi: 10.1016/j.psyneuen.2009.02.009. PMID: 19297102.19297102
60 Hodis HN; Mack WJ; Lobo RA; Shoupe D; Sevanian A; Mahrer PR; Selzer RH; Liu Cr CR; Liu Ch CH; Azen SP. Estrogen in the prevention of atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2001 Dec 4;135(11):939-53. PMID: 11730394.11730394
61 Veerus P; Hovi SL; Fischer K; Rahu M; Hakama M; Hemminki E. Results from the Estonian postmenopausal hormone therapy trial [ISRCTN35338757]. Maturitas. 2006 Sep 20;55(2):162-73. doi: 10.1016/j.maturitas.2006.01.012. PMID: 16504428.16504428
62 Herrington DM; Reboussin DM; Brosnihan KB; Sharp PC; Shumaker SA; Snyder TE; Furberg CD; Kowalchuk GJ; Stuckey TD; Rogers WJ; Givens DH; Waters D. Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med. 2000 Aug 24;343(8):522-9. doi: 10.1056/nejm200008243430801. PMID: 10954759.10954759
63 Cherry N; Gilmour K; Hannaford P; Heagerty A; Khan MA; Kitchener H; McNamee R; Elstein M; Kay C; Seif M; Buckley H; team E. Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet. 2002 Dec 21-28;360(9350):2001-8. PMID: 12504395.12504395
64 Cherry N; McNamee R; Heagerty A; Kitchener H; Hannaford P. Long-term safety of unopposed estrogen used by women surviving myocardial infarction: 14-year follow-up of the ESPRIT randomised controlled trial. BJOG. 2014 May;121(6):700-5; discussion 5. doi: 10.1111/1471-0528.12598. PMID: 24533510.24533510
65 Greenspan SL; Resnick NM; Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. Am J Med. 2005 Nov;118(11):1232-9. doi: 10.1016/j.amjmed.2005.03.004. PMID: 16271907.16271907
66 Grady D; Applegate W; Bush T; Furberg C; Riggs B; Hulley SB. Heart and Estrogen/progestin Replacement Study (HERS): design, methods, and baseline characteristics. Control Clin Trials. 1998 Aug;19(4):314-35. PMID: 9683309.9683309
67 Grady D; Herrington D; Bittner V; Blumenthal R; Davidson M; Hlatky M; Hsia J; Hulley S; Herd A; Khan S; Newby LK; Waters D; Vittinghoff E; Wenger N; Group HR. Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II).[Erratum appears in JAMA 2002 Sep 4;288(9):1064]. JAMA. 2002 Jul 3;288(1):49-57. PMID: 12090862.12090862
68 Hulley S; Furberg C; Barrett-Connor E; Cauley J; Grady D; Haskell W; Knopp R; Lowery M; Satterfield S; Schrott H; Vittinghoff E; Hunninghake D; Group HR. Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. 2002 Jul 3;288(1):58-66. PMID: 12090863.12090863
69 Hulley S; Grady D; Bush T; Furberg C; Herrington D; Riggs B; Vittinghoff E. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998 Aug;280(7):605-13. PMID: 9718051.9718051
70 Kanaya AM; Herrington D; Vittinghoff E; Lin F; Grady D; Bittner V; Cauley JA; Barrett-Connor E; Heart; Estrogen/progestin Replacement S. Glycemic effects of postmenopausal hormone therapy: the Heart and Estrogen/progestin Replacement Study. A randomized, double-blind, placebo-controlled trial.[Summary for patients in Ann Intern Med. 2003 Jan 7;138(1):I10; PMID: 12513063]. Ann Intern Med. 2003 Jan 7;138(1):1-9. PMID: 12513038.12513038
71 Steinauer JE; Waetjen LE; Vittinghoff E; Subak LL; Hulley SB; Grady D; Lin F; Brown JS. Postmenopausal hormone therapy: does it cause incontinence? Obstet Gynecol. 2005 Nov;106(5 Pt 1):940-5. PMID: 16260510.16260510
72 Grady D; Yaffe K; Kristof M; Lin F; Richards C; Barrett-Connor E. Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med. 2002 Nov;113(7):543-8. PMID: 12459399.12459399
73 Gleason CE; Dowling NM; Wharton W; Manson JE; Miller VM; Atwood CS; Brinton EA; Cedars MI; Lobo RA; Merriam GR; Neal-Perry G; Santoro NF; Taylor HS; Black DM; Budoff MJ; Hodis HN; Naftolin F; Harman SM; Asthana S. Effects of Hormone Therapy on Cognition and Mood in Recently Postmenopausal Women: Findings from the Randomized, Controlled KEEPS-Cognitive and Affective Study. PLoS Med. 2015 Jun;12(6):e1001833; discussion e. doi: 10.1371/journal.pmed.1001833 [doi]; PMEDICINE-D-14-01484 [pii]. PMID: 26035291.26035291
74 Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial. JAMA. 1995 Jan 18;273(3):199-208. PMID: 7807658.7807658
75 Gallagher JC; Fowler SE; Detter JR; Sherman SS. Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001 Aug;86(8):3618-28. doi: 10.1210/jcem.86.8.7703. PMID: 11502787.11502787
76 Ettinger B; Ensrud KE; Wallace R; Johnson KC; Cummings SR; Yankov V; Vittinghoff E; Grady D. Effects of ultralow-dose transdermal estradiol on bone mineral density: a randomized clinical trial. Obstet Gynecol. 2004 Sep;104(3):443-51. PMID: 15339752.15339752
77 Johnson SR; Ettinger B; Macer JL; Ensrud KE; Quan J; Grady D. Uterine and vaginal effects of unopposed ultralow-dose transdermal estradiol. Obstet Gynecol. 2005;105(4):779-87. PMID: 15802405.15802405
78 Waetjen LE; Brown JS; Vittinghoff E; Ensrud KE; Pinkerton J; Wallace R; Macer JL; Grady D. The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. 2005 Nov;106(5 Pt 1):946-52. PMID: 16260511.16260511
79 Yaffe K; Vittinghoff E; Ensrud KE; Johnson KC; Diem S; Hanes V; Grady D. Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. Arch Neurol. 2006 Jul;63(7):945-50. doi: 10.1001/archneur.63.7.945. PMID: 16831962.16831962
80 Waters DD; Alderman EL; Hsia J; Howard BV; Cobb FR; Rogers WJ; Ouyang P; Thompson P; Tardif JC; Higginson L; Bittner V; Steffes M; Gordon DJ; Proschan M; Younes N; Verter JI. Effects of hormone replacement therapy and antioxidant vitamin supplements on coronary atherosclerosis in postmenopausal women: a randomized controlled trial. JAMA. 2002 Nov 20;288(19):2432-40. PMID: 12435256.12435256
81 Anderson GL; Judd HL; Kaunitz AM; Barad DH; Beresford SAA; Pettinger M; Liu J; McNeeley SG; Lopez AM; Women's Health Initiative I. Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women's Health Initiative randomized trial. JAMA. 2003 Oct 1;290(13):1739-48. PMID: 14519708.14519708
82 Canonico M; Plu-Bureau G; O'Sullivan MJ; Stefanick ML; Cochrane B; Scarabin PY; Manson JE. Age at menopause, reproductive history, and venous thromboembolism risk among postmenopausal women: the Women's Health Initiative Hormone Therapy clinical trials. Menopause. 2014 Mar;21(3):214-20. doi: 10.1097/GME.0b013e31829752e0 [doi]. PMID: 23760439.23760439
83 Cauley JA; Robbins J; Chen Z; Cummings SR; Jackson RD; LaCroix AZ; LeBoff M; Lewis CE; McGowan J; Neuner J; Pettinger M; Stefanick ML; Wactawski-Wende J; Watts NB; Women's Health Initiative I; Cauley JA; Robbins J; Chen Z; Cummings SR; Jackson RD; LaCroix AZ; LeBoff M; Lewis CE; McGowan J; Neuner J; Pettinger M; Stefanick ML; Wactawski-Wende J; Watts NB. Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women's Health Initiative randomized trial. JAMA. 2003 Oct 1;290(13):1729-38. PMID: 14519707.14519707
84 Chlebowski RT; Anderson GL; Gass M; Lane DS; Aragaki AK; Kuller LH; Manson JE; Stefanick ML; Ockene J; Sarto GE; Johnson KC; Wactawski-Wende J; Ravdin PM; Schenken R; Hendrix SL; Rajkovic A; Rohan TE; Yasmeen S; Prentice RL; Investigators WHI. Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA. 2010 Oct 20;304(15):1684-92. PMID: 20959578.20959578
85 Chlebowski RT; Hendrix SL; Langer RD; Stefanick ML; Gass M; Lane D; Rodabough RJ; Gilligan MA; Cyr MG; Thomson CA; Khandekar J; Petrovitch H; McTiernan A; Investigators WHI. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women's Health Initiative Randomized Trial. JAMA. 2003 Jun 25;289(24):3243-53. PMID: 12824205.12824205
86 Chlebowski RT; Schwartz AG; Wakelee H; Anderson GL; Stefanick ML; Manson JE; Rodabough RJ; Chien JW; Wactawski-Wende J; Gass M; Kotchen JM; Johnson KC; O'Sullivan MJ; Ockene JK; Chen C; Hubbell FA; Women's Health Initiative I. Oestrogen plus progestin and lung cancer in postmenopausal women (Women's Health Initiative trial): a post-hoc analysis of a randomised controlled trial. Lancet. 2009 Oct 10;374(9697):1243-51. PMID: 19767090.19767090
87 Chlebowski RT; Wactawski-Wende J; Ritenbaugh C; Hubbell FA; Ascensao J; Rodabough RJ; Rosenberg CA; Taylor VM; Harris R; Chen C; Adams-Campbell LL; White E; Women's Health Initiative I; Chlebowski RT; Wactawski-Wende J; Ritenbaugh C; Hubbell FA; Ascensao J; Rodabough RJ; Rosenberg CA; Taylor VM; Harris R; Chen C; Adams-Campbell LL; White E. Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med. 2004 Mar 4;350(10):991-1004. PMID: 14999111.14999111
88 Cirillo DJ; Wallace RB; Rodabough RJ; Greenland P; LaCroix A; Limacher MC; Larson JC. Effect of estrogen therapy on gallbladder disease. JAMA. 2005;293:330-9. PMID: 15657326.15657326
89 Cushman M; Kuller LH; Prentice R; Rodabough RJ; Psaty BM; Stafford RS; Sidney S; Rosendaal FR; Women's Health Initiative I. Estrogen plus progestin and risk of venous thrombosis. JAMA. 2004 Oct 6;292(13):1573-80. PMID: 15467059.15467059
90 Gramling R; Eaton CB; Rothman KJ; Cabral H; Silliman RA; Lash TL. Hormone replacement therapy, family history, and breast cancer risk among postmenopausal women. Epidemiology. 2009 Sep;20(5):752-6. PMID: 19451819.19451819
91 Hays J; Ockene JK; Brunner RL; Kotchen JM; Manson JE; Patterson RE; Aragaki AK; Shumaker SA; Brzyski RG; LaCroix AZ; Granek IA; Valanis BG; Women's Health Initiative I. Effects of estrogen plus progestin on health-related quality of life. N Engl J Med. 2003 May 8;348(19):1839-54. PMID: 12642637.12642637
92 Heiss G; Wallace R; Anderson GL; Aragaki A; Beresford SAA; Brzyski R; Chlebowski RT; Gass M; LaCroix A; Manson JE; Prentice RL; Rossouw J; Stefanick ML; Investigators WHI. Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. JAMA. 2008 Mar 5;299(9):1036-45. PMID: 18319414.18319414
93 Hendrix SL. The Women's Health Initiative estrogen plus progestin trial: the study and how it changes our practice. J Am Osteopath Assoc. 2003 Feb;103(2 Suppl 2):S3-5. PMID: 12625631.12625631
94 Hendrix SL; Cochrane BB; Nygaard IE; Handa VL; Barnabei VM; Iglesia C; Aragaki A; Naughton MJ; Wallace RB; McNeeley SG; Hendrix SL; Cochrane BB; Nygaard IE; Handa VL; Barnabei VM; Iglesia C; Aragaki A; Naughton MJ; Wallace RB; McNeeley SG. Effects of estrogen with and without progestin on urinary incontinence. JAMA. 2005 Feb 23;293(8):935-48. PMID: 15728164.15728164
95 Hsia J; Criqui MH; Rodabough RJ; Langer RD; Resnick HE; Phillips L; Allison M; Bonds D; Masaki K; Caralis P; Kotchen JM. Estrogen plus progestin and the risk of peripheral aerterial disease. Circulation. 2004;109(5):620-26. PMID: 14769684.14769684
96 Manson JE; Hsia J; Johnson KC; Rossouw JE; Assaf AR; Lasser NL; Trevisan M; Black HR; Heckbert SR; Detrano R; Strickland OL; Wong ND; Crouse JR; Stein E; Cushman M; Women's Health Initiative I. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003 Aug 7;349(6):523-34. PMID: 12904517.12904517
97 Margolis KL; Bonds DE; Rodabough RJ; Tinker L; Phillips LS; Allen C; Bassford T; Burke G; Torrens J; Howard BV; Women's Health Initiative I. Effect of oestrogen plus progestin on the incidence of diabetes in postmenopausal women: results from the Women's Health Initiative Hormone Trial. Diabetologia. 2004 Jul;47(7):1175-87. PMID: 15252707.15252707
98 Prentice RL; Manson JE; Langer RD; Anderson GL; Pettinger M; Jackson RD; Johnson KC; Kuller LH; Lane DS; Wactawski-Wende J; Brzyski R; Allison M; Ockene J; Sarto G; Rossouw JE. Benefits and risks of postmenopausal hormone therapy when it is initiated soon after menopause. Am J Epidemiol. 2009 Jul 1;170(1):12-23. doi: 10.1093/aje/kwp115. PMID: 19468079.19468079
99 Tang JY; Spaunhurst KM; Chlebowski RT; Wactawski-Wende J; Keiser E; Thomas F; Anderson ML; Zeitouni NC; Larson JC; Stefanick ML. Menopausal hormone therapy and risks of melanoma and nonmelanoma skin cancers: women's health initiative randomized trials. J Natl Cancer Inst. 2011 Oct 5;103(19):1469-75. doi: djr333 [pii]; 10.1093/jnci/djr333 [doi]. PMID: 21878677.21878677
100 Toh S; Hernandez-Diaz S; Logan R; Rossouw JE; Hernan MA Coronary heart disease in postmenopausal recipients of estrogen plus progestin therapy: does the increased risk ever disappear? A randomized trial.[Summary for patients in Ann Intern Med. 2010 Feb 16;152(4):I-40; PMID: 20157120]. Ann Intern Med. 2010 Feb 16;152(4):211-7. PMID: 20157135.20157135
101 Wassertheil-Smoller S; Hendrix SL; Limacher M; Heiss G; Kooperberg C; Baird A; Kotchen T; Curb JD; Black H; Rossouw JE; Aragaki A; Safford M; Stein E; Laowattana S; Mysiw WJ; Investigators WHI. Effect of estrogen plus progestin on stroke in postmenopausal women: the Women's Health Initiative: a randomized trial. JAMA. 2003 May 28;289(20):2673-84. PMID: 12771114.12771114
102 Manson JE; Chlebowski RT; Stefanick ML; Aragaki AK; Rossouw JE; Prentice RL; Anderson G; Howard BV; Thomson CA; LaCroix AZ; Wactawski-Wende J; Jackson RD; Limacher M; Margolis KL; Wassertheil-Smoller S; Beresford SA; Cauley JA; Eaton CB; Gass M; Hsia J; Johnson KC; Kooperberg C; Kuller LH; Lewis CE; Liu S; Martin LW; Ockene JK; O'Sullivan MJ; Powell LH; Simon MS; Van Horn L; Vitolins MZ; Wallace RB. Menopausal hormone therapy and health outcomes during the intervention and extended poststopping phases of the Women's Health Initiative randomized trials. JAMA. 2013 Oct 2;310(13):1353-68. doi: 1745676 [pii]; 10.1001/jama.2013.278040 [doi]. PMID: 24084921.24084921
103 Chlebowski RT; Anderson GL; Sarto GE; Haque R; Runowicz CD; Aragaki AK; Thomson CA; Howard BV; Wactawski-Wende J; Chen C; Rohan TE; Simon MS; Reed SD; Manson JE. Continuous combined estrogen plus progestin and endometrial cancer: The Women's Health Initiative Randomized Trial. J Natl Cancer Inst. 2016 Mar;108(3). doi: djv350 [pii]; 10.1093/jnci/djv350 [doi]. PMID: 26668177.26668177
104 Chlebowski RT; Rohan TE; Manson JE; Aragaki AK; Kaunitz A; Stefanick ML; Simon MS; Johnson KC; Wactawski-Wende J; O'Sullivan MJ; Adams-Campbell LL; Nassir R; Lessin LS; Prentice RL. Breast cancer after use of estrogen plus progestin and estrogen alone: analyses of data from 2 women's health initiative randomized clinical trials. JAMA Oncol. 2015 Jun;1(3):296-305. doi: 2250347 [pii]; 10.1001/jamaoncol.2015.0494 [doi]. PMID: 26181174.26181174
105 Anderson GL; Chlebowski RT; Aragaki AK; Kuller LH; Manson JE; Gass M; Bluhm E; Connelly S; Hubbell FA; Lane D; Martin L; Ockene J; Rohan T; Schenken R; Wactawski-Wende J. Conjugated equine oestrogen and breast cancer incidence and mortality in postmenopausal women with hysterectomy: extended follow-up of the Women's Health Initiative randomised placebo-controlled trial. Lancet Oncol. 2012 May;13(5):476-86. doi: 10.1016/s1470-2045(12)70075-x. PMID: 22401913.22401913
106 Bonds DE; Lasser N; Qi L; Brzyski R; Caan B; Heiss G; Limacher MC; Liu JH; Mason E; Oberman A; O'Sullivan MJ; Phillips LS; Prineas RJ; Tinker L. The effect of conjugated equine oestrogen on diabetes incidence: the Women's Health Initiative randomised trial. Diabetologia. 2006 Mar;49(3):459-68. PMID: 16440209.16440209
107 Brunner RL; Gass M; Aragaki A; Hays J; Granek I; Woods N; Mason E; Brzyski R; Ockene J; Assaf A; LaCroix A; Matthews K; Wallace R; Women's Health Initiative I. Effects of conjugated equine estrogen on health-related quality of life in postmenopausal women with hysterectomy: results from the Women's Health Initiative Randomized Clinical Trial. Arch Intern Med. 2005 Sep 26;165(17):1976-86. PMID: 16186467.16186467
108 Chlebowski RT; Anderson GL; Manson JE; Schwartz AG; Wakelee H; Gass M; Rodabough RJ; Johnson KC; Wactawski-Wende J; Kotchen JM; Ockene JK; O'Sullivan MJ; Hubbell FA; Chien JW; Chen C; Stefanick ML. Lung cancer among postmenopausal women treated with estrogen alone in the women's health initiative randomized trial. J Natl Cancer Inst. 2010 Sep 22;102(18):1413-21. PMID: 20709992.20709992
109 Curb JD; Prentice RL; Bray PF; Langer RD; Van Horn L; Barnabei VM; Bloch MJ; Cyr MG; Gass M; Lepine L; Rodabough RJ; Sidney S; Uwaifo GI; Rosendaal FR. Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med. 2006 Apr 10;166(7):772-80. PMID: 16606815.16606815
110 Hendrix SL; Wassertheil-Smoller S; Johnson KC; Howard BV; Kooperberg C; Rossouw JE; Trevisan M; Aragaki A; Baird AE; Bray PF; Buring JE; Criqui MH; Herrington D; Lynch JK; Rapp SR; Torner J; Investigators WHI. Effects of conjugated equine estrogen on stroke in the Women's Health Initiative. Circulation. 2006 May 23;113(20):2425-34. PMID: 16702472.16702472
111 Hsia J; Langer RD; Manson JE; Kuller L; Johnson KC; Hendrix SL; Pettinger M; Heckbert SR; Greep N; Crawford S; Eaton CB; Kostis JB; Caralis P; Prentice R. Conjugated equine estrogens and coronary heart disease: the Women's Health Initiative. Arch Intern Med. 2006 Feb 13;166(3):357-65. doi: 10.1001/archinte.166.3.357. PMID: 16476878.16476878
112 LaCroix AZ; Chlebowski RT; Manson JE; Aragaki AK; Johnson KC; Martin L; Margolis KL; Stefanick ML; Brzyski R; Curb JD; Howard BV; Lewis CE; Wactawski-Wende J; Investigators WHI. Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy: a randomized controlled trial. JAMA. 2011 Apr 6;305(13):1305-14. PMID: 21467283.21467283
113 Ritenbaugh C; Stanford JL; Wu L; Shikany JM; Schoen RE; Stefanick ML; Taylor V; Garland C; Frank G; Lane D; Mason E; McNeeley SG; Ascensao J; Chlebowski RT; Women's Health Initiative I. Conjugated equine estrogens and colorectal cancer incidence and survival: the Women's Health Initiative randomized clinical trial. Cancer Epidemiol Biomarkers Prev. 2008 Oct;17(10):2609-18. PMID: 18829444.18829444
114 Culhane NS. Estrogen plus progestin may increase incidence of dementia. J Fam Pract. 2003 Oct;52(10):754-5. PMID: 14529594.14529594
115 Espeland MA; Rapp SR; Shumaker SA; Brunner R; Manson JE; Sherwin BB; Hsia J; Margolis KL; Hogan PE; Wallace R; Dailey M; Freeman R; Hays J; Women's Health Initiative Memory S. Conjugated equine estrogens and global cognitive function in postmenopausal women: Women's Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2959-68. PMID: 15213207.15213207
116 Rapp SR; Espeland MA; Shumaker SA; Henderson VW; Brunner RL; Manson JE; Gass MLS; Stefanick ML; Lane DS; Hays J; Johnson KC; Coker LH; Dailey M; Bowen D; Investigators W. Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003 May 28;289(20):2663-72. PMID: 12771113.12771113
117 Shumaker SA; Legault C; Kuller L; Rapp SR; Thal L; Lane DS; Fillit H; Stefanick ML; Hendrix SL; Lewis CE; Masaki K; Coker LH; Women's Health Initiative Memory S. Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women's Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2947-58. PMID: 15213206.15213206
118 Shumaker SA; Legault C; Rapp SR; Thal L; Wallace RB; Ockene JK; Hendrix SL; Jones BN, 3rd; Assaf AR; Jackson RD; Kotchen JM; Wassertheil-Smoller S; Wactawski-Wende J; Investigators W. Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003 May 28;289(20):2651-62. PMID: 12771112.12771112
119 Espeland MA; Shumaker SA; Leng I; Manson JE; Brown CM; LeBlanc ES; Vaughan L; Robinson J; Rapp SR; Goveas JS; Wactawski-Wende J; Stefanick ML; Li W; Resnick SM. Long-term effects on cognitive function of postmenopausal hormone therapy prescribed to women aged 50 to 55 years. JAMA internal medicine; 2013. p. 1429-36.23797469
120 Espeland MA; Brunner RL; Hogan PE; Rapp SR; Coker LH; Legault C; Granek I; Resnick SM; Women's Health Initiative Study of Cognitive Aging Study G. Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women's Health Initiative study of cognitive aging extension. J Am Geriatr Soc. 2010 Jul;58(7):1263-71. PMID: 20649689.20649689
121 Resnick SM; Espeland MA; An Y; Maki PM; Coker LH; Jackson R; Stefanick ML; Wallace R; Rapp SR; Women's Health Initiative Study of Cognitive Aging Investigators. Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. J Clin Endocrinol Metab. 2009 Nov;94(11):4152-61. PMID: 19850684.19850684
122 Resnick SM; Maki PM; Rapp SR; Espeland MA; Brunner R; Coker LH; Granek IA; Hogan P; Ockene JK; Shumaker SA; Women's Health Initiative Study of Cognitive Aging I. Effects of combination estrogen plus progestin hormone treatment on cognition and affect. J Clin Endocrinol Metab. 2006 May;91(5):1802-10. PMID: 16522699.16522699
123 Vickers MR; MacLennan AH; Lawton B; Ford D; Martin J; Meredith SK; DeStavola BL; Rose S; Dowell A; Wilkes HC; Darbyshire JH; Meade TW. Main morbidities recorded in the women's international study of long duration oestrogen after menopause (WISDOM): a randomised controlled trial of hormone replacement therapy in postmenopausal women. BMJ. 2007 Aug 4;335(7613):239. doi: 10.1136/bmj.39266.425069.AD. PMID: 17626056.17626056
124 Clarke SC; Kelleher J; Lloyd-Jones H; Slack M; Schofiel PM. A study of hormone replacement therapy in postmenopausal women with ischaemic heart disease: the Papworth HRT atherosclerosis study. BJOG. 2002 Sep;109(9):1056-62. PMID: 12269682.12269682
125 Notelovitz M; John VA; Good WR Effectiveness of Alora estradiol matrix transdermal delivery system in improving lumbar bone mineral density in healthy, postmenopausal women. Menopause. 2002 Sep-Oct;9(5):343-53. PMID: 12218723.12218723
126 Pefanco MA; Kenny AM; Kaplan RF; Kuchel G; Walsh S; Kleppinger A; Prestwood K. The effect of 3-year treatment with 0.25 mg/day of micronized 17beta-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. 2007 Mar;55(3):426-31. doi: 10.1111/j.1532-5415.2007.01085.x. PMID: 17341247.17341247
127 Resnick SM; Coker LH; Maki PM; Rapp SR; Espeland MA; Shumaker SA. The Women's Health Initiative Study of Cognitive Aging (WHISCA): a randomized clinical trial of the effects of hormone therapy on age-associated cognitive decline. Clin Trials. 2004;1(5):440-50. PMID: 16279282.16279282
128 Vickers MR; Martin J; Meade TW; Arasaratnum N; Collins N; Furness P; Ghali M; Gordon E; Huppert F; Islam Z; Knott C; Meredith S; Prince M; Purdon S; Richards M; Taylor L; Welton A; Zhu CQ; Zuhrie R; Dowell A; Lawton B; MacLennon A. The Women's International Study of Long-duration Oestrogen after Menopause (WISDOM): a randomised controlled trial. BMC Womens Health 2007;7(2). PMID: 17324282.17324282
129 Harman SM; Black DM; Naftolin F; Brinton EA; Budoff MJ; Cedars MI; Hopkins PN; Lobo RA; Manson JE; Merriam GR; Miller VM; Neal-Perry G; Santoro N; Taylor HS; Vittinghoff E; Yan M; Hodis HN. Arterial imaging outcomes and cardiovascular risk factors in recently menopausal women: a randomized trial. Ann Intern Med. 2014 Aug 19;161(4):249-60. doi: 10.7326/m14-0353. PMID: 25069991.25069991
130 Beral V; Gaitskell K; Hermon C; Moser K; Reeves G; Peto R. Menopausal hormone use and ovarian cancer risk: individual participant meta-analysis of 52 epidemiological studies. Lancet. 2015 May 9;385(9980):1835-42. doi: 10.1016/S0140-6736(14)61687-1. PMID: 25684585.25684585
131 McEvoy GK, ed AHFS Drug Information(r). 58th ed. Bethesda, MD: American Society of Health-System Pharmacists; 2016.
132 Wathen CN; Feig DS; Feightner JW; Abramson BL; Cheung AM. Hormone replacement therapy for the primary prevention of chronic diseases: recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ. 2004 May 11;170(10):1535-7. PMID: 15136543.15136543
133 Goodman NF; Cobin RH; Ginzburg SB; Katz IA; Woode DE. American Association of Clinical Endocrinologists Medical Guidelines for Clinical Practice for the diagnosis and treatment of menopause: executive summary of recommendations. Endocr Pract. 2011 Nov-Dec;17(6):949-54. doi: 02385477X7V38958 [pii]. PMID: 22193145.22193145
134 Mosca L; Benjamin EJ; Berra K; Bezanson JL; Dolor RJ; Lloyd-Jones DM; Newby LK; Pina IL; Roger VL; Shaw LJ; Zhao D; Beckie TM; Bushnell C; D'Armiento J; Kris-Etherton PM; Fang J; Ganiats TG; Gomes AS; Gracia CR; Haan CK; Jackson EA; Judelson DR; Kelepouris E; Lavie CJ; Moore A; Nussmeier NA; Ofili E; Oparil S; Ouyang P; Pinn VW; Sherif K; Smith SC, Jr.; Sopko G; Chandra-Strobos N; Urbina EM; Vaccarino V; Wenger NK. Effectiveness-based guidelines for the prevention of cardiovascular disease in women - 2011 update: a guideline from the American Heart Association. Circulation. 2011;123(11):1243-62. PMID: 21325087.21325087
135 American Academy of Family Physicians. Hormone Replacement Therapy: Clinical Preventive Service Recommendation. Leawood, KS: American Academy of Family Physicians. http://www.aafp.org/patient-care/clinical-recommendations/all/hrt.html. Accessed on April 13, 2015.
136 American Family Physician. ACOG Releases Practice Bulletin on Osteoporosis. Am Fam Physician. 2013 August 15;88(4):269-75.23944732
137 American College of Physicians. ACP Clinical Practice Guidelines. Philadelphia: American College of Physicians; 2015. http://www.acponline.org/clinical_information/guidelines/guidelines/. Accessed on April 13, 2015.
138 Hill DA; Hill SR. Counseling patients about hormone therapy and alternatives for menopausal symptoms. Am Fam Physician. 2010 Oct 1;82(7):801-7. PMID: 20879703.20879703