# Acknowledgments

The authors acknowledge the following individuals for their contributions to this project and appreciate their considerable support, commitment, and contributions: Tina Fan, MD, MPH, AHRQ Medical Officer; Howard Tracer, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director, U.S. Preventive Services Task Force; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Cindy Farquhar, MD, MPH, The University of Auckland, JoAnn Manson, MD, MPH, DrPH, Brigham and Women's Hospital, Anita Nelson, MD, and Susan Reed, MD, MPH, University of Washington School of Medicine; four federal partner reviewers from the National Institutes of Health; Evelyn Whitlock, MD, MPH, former Director of the Kaiser Permanente Research Affiliates EPC; RTI International–University of North Carolina EPC staff: Dan Jonas, MD, MPH, Co-Director, Carol Woodell, Project Manager, research assistants Emmanuel Coker-Schwimmer, MPH, Catherine Aspden Grodensky, MPH, Huiling Pan, BA, Stephanie Scope, BS, Lynn Whitener, DrPH, MSPH, librarian, Sharon Barrell, MA, editor, and Loraine Monroe, publications specialist.