# Chapter 4 Discussion

This chapter begins with a summary of review findings for each KQ. Following those sections, we present limitations of the evidence and the review, and end with conclusions. Our searches also addressed two contextual questions on the duration of hormone therapy use and differences in use by subgroups (see the Methods section for detailed contextual questions). For both questions, we did not find any studies of interest and, therefore, do not discuss contextual questions any further in this chapter.

## Summary of Review Findings

### Benefits and Harms of Hormone Therapy (KQs 1 and 2)

Eighteen trials (reported in 68 publications) comparing the effects of estrogen only or estrogen plus progestin versus placebo for preventing chronic conditions in postmenopausal women met our eligibility criteria. Tables 6 and 7 summarize findings, SOE, and applicability for various outcomes for both KQs 1 and 2.

The WHI was the only trial designed and powered to evaluate the effectiveness of hormone therapy for the primary prevention of the multiple conditions that are the focus of this review. The WHI met criteria for fair quality, and it provided most of the estimates of benefits and harms. Including the posttrial phases, it had up to 13 years of followup to assess how risk of chronic conditions change after women stopped hormone therapy.

Results of our review indicate some benefits of hormone therapy regarding the prevention of chronic conditions (KQ 1). For women using estrogen only, risk of diabetes (137 fewer cases per 10,000 women over 7.1 years) and fractures (382 fewer cases per 10,000 women over 6.8 years) was statistically significantly reduced compared with women taking placebo. Women using estrogen plus progestin therapy experienced statistically significantly reduced risk of colorectal cancer (33 fewer cases per 10,000 women over 5.6 years), diabetes (77 fewer cases per 10,000 women over 5.6 years), and fractures (222 fewer cases per 10,000 women over 5.0 years) compared with women in the placebo groups.

Our review also documented several important harms of hormone therapy (KQ 2). Women taking estrogen-only therapy had statistically significantly increased risk of gallbladder disease (213 more cases per 10,000 women over 7.1 years), stroke (79 more cases per 10,000 women over 7.1 years), urinary incontinence (1,261 more cases per 10,000 women over 1 year), and venous thromboembolism (78 more cases per 10,000 women over 7.1 years) compared with women in the placebo groups.

Likewise, for women taking estrogen plus progestin therapy, risk of invasive breast cancer (52 more cases per 10,000 women over 5.6 years), probable dementia (88 more cases per 10,000 women over 4 years), gallbladder disease (116 more cases per 10,000 women over 5.6 years), stroke (53 more cases per 10,000 women over 5.6 years), urinary incontinence (876 more cases per 10,000 women over 1 year), and venous thromboembolism (120 more cases per 10,000 women over 5.6 years) was statistically significantly increased compared with women taking placebo.

The WHI used a global index based on beneficial and harmful events to assess the tradeoff between advantages and disadvantages of hormone therapy. Overall, estrogen plus progestin led to 20 additional adverse events per 10,000 person-years (HR, 1.12 [95% CI, 1.02 to 1.24]).^102^ For women who were randomized to estrogen-only therapy, the global index did not show a statistically significant difference in overall beneficial or harmful events (HR, 1.03 [95% CI, 0.93 to 1.13]).

### Information About Subgroups of Women (KQ 3)

Subgroups (KQ 3) of interest for this report include the following characteristics: race/ethnicity; women with premature menopause; women with surgical menopause; age; duration of use; type, dose, and mode of delivery of hormone therapy; and presence of coexisting conditions. Table 8 summarizes findings, SOE, and applicability for subgroups for both treatment regimens (KQ 3).

Trials did not report results for most of these subgroups. Subgroup analyses of trial results based on these characteristics were restricted to race/ethnicity, age, and a limited number of comorbid conditions or risk factors. In general, tests of interactions did not detect any statistically significant subgroup effects that are of interest for this report. An exception is the influence of age on myocardial infarction, colorectal cancer, and all-cause mortality. Analyses that compared younger (ages 50 to 59 years) with older (ages 70 to 79 years) women using estrogen-only therapy yielded a statistically significant trend for increasing risk by age for myocardial infarction (p=0.02 for trend), colorectal cancer (p=0.02 for trend), and all-cause mortality (p=0.04 for trend).

These findings, however, have to be interpreted cautiously. For example, only 489 women died in the WHI estrogen-only trial, which could lead to chance findings when assessing differences in subgroups.

Recent subgroup analyses of the WHI regarding the effect of timing on risk of coronary events provide consistent findings. Time since menopause did not have a statistically significant effect on the risk of coronary heart disease in women using estrogen-only therapy. Women who initiated combination therapy within 10 years of menopause did not have an increased coronary risk compared with those who initiated later. Early initiation in this group, however, also did not lead to any beneficial effects regarding cardiovascular risk. It remains unclear whether a shorter time interval than 10 years might have been a more appropriate measure to assess the effect of timing. An additional subgroup analysis took hormone therapy use before enrollment into the WHI into consideration (e.g., about 40% of women in the estrogen-only trial used hormone therapy before enrollment) and also found no difference in coronary risk between early and late initiation of hormone therapy.

Two recent trials, KEEPS and ELITE,^29, 129^ addressed whether timing of therapy initiation affected either benefits or harms of hormone therapy. Both trials enrolled women who were younger than participants in the WHI. Both trials assessed surrogate outcomes of cardiovascular disease (primary outcome in both trials was carotid artery intima-media thickness). They provided mixed results regarding beneficial effects of early initiation of hormone therapy on carotid artery intima-media thickness.

A recent Cochrane review assessed the timing hypothesis by stratifying trials in a meta-analysis according to when any hormone therapy treatment was started (the review did not stratify between estrogen-only and combination hormone therapy, which is a substantial limitation of this review).^19^ If this information was not available, the authors used the mean age of participants at baseline as a surrogate. Results provided some support of the timing hypothesis. All-cause mortality was lower in the subgroup of studies in which treatment was started within 10 years of menopause compared with studies in which more than 10 years had elapsed (p=0.01). Likewise, the risk of coronary heart disease was lower in women who initiated hormone therapy early (p=0.02). Nevertheless, because of issues of potential ecological fallacy, findings of such study-level analyses have to be viewed cautiously.

Another study that is sometimes viewed as supporting the timing hypothesis is the Danish Osteoporosis Prevention Study.^58^ We did not consider this study because of poor quality due to lack of blinding of outcomes assessors. The study included 1,006 women who, on average, were younger than those in the WHI; it reported that hormone therapy given to early postmenopausal women reduced the risk of cardiovascular disease without any significant increase in harms after 10 years of treatment and 16 years of cumulative followup. These findings would support the timing hypothesis, but they are limited by the small number of events and the precision of the estimates. For example, during 10 years of treatment, only 49 cardiovascular events took place.

To date, the evidence regarding the effect of dose and mode of delivery of hormone therapy on benefits and risks is still insufficient to draw firm conclusions. In treatment studies, progestins and natural progesterones differ in their metabolic action and risk of harms such as adverse effects on blood lipids, breast tenderness, and headaches. The risk-benefit profile of each type of progestin and progesterone for use in hormone therapy is currently still unclear.^19^

For this report, the PEPI trial was the only eligible study that used different types (regular synthetic and micronized progestins) and regimens of progestins (continuous and sequential progestin regimens) within the same study.^74^ Results reported no differences in benefits and harms between different types and regimens. The sample size of the PEPI trial (N=875) was too small to detect potential differences in outcomes that are of interest for this report. All the other studies included in this review used continuous progestin regimens.

## Limitations and Future Research

In our analyses, we stratified results by regimen because findings from the WHI suggested that the risk-benefit profiles for estrogen-only and estrogen plus progestin therapy are different. As a consequence, we were not able to include three trials that did not report results stratified by treatment regimen in our analyses.^65, 75, 80^

The WHI provided the best and most applicable information for many of our outcomes of interest. To date, more than 130 articles have been published on the WHI trials. During our review, we noticed that effect estimates were not always consistent across various publications. Because it was impossible for us to discern which were the most correct estimates, in general, we relied on articles that focused on specific outcomes (e.g., gallbladder disease, urinary incontinence), when available. In general, differences in effect estimates affected the magnitude of risks and benefits but never the direction of effects. For each effect estimate that we present in the report, we provide the respective citation of the WHI publication.

Low event rates also limited conclusions for some outcomes in the report. For example, in the WHI estrogen plus progestin trial, only 40 women developed ovarian cancer. Likewise, event rates for cervical and endometrial cancer were low, rendering wide CIs that encompassed clinically meaningful differences in risk. The confidence in conclusions about benefits and risks of hormone therapy regarding these outcomes is low.

A recent analysis of individual patient data from 52 epidemiological studies on more than 21,000 women with ovarian cancer detected a higher risk of ovarian cancer in women who used hormone therapy (RR, 1.37 [95% CI, 1.29 to 1.46]).^130^ The risk was similar between estrogen-only and estrogen plus progestin therapies. Even 10 years after stopping long-duration hormone therapy, risk of serious and endometrioid ovarian tumors were still elevated (RR, 1.25 [95% CI, 1.07 to 1.46]).

Some outcomes that relied on self-reporting (e.g., diabetes and urinary incontinence) might be affected by potential biases, or limited by disparate adherence rates (e.g., cognitive function) (WHIMS: 61.4% vs. 32.3% for placebo vs. estrogen plus progestin, respectively). Trials often used different measures for ascertaining outcomes, which limited comparisons across trials. For cognitive function, WHIMS was the only trial to use a thorough adjudication process for probable dementia and mild cognitive impairment, whereas other trials used batteries of cognitive tests. For diabetes, the WHI relied on participants' self-reports of new diagnoses or new treatment for diabetes, whereas HERS used fasting glucose levels. For urinary incontinence, all trials relied on self-reported measures.

In addition, we did not find any evidence on functional capacity.

The main limitation of our review process was that we restricted our review to trials published in English-language journals. However, we did not identify any relevant trials from English-language abstracts of non-English journals, additional citation searches, or expert reviewers. Given the large number of eligible trials for this report, the effect of potentially missed non-English publications on the overall effect estimates and conclusions is probably negligible.

Most trials had high attrition or low adherence to medications; this was true even for the WHI, in which 40 to 50 percent of participants discontinued their medications during the trial. Nevertheless, secondary analyses of the WHI limited to adherent women (i.e., censoring women within 6 months of reporting with <80% compliance with study pills) were generally similar to intention-to-treat results^102^ but with accentuated findings. For example, the adherence-adjusted HRs for breast cancer were 0.58 (95% CI, 0.39 to 0.84) for women taking estrogen-only therapy and 1.52 (95% CI, 1.15 to 2.00) for women taking estrogen plus progestin (compared with HR, 0.79 [95% CI, 0.61 to 1.02] and HR, 1.26 [95% CI, 1.02 to1.55], respectively, in the intention-to treat analyses).^102^

The applicability of our findings may be limited by three main aspects. First, the average age of women in the included studies ranged from 50 to 79 years, which is older than the average age of women experiencing menopause (51 years). For example, in the WHI, the average age of women was 64 years; approximately 30 percent of women in the WHI were ages 50 to 59 years at the time of enrollment. Second, the majority of women (around 80%) were white. Subgroup analyses did not did reveal differences in beneficial or harmful effects among racial/ethnic groups, but such analyses might have been underpowered. Third, the majority of findings came from the WHI, which tested only one dose, formulation, and route of administration of hormone therapy in each trial (0.625 mg/day of oral conjugated equine estrogen, with or without 2.5 mg/day of medroxyprogesterone). The PEPI trial was the only study that directly compared different formulations of estrogen and progestin combinations. To date, however, the evidence regarding the effect of different formulations, doses, and modes of delivery of hormone therapy on benefits and risks is insufficient to draw firm conclusions.

Continuing research on long-term outcomes, such as cancer and mortality, will be important to provide a full understanding of the implications of hormone therapy. In the WHI studies, some of the risk reductions and increases disappeared after women had stopped treatment. Other risk, such as risk of invasive breast cancer, were still elevated years after women had stopped estrogen plus progestin treatment. Given that most women who use hormone therapy start treatment of menopausal symptoms during perimenopause or early postmenopause, future research needs to further explore the effect of early initiation on health outcomes and the primary prevention of chronic diseases. Future studies also need to explore the comparative benefits and harms of different formulations and treatment durations of hormone therapy.

Finally, most subgroup analyses of the WHI were probably not powered to detect clinically relevant differences between subgroups of interest. Combining individual patient data from all trials to conduct individual patient data meta-analyses could probably overcome this issue and provide more definitive answers.

## Conclusions

Depending on the treatment regimen, the risk-benefit profile of hormone therapy for the prevention of chronic conditions differs for women ages 50 to 79 years. Women undergoing hormone therapy experience some beneficial effects (e.g., reduced risk of fractures or diabetes) but also an increased risk of harms (e.g., higher risk of stroke, thromboembolic events, gallbladder disease, and urinary incontinence), particularly among women older than age 60 years. Some evidence suggests that age at the initiation of hormone therapy can modify the risk-benefit profile, particularly for overall mortality and cardiovascular events. To date, however, the available evidence regarding benefits and harms of early initiation of hormone therapy is inconclusive.