# Chapter 3 Results

This chapter begins with the results of our literature searches and a general description of the included trials that form the basis of our analyses and findings. As noted, we used systematic reviews only for finding trials of hormone therapy that our searches might have missed. Furthermore, because we had adequate evidence based on trials, we do not present information on controlled cohort studies.

Following those sections, we present a summary of the available trial evidence regarding benefits and harms (KQ 1 and KQ 2) and differences of effects in subgroups (KQ 3). We then document the evidence in more detail for each outcome of interest stratified by the hormone therapy treatment (estrogen only or estrogen plus progestin).

Because results of the WHI have been published in multiple publications, we chose articles that focused on specific outcomes (e.g., gallbladder disease, urinary incontinence) over more general publications, when available.

## Results of Literature Searches

The update of this report identified 2,241 citations. Of these, 1,989 abstracts were excluded and investigators reviewed 252 full-text articles. We retained 17 articles reporting on 13 trials that met inclusion criteria (Appendix B). Overall, 68 articles from the previous review and this update represented a total of 18 good- or fair-quality trials.^39^ Appendix D documents the disposition of the articles identified from searches (i.e., the flowchart of the literature). Appendix E lists articles excluded at full-text review.

## Description of Trials

Included articles provided data on 40,058 perimenopausal and postmenopausal women comparing the effects of estrogen, either alone or in combination with progestin, versus placebo for the prevention of chronic conditions. These trials specifically were the following:^57, 58^ Estrogen Memory Study (EMS),^59^ Estrogen in the Prevention of Atherosclerosis Trial (EPAT),^60^ Estonian Postmenopausal Hormone Therapy Trial (EPHT),^61^ Estrogen Replacement and Atherosclerosis Study (ERA),^62^ Oestrogen in the Prevention of Reinfarction Trial (ESPRIT),^63, 64^ Greenspan et al, 2005,^65^ Heart and Estrogen Replacement Study (HERS),^66-72^ Kronos Early Estrogen Prevention Study–Cognitive and Affective Study (KEEPS-Cog),^73^ Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial,^74^ STOP-IT,^75^ Ultra-Low-Dose Transdermal Estrogen Assessment (ULTRA),^76-79^ Women's Angiographic Vitamin and Estrogen (WAVE) Trial,^80^ WHI estrogen plus progestin trial,^23, 35, 81-104^ WHI estrogen-only trial,^24, 35, 82, 88, 94, 98, 99, 102, 104-113^ WHI Memory Study (WHIMS),^114-118^ WHI Memory Study of Younger Women (WHIMSY),^119^ WHI Study of Cognitive Aging (WHISCA),^120-122^ and Women's International Study of Long Duration Oestrogen After Menopause (WISDOM).^123^

Of the 18 included trials, 13 were conducted in the United States. The remaining trials were conducted in Australia, Canada, Estonia, New Zealand, and the United Kingdom. The duration of followup in the trials averaged 3.5 years. The mean age of women participating in trials ranged from 53 (KEEPS-Cog) to 79 years (EMS). The majority of women were white; the proportions of nonwhite women ranged from 1 (WISDOM) to 41 percent (EPHT). The proportions of women with previous or current hormone therapy use ranged from 2 to 54.5 percent. A range of 3.7 to 58 percent of women in the trials were current smokers.

Of the 18 included studies, the WHI trials were the only studies powered to assess the effectiveness of hormone therapy for the primary prevention of various chronic conditions. They enrolled generally healthy postmenopausal women ages 50 to 79 years and compared 0.625 mg/day of oral conjugated equine estrogen, with or without 2.5 mg/day of medroxyprogesterone, with placebo. The WHI trials also had the longest durations of followup among included trials (median of 7.2 years for the estrogen-only trial and 5.6 years for the estrogen plus progestin trial).

Table 3 summarizes the main characteristics and quality ratings of the eligible trials named above. Of these, all but five were rated fair quality. We rated four trials as poor quality and do not include them in these tables or analyses.^57, 124-126^ Three trials (described in Table 3) met eligibility criteria but did not stratify results by regimen (i.e., whether women used estrogen only or estrogen plus progestin).^65, 75, 80^ Table 4 presents baseline characteristics of participants in included trials. Outcomes data from included trials are presented in Appendix G.

Table 3 Characteristics of Randomized, Controlled Trials of Use of Hormone Therapy

Trial Name (Acronym) | Author, Year | Country; Participants | Intervention; Duration | Quality Rating
Estrogen Memory Study (EMS) | Tierney et al, 2009^59^ | - Canada; - Ages 61-87 years; - Last menstrual cycle >12 months before screening; - Fluent in English and could read normal print and hear normal speech | 17β-estradiol 1 mg/day for 4 days then 17β-estradiol 1 mg plus norethindrone 0.35 mg/day for 3 days, repeated every week (N=70) Placebo (N=72) 2 years | Fair
Estrogen in the Prevention of Atherosclerosis (EPAT) | Hodis et al, 2011^60^ | - United States; - Postmenopausal women; - Ages 46–80 years; - Low-density lipoprotein cholesterol level ≥130 mg/dL | Micronized 17β-estradiol 1 mg/day (N=111) Placebo (N=111) 2 years | Fair
Estonian Postmenopausal Hormone Therapy Trial (EPHT) | Veerus et al, 2003^61^ | - Estonia; - Ages 50–64 years; - An elapsed ≥12 months since last period at the randomization stage | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=404) Placebo (N=373) Mean 3.4 years | Fair
Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis (ERA) | Herrington et al, 2000^62^ | - United States; - Ages 41–79 years; - Postmenopausal women not currently receiving estrogen replacement therapy; - With >1 epicardial coronary stenosis of ≥30% of the luminal diameter | CEE 0.625 mg/day (N=100) CEE 0.625 mg/day plus MPA 2.5 mg/day (N=104) Placebo (N=105) 3 years | Fair
Oestrogen in the Prevention of Reinfarction Trial (ESPRIT) | Cherry et al, 2002^63^ | - United Kingdom; - Ages 50–69 years; - Admitted to coronary care units or general medical wards in participating hospitals; - Met diagnostic criteria for initial myocardial infarction; - Discharged from hospital within 31 days of admission | Estradiol valerate 2 mg/day (N=513) Placebo (N=504) 2 years | Fair
Greenspan et al | Greenspan et al, 2005^65^ | - United States; - Ages 65–90 years; - Community-dwelling women | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=187) Placebo (N=186) 3 years | Good
Heart and Estrogen/Progestin Replacement Study (HERS) | Grady et al, 1998;^66^ Hulley et al, 1998;^69^ Kanaya et al, 2003;^70^ Steinauer et al, 2005^71^ | - United States; - Age ≤80 years (mean, 66.7); - Intact uterus; - Postmenopausal; - Established coronary artery disease | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=1,380) Placebo (N=1,383) Mean 4.1 years | Good
Kronos Early Estrogen Prevention Study–Cognitive and Affective Study (KEEPS-Cog) | Gleason et al, 2015^73^ | - United States; - Ages 42–58 years; - Intact uterus; - Recently postmenopausal; - At risk for cardiovascular disease | CEE 0.45 mg/day plus MP 200 mg/day for 12 days/month (N=220) Transdermal estradiol 50 μg/day plus MP 200 mg/day for 12 days/month (N=211) Placebo (N=262) 4 years | Fair
Postmenopausal Estrogen and Progestin Interventions Trial (PEPI) | PEPI, 1995^74^ | - United States; - Ages 45–64 years; - With or without a uterus; - Naturally or surgically menopausal | CEE 0.625 mg/day (N=175) CEE 0.625 mg/day plus MPA 10 mg/day for 12 days/month (N=174) CEE 0.625 mg/day plus MP 200 mg/day for 12 days/month (N=178) Placebo (N=174) 3 years | Fair
STOP-IT | Gallagher et al, 2001^75^ | - United States; - Ages 65–77 years; - Femoral neck density within normal range for age | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=121) CEE 0.625 mg/day plus MPA 2.5 mg/day plus calcitriol 0.25 μg twice daily (N=122) Calcitriol 0.25 μg twice daily (N=123) Placebo (N=123) 3 years | Fair
Ultra-Low-Dose Transdermal Estrogen Assessment (ULTRA) | Ettinger et al, 2004;^76^ Johnson et al, 2005;^77^ Waetjen et al, 2005;^78^ Yaffe et al, 2006^79^ | - United States; - Ages 60–80 years; - Intact uterus; - ≥5 years past menopause; - Bone mineral density normal for age | Unopposed transdermal estradiol 0.014 mg/day (N=208) Placebo (N=209) 2 years | Good
Women's Angiographic Vitamin and Estrogen Trial (WAVE) | Waters et al, 2002^80^ | - United States, Canada; - Postmenopausal; - Mean age of 65 years; - Coronary angiogram performed within 4 months of study entry | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=210) Placebo (N=213) Mean 2.8 years | Fair
Women's Health Initiative (WHI) E Trial | Anderson et al, 2004;^24^ Bonds et al, 2006;^106^ Brunner et al, 2005;^107^ Chlebowski et al, 2010;^108^ Cirillo et al, 2005;^88^ Curb et al, 2006;^109^ Hendrix et al, 2005;^94^ Hendrix et al, 2006;^110^ Hsia et al, 2006;^111^ Manson et al, 2013;^102^ Ritenbaugh et al, 2008;^113^ Rossouw et al, 2007^35^ | - United States; - Postmenopausal; - Ages 50–79 years; - Prior hysterectomy; - 3-month washout period required for women using hormone therapy at baseline | CEE 0.625 mg/day (N=5,310) Placebo (N=5,429) Median 7.2 years | Fair
WHI E Postintervention and Postintervention Extension Phases | Chlebowski et al, 2010;^84^ LaCroix et al, 2011;^112^ Manson et al, 2013^102^ | 9,666 participants from WHI (90%) had any postintervention followup and 7,645 (71%) consented to participate in the extension phase | CEE 0.625 mg/day (N=5,310) Placebo (N=5,429) Mean 6.6 years | Fair
WHI E+P Trial | Anderson et al, 2012;^105^ Anderson et al, 2003;^81^ Canonico et al, 2014;^82^ Cauley et al, 2003;^83^ Chlebowski et al, 2003;^85^ Chlebowski et al, 2004;^87^ Cirillo et al, 2005;^88^ Cushman et al, 2004;^89^ Hays et al, 2003;^91^ Hendrix et al, 2003;^93^ Hendrix et al, 2005;^94^ Hsia et al, 2004;^95^ Manson et al, 2003;^96^ Manson et al, 2013;^102^ Margolis et al, 2004;^97^ Prentice et al, 2009;^98^ Rossouw et al, 2002;^23^ Rossouw et al, 2007;^35^ Tang et al, 2011;^99^ Toh et al, 2010;^100^ Wassertheil-Smoller et al, 2003^101^ | - United States; - Postmenopausal; - Ages 50–79 years; - 3-month washout period for women using hormone therapy at baseline | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=8,506) Placebo (N=8,102) Median 5.6 years | Fair
WHI E+P Postintervention and Postintervention Extension Phases | Chlebowski et al, 2009;^86^ Chlebowski et al, 2010;^84^ Gramling et al, 2009;^90^ Heiss et al, 2008;^92^ Manson et al, 2013^102^ | 15,747 participants from WHI (95%) had any postintervention followup and 12,788 (77%) consented to participate in the extension phase | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=8,506) Placebo (N=8,102) Median 8.2 years | Fair
Women's Health Initiative Memory Study (WHIMS) E | Espeland et al, 2004;^115^ Shumaker et al, 2004^117^ | - United States; - WHI participants enrolled in the estrogen-only trial; - Ages 65–79 years; - Free of probable dementia; - Able and willing to undergo annual cognitive assessment | CEE 0.625 mg/day (N=1,464) Placebo (N=1,483) 5.2 years | Good
WHIMS E+P | Culhane, 2003;^114^ Rapp et al, 2003;^116^ Shumaker et al, 2003^118^ | - United States; - WHI participants enrolled in the E+P trial; - Age >65 years; - Free of probable dementia; - Able and willing to undergo annual cognitive assessment | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=2,229) Placebo (N=2,303) 5.4 years | Good
Women's Health Initiative Memory Study of Younger Women (WHIMSY) | Espeland et al, 2013^119^ | - United States; - Postmenopausal; - Ages 50–55 years; - 3-month washout period for women using hormone therapy at baseline | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=696) Placebo (N=630) 7.2 years | Fair
Women's Health Initiative Study of Cognitive Aging (WHISCA) E | Espeland et al, 2010;^120^ Resnick et al, 2009^121^ | - United States; - WHIMS E-only trial participants; - Free of probable dementia; - At 1 of 14 WHIMS centers | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=434) Placebo (N=452) 2.7 years | Good
WHISCA E+P | Espeland et al, 2010;^120^ Resnick et al, 2006^122^ | - United States; - WHIMS E+P trial participants; - Free of probable dementia; - At 1 of 14 WHIMS centers | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=690) Placebo (N=726) 3 years | Good
Women's International Study of Long Duration Oestrogen After Menopause (WISDOM) | Vickers et al, 2007^123^ | - United Kingdom; - Postmenopausal; - Ages 50–69 years | CEE 0.625 mg/day plus MPA 2.5–5.0 mg/day (N=2,196) Placebo (N=2,189) 1 year | Fair

Abbreviations: CEE = conjugated equine estrogen; E = estrogen only; E+P = estrogen plus progestin; MP = cyclic micronized progesterone; MPA = medroxyprogesterone acetate; N = number of subjects.

Table 4 Baseline Characteristics of Participants in Randomized, Controlled Trials of Hormone Therapy to Prevent Chronic Conditions

Characteristic (Hormone Therapy; Placebo)^a^ | EMS E+P | EPAT | EPHT | ERA | ESPRIT E | Greenspan et al | HERS E+P | KEEPS-Cog | PEPI | STOP-IT
N | 70; 72 | 111; 111 | 404; 373 | 100; 104; 105 | 513; 504 | 187; 186 | 1380; 1383 | 220; 211; 262 | 175; 174; 178; 174 | 121; 122; 123; 123
Age (mean years) | 75; 74.5 | 60.9; 62.1 | 58.5; 59.0 | 66.3; 65.5; 65.6 | 62.3; 62.9 | 71.1; 71.3 | 67; 67 | 52.8; 52.6; 52.5 | - | 72; 71; 72; 74
Nonwhite race (%) | 4.3; 9.7 | 43.0; 38.0 | 49.6; 49.7 | 19.0; 16.0; 19.0 | 3; 3 | - | 12; 10 | 22.3; 22.7; 23.3 | - | -
Previous or current HT (%) | 31.4; 23.6 | - | 9.2; 6.4 | 9.0; 8.0; 10.0 | 12; 10 | - | 1.7; 1.7 | 26.4; 20.4; 18.3 | - | -
Hysterectomy at age <40 years (%) | - | - | - | - | - | - | - | - | - | -
Hysterectomy at ages 40–49 years (%) | - | 33.0; 44.0^b^ | 11.4; 12.9^b^ | 56.0; 62.0; 66.0 | - | - | - | - | - | -
Bilateral oophorectomy (%) | - | 32.0; 19.0 | - | 25.0; 30.0; 36.0 | - | - | - | - | - | -
Never pregnant (%) | - | - | 8.9; 8.1 | - | - | - | - | - | - | -
First pregnancy at age ≥30 years (%) | - | - | - | - | - | - | - | - | - | -
Female relative with breast cancer (%) | - | - | 7.2; 7.0 | - | - | - | - | - | - | -
Current smoker (%) | - | 58.0; 46.0 | 16.3; 13.9 | 18.0; 16.0; 21.0 | 54; 52 | - | 13; 13 | 5.9; 6.6; 6.9 | - | -
Mean BMI (kg/m^2^) | 27; 26.6 | 28.7; 29.0 | 27.0; 26.9 | - | 26.8; 26.7 | 27.5; 27.7 | 29; 29 | 26.1; 26.1; 26.6 | - | -
History of MI (%) | 5.7; 4.2 | - | 0.5; 0.3 | 48.0; 41.0; 55.0 | - | - | 50; 52 | - | - | -
History of stroke (%) | - | - | - | - | - | - | - | - | - | -
History of DVT or PE (%) | - | - | - | - | - | - | - | - | - | -
Mean SBP (mm Hg) | - | 127.8; 128.6 | 137; 137 | 131.0; 136.2; 134.4 | - | - | 135; 135 | 119.1; 117.5; 120.1 | 115; 115; 114; 116 | -
Mean DBP (mm Hg) | - | 78.1; 77.0 | 85.7; 86 | 73.4; 74.1; 74.4 | - | - | 73; 73 | 75.3; 74.1; 75.5 | 72; 72; 73; 71 | -
Treated for hypertension or BP >140/90 mm Hg (%) | - | - | 13.1; 12.1 | 60.0; 73.0; 69.0 | - | - | - | - | - | -
Elevated cholesterol requiring medication (%) | - | - | - | 34.0; 38.0; 37.0 | - | - | - | - | - | -
Prior aspirin use or use at baseline (%) | - | - | - | 67.0; 73.0; 70.0 | - | - | 79; 79 | - | - | -
History of or treatment for diabetes (%) | 7.1; 11.1 | 2.0; 4.0 | - | 25.0; 29.0; 30.0 | 15; 15 | - | 19; 18 | - | - | -
Fracture at age ≥55 years (%) | - | - | - | - | - | - | - | - | - | -

Characteristic (Hormone Therapy; Placebo)^a^ | ULTRA E | WAVE | WHI E+P | WHI E | WHIMSY | WHIMS E+P | WHIMS E | WHISCA E+P | WHISCA E | WISDOM E+P
N | 191; 185 | 210; 213 | 8506; 8102 | 5310; 5429 | 696; 630 | 2229; 2303 | 1464; 1483 | 690; 726 | 434; 452 | 2196; 2189
Age (mean years) | 66.8; 66.7 | 65.0; 69.0 | 63.2; 63.3 | 63.6; 63.6 | 53.0; 52.9 | 63.2; 63.3 | 63.6; 63.6 | 73.69; 73.86 | 74.01; 74.02 | 63.3; 63.3
Nonwhite race (%) | 7.2; 8.1 | 35.0; 32.0 | 16.1; 16.0 | 24.5; 24.9 | 20.0; 19.2 | - | 17.3; 16.4 | 8.4; 7.0 | 14.09; 13.08 | 1; 1.4
Previous or current HT (%) | - | - | 26.1; 25.6 | 47.8; 48.9 | 47.9; 53.2 | 21.8; 22.4 | 45.8; 44.7 | 21.2; 22.6 | 49.54; 46.24 | 55; 54.3
Hysterectomy at age <40 years (%) | - | - | - | 39.8; 39.8 | 56.6; 57.3 | - | - | - | - | -
Hysterectomy at ages 40–49 years (%) | - | 59.0; 58.0^b^ | - | 43.2; 42.2 | 20.9; 16.5 | - | - | - | - | -
Bilateral oophorectomy (%) | - | 36.0; 37.0 | - | 39.5; 42.0 | - | - | - | - | - | -
Never pregnant (%) | - | - | 10.1; 10.3 | 9.3; 8.5 | - | - | - | - | - | -
First pregnancy at age ≥30 years (%) | - | - | 10.6; 9.7 | 4.9; 5.9 | - | - | - | - | - | -
Female relative with breast cancer (%) | - | - | 16.0; 15.3 | 18.0; 17.1 | - | - | - | - | - | 8; 9
Current smoker (%) | 7.7; 6.2 | 19.0; 19.0 | 10.5; 10.5 | 10.3; 10.6 | 13.5; 16.3 | 6.7; 6.9 | 7.3; 8.0 | 6.2; 5.0 | 3.72; 7.59 | 12; 14
Mean BMI (kg/m^2^) | 28.3; 28.0 | 31.1; 30.3 | 28.5; 28.5 | 30.1; 30.1 | - | - | - | 28.5; 28.1 | 29.40; 29.21 | 27.9; 28.0
History of MI (%) | - | 46.0; 40.0 | 1.6; 1.9 | 3.1; 3.2 | - | - | - | - | - | 2; 1
History of stroke (%) | - | - | 0.7; 1.0 | 1.4; 1.7 | - | 1.0; 1.9 | 1.8; 2.1 | 1; 1 | 1.15; 1.77 | 1; 2
History of DVT or PE (%) | - | - | 0.9; 0.8 | 1.6; 1.5 | - | - | - | - | - | -
Mean SBP (mm Hg) | - | 140.0; 138.0 | 127.6; 127.8 | 130.4; 130.2 | - | - | - | - | - | -
Mean DBP (mm Hg) | - | 76.0; 75.0 | 75.6; 75.8 | 76.5; 76.5 | - | - | - | - | - | -
Treated for hypertension or BP >140/90 mm Hg (%) | - | 77.0; 74.0 | 35.7; 36.4 | 48.0; 47.4 | 21.0; 21.0 | - | 47.3; 42.3 | 44.4; 46.0 | 53.69; 51.11 | -
Elevated cholesterol requiring medication (%) | - | - | 12.5; 12.9 | 14.5; 15.9 | - | - | - | - | - | -
Prior aspirin use or use at baseline (%) | - | 84.0; 86.0 | 19.1; 20.1 | 19.4; 19.7 | - | 28.1; 29.6 | 28.0; 30.9 | - | - | -
History of or treatment for diabetes (%) | - | 42.0; 31.0 | 4.4; 4.4 | 7.7; 7.6 | - | 7.0; 6.5 | 11.3; 10.6 | 5.4; 6.2 | 10.14; 10.84 | 3; 4
Fracture at age ≥55 years (%) | - | - | 13.5; 13.6 | 14.0; 13.2 | - | - | - | - | - | -

a Intervention dosages are listed in Table 3 by trial.

b Participants of all ages.

Abbreviations: BMI = body mass index; BP = blood pressure; DBP = diastolic blood pressure; DOPS = Danish Osteoporosis Prevention Trial; DVT = deep vein thrombosis; E = estrogen; E+P = estrogen plus progestin; EMS = Estrogen Memory Study; EPAT = Estrogen in the Prevention of Atherosclerosis; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ERA = Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HERS = Heart and Estrogen/Progestin Replacement Study; HT = hormone therapy; MI = myocardial infarction; P=progestin; PE = pulmonary embolism; PEPI = Postmenopausal Estrogen and Progestin Interventions Trial; SBP = systolic blood pressure; ULTRA = Ultra-Low-Dose Transdermal Estrogen Assessment; WAVE = Women's Angiographic Vitamin and Estrogen Trial; WHI = Women's Health Initiative; WHIMS = Women's Health Initiative Memory Study; WHISCA = Women's Health Initiative Study of Cognitive Aging; WISDOM = Women's International Study of Long Duration Oestrogen After Menopause.

## Summary of Evidence

Eighteen fair- and good-quality trials met eligibility criteria. The WHI reported most of the results and was most applicable to the target population. This summary section provides an overview of results. More detailed findings by chronic condition and regimen follow the summary.

Figures 2 and 3 depict the absolute risk reductions or increases for various outcomes of interest for women who received hormone therapy for 5 to 7 years compared with those who received placebo. Results are depicted as point estimates (fewer or more events per 10,000 women) with 95 percent CIs based on meta-analyses of included trials or, if meta-analyses were not feasible, based on results from the largest and most reliable trial (usually the WHI).

Figure 2 Absolute Risk Reductions or Increases for Women Treated With Estrogen Only^a^ a Followup periods for all outcomes are 7.1 years except: fractures ,7.2 years; dementia, 5.2 years; urinary incontinence, 1 year.

b We calculated relative risks to determine absolute risk reductions and increases presented in this figure because it is unclear whether the proportional hazards assumption is always met in long-term hormone therapy trials. Estimates of relative risks might differ from hazard ratios of trials that are presented in the text.

c Estimates are based on the best available single study.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; PE=pulmonary embolism; RR=relative risk; SOE=strength of evidence.

Figure 2 displays the relative risks of various outcomes, comparing estrogen-only hormone therapy with placebo, and includes a forest plot of events per 10,000 women for each outcome. There was moderate evidence of a relative risk for invasive breast cancer at 7.1 years of 0.79, with a 95% confidence interval of 0.61 to 1.01. The bar is almost entirely green to demonstrate a risk reduction. There was low evidence of a relative risk for colorectal cancer at 7.1 years of 1.15, with a 95% confidence interval of 0.81 to 1.63. The bar is green and red to demonstrate a mixed effect. There was low evidence of a relative risk for lung cancer at 7.1 years of 1.04, with a 95% confidence interval of 0.73 to 1.48. The bar is green and red to demonstrate a mixed effect. There was high evidence of a relative risk for coronary heart disease at 7.1 years of 0.95, with a 95% confidence interval of 0.79 to 1.14. The bar is green and red to demonstrate a mixed effect. There was low evidence of a relative risk for probable dementia at 5.2 years of 1.49, with a 95% confidence interval of 0.84 to 2.66. The bar is mostly red to demonstrate a risk increase. There was moderate evidence of a relative risk for diabetes at 7.1 years of 0.87, with a 95% confidence interval of 0.77 to 0.98. The bar is green to demonstrate a risk reduction. There was high evidence of a relative risk for fractures at 7.2 years of 0.73, with a 95% confidence interval of 0.65 to 0.80. The bar is green to demonstrate a risk reduction. There was moderate evidence of a relative risk for gallbladder disease at 7.1 years of 1.63, with a 95% confidence interval of 1.33 to 2.00. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for stroke at 7.1 years of 1.33, with a 95% confidence interval of 1.06 to 1.67. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for urinary incontinence at 1 year of 1.53, with a 95% confidence interval of 1.37 to 1.71. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for venous thromboembolism at 7.1 years of 1.43, with a 95% confidence interval of 1.11 to 1.85. The bar is red to demonstrate a risk increase. There was high evidence of a relative risk for all-cause mortality at 7.1 years of 1.01, with a 95% confidence interval of 0.88 to 1.17. The bar is green and red to demonstrate a mixed effect.

Figure 3 Absolute Risk Reductions or Increases for Women Treated With Estrogen Plus Progestin^a^ a Followup periods for all outcomes are 5.6 years except: fractures, 5.0 years; coronary heart disease, 5.1 years; dementia, 4 years; urinary incontinence, 1 year.

b We calculated relative risks to determine absolute risk reductions and increases presented in this figure because it is unclear whether the proportional hazards assumption is always met in long-term hormone therapy trials. Estimates of relative risks might differ from hazard ratios of trials that are presented in the text.

c Estimates are based on the best available single study.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; PE=pulmonary embolism; RR=relative risk; SOE=strength of evidence.

Figure 3 displays the relative risks of various outcomes, comparing estrogen plus progestin hormone therapy with placebo, and includes a forest plot of events per 10,000 women for each outcome. There was high evidence of a relative risk for invasive breast cancer at 5.6 years of 1.27, with a 95% confidence interval of 1.03 to 1.56. The bar is red to demonstrate a risk increase. There was low evidence of a relative risk for cervical cancer at 5.6 years of 1.52, with a 95% confidence interval of 0.50 to 4.66. The bar is green and red to demonstrate a mixed effect. There was moderate evidence of a relative risk for colorectal cancer at 5.6 years of 0.64, with a 95% confidence interval of 0.44 to 0.91. The bar is green to demonstrate a risk reduction. There was low evidence of a relative risk for endometrial cancer at 5.6 years of 0.86, with a 95% confidence interval of 0.51 to 1.44. The bar is green and red to demonstrate a mixed effect. There was moderate evidence of a relative risk for lung cancer at 5.6 years of 1.06, with a 95% confidence interval of 0.77 to 1.46. The bar is green and red to demonstrate a mixed effect. There was low evidence of a relative risk for ovarian cancer at 5.6 years of 1.43, with a 95% confidence interval of 0.76 to 2.69. The bar is green and red to demonstrate a mixed effect. There was high evidence of a relative risk for coronary heart disease at 5.1 years of 1.23, with a 95% confidence interval of 1.00 to 1.52. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for probable dementia at 4 years of 1.97, with a 95% confidence interval of 1.16 to 3.33. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for diabetes at 5.6 years of 0.84, with a 95% confidence interval of 0.72 to 0.97. The bar is green to demonstrate a risk reduction. There was high evidence of a relative risk for fractures at 5.0 years of 0.80, with a 95% confidence interval of 0.68 to 0.94. The bar is green to demonstrate a risk reduction. There was moderate evidence of a relative risk for gallbladder disease at 5.6 years of 1.59, with a 95% confidence interval of 1.29 to 1.97. The bar is red to demonstrate a risk increase. There was high evidence of a relative risk for stroke at 5.6 years of 1.39, with a 95% confidence interval of 1.09 to 1.77. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for urinary incontinence at 1 year of 1.39, with a 95% confidence interval of 1.27 to 1.52. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for venous thromboembolism at 5.6 years of 1.95, with a 95% confidence interval of 1.54 to 2.47. The bar is red to demonstrate a risk increase. There was moderate evidence of a relative risk for all-cause mortality at 5.6 years of 1.01, with a 95% confidence interval of 0.88 to 1.17. The bar is green and red to demonstrate a mixed effect.

Figures 2 and 3 also present the relative risk (RR) and the SOE for each outcome. We calculated RRs based primarily on the latest publication summarizing results of the WHI trials.^102^ Therefore, effect estimates might differ slightly from hazard ratios (HRs) reported in WHI publications. We chose RR because it is more intuitive to interpret than HR.

For several outcomes of interest we did not find any statistically significant differences between women using hormone therapy and women taking placebo. For estrogen-only therapy, outcomes that were not statistically significant include probable dementia, breast cancer, colorectal cancer, lung cancer, coronary heart disease, quality of life, and all-cause mortality. For estrogen plus progestin therapy, we did not find statistically significant differences for cervical cancer, endometrial cancer, lung cancer, ovarian cancer, coronary heart disease, quality of life, and all-cause mortality.

Some of these nonstatistically significant outcomes, however, had wide CIs that encompassed both clinically relevant benefits and harms leading to inconclusive results. Specifically for cervical cancer, endometrial cancer, lung cancer, and ovarian cancer, event rates in studies were too low to draw firm conclusions about differences in benefits and harms.

### KQ 1 What Are the Benefits of Menopausal Hormone Therapy When Used for Primary Prevention of Chronic Conditions?

Overall, trials reported several statistically significant benefits for women using hormone therapy. For women using estrogen only, risk of fractures (382 fewer cases per 10,000 women over 7.2 years [95% CI, 283 to 495]) and diabetes (137 fewer cases per 10,000 women over 7.1 years [95% CI, 21 to 248]) were statistically significantly reduced compared with women taking placebo (Figure 2). The risk of breast cancer was numerically reduced but did not reach statistical significance (HR, 0.79 [95% CI, 0.61 to 1.02]).^102^ Women using estrogen plus progestin therapy experienced statistically significantly reduced risk of colorectal cancer (33 fewer cases per 10,000 women over 5.6 years [95% CI, 8 to 52]), fractures (222 fewer cases per 10,000 women over 5.0 years [95% CI, 67 to 354]), and diabetes (77 fewer cases per 10,000 women over 5.6 years [95% CI, 21 to 206]) compared with women in the placebo groups (Figure 3).

Long-term followup studies of the WHI showed that most beneficial effects dissipated after stopping hormone therapy. An exception was the risk of invasive breast cancer in women who received estrogen-only therapy. Specifically, 3.9 years after women stopped hormone therapy treatment, the risk remained numerically (but not statistically) lower for women who had been treated with estrogen only during the trial phase (HR, 0.75 [95% CI, 0.51 to 1.09]).^112^ We did not find any evidence on functional capacity.

### KQ 2 What Are the Harms of Menopausal Hormone Therapy When Used for Primary Prevention of Chronic Conditions?

Results of trials and our meta-analyses indicate several important harms for hormone therapy. They differ by treatment formulation (i.e., estrogen only or estrogen plus progestin).

Women receiving estrogen-only therapy had statistically significantly increased risk of gallbladder disease (213 more cases per 10,000 women over 7.1 years [95% CI, 236 to 538]), stroke (79 more cases per 10,000 women over 7.1 years [95% CI, 14 to 160]), urinary incontinence (1,261 more cases per 10,000 women over 1 year [95% CI, 880 to 1,689]), and venous thromboembolism (78 more cases per 10,000 women over 7.1 years [95% CI, 20 to 153]; [Figure 2]). Likewise, for women receiving estrogen plus progestin therapy, risk of invasive breast cancer (52 more cases per 10,000 women over 5.6 years [95% CI, 6 to 107]), probable dementia (88 more cases per 10,000 women over 4 years [95% CI, 15 to 213]), gallbladder disease (116 more cases per 10,000 women over 5.6 years [95% CI, 167 to 366]), stroke (53 more cases per 10,000 women over 5.6 years [95% CI, 12 to 104]), urinary incontinence (876 more cases per 10,000 women over 1 year [95% CI, 606 to 1,168]), and venous thromboembolism (120 more cases per 10,000 women over 5.6 years [95% CI, 68 to 185]) were statistically significantly increased compared with women taking placebo (Figure 3). We did not find any evidence on other harms or on the effect of harms on functional capacity.

### KQ 3 Do the Benefits and Harms of Menopausal Hormone Therapy Differ by Subgroup or by Timing of Intervention?

Subgroups specified for this KQ included the following: race/ethnicity; women with premature menopause; women with surgical menopause; age; duration of use; type, dose, and mode of delivery of hormone therapy; and presence of comorbid conditions. Trials did not report results for most of these subgroups. Subgroup analyses of trial results based on these characteristics were restricted to age, race/ethnicity, and a limited number of coexisting conditions or risk factors.

Some subgroup analyses indicate that age may modify the effects of hormone therapy. Analyses that compared younger (ages 50 to 59 years) with older (ages 70 to 79 years) women using estrogen-only therapy yielded a statistically significant trend for increasing risk by age of myocardial infarction (HR, 0.55 [95% CI, 0.31 to 1.00] vs. HR, 1.24 [95% CI, 0.88 to 1.75]; p=0.02 for trend),^102^ colorectal cancer (HR, 0.71 [95% CI, 0.30 to 1.67] vs. HR, 2.24 [95% CI, 1.16 to 4.30]; p=0.02 for trend),^102^ and all-cause mortality (HR, 0.70 [95% CI, 0.46 to 1.09] vs. HR, 1.21 [95% CI, 0.95 to 1.56]; p=0.04 for trend).^102^ Post-hoc subgroup analyses regarding the effects of time since menopause were inconclusive.

Findings also indicated an increased risk of breast cancer in women taking estrogen plus progestin who initiated therapy within 5 years of menopause (p=0.03). Older women had an increased risk of colorectal cancer attributable to estrogen-only hormone therapy. Some of these subgroup differences, however, are based on relatively few events and need to be interpreted cautiously. We did not find any evidence on functional capacity.

## Detailed Presentation of the Evidence

In the sections below, we present benefits and harms first for estrogen-only hormone therapy and then for estrogen plus progestin by outcome of interest. Although data from the four trials that did not stratify results by treatment regimen are not analyzed in this report, they are included in Appendix G. We specifically comment on the various types of cancer (breaking out the gynecologic cancers by specific type, such as cervical or ovarian) and then turn to the various other condition-specific outcomes. Evidence about all-cause mortality is presented last. We also address differences of effects by subgroups and by the timing of the intervention, when such data were available. In one instance (the effect of timing of the intervention on cardiovascular outcomes), we present information from two trials that were not eligible for our report because they focused on intermediate outcomes. However, they are the only available evidence directly addressing this question.

Table 3 describes the main characteristics of eligible trials, including the various types and levels of estrogen or estrogen plus progestin used. Appendix G presents results of individual trials for each outcome in more detail.

Because the two WHI trials were the largest studies, we summarize results on outcomes of interest at the end of the intervention phase of the WHI trials according to treatment (estrogen only or estrogen plus progestin) in Table 5. Tables 6–8 are summary tables presenting the available evidence, effect estimates, and SOE ratings for each outcome by treatment. Effect estimates are based on meta-analyses of included trials or, if meta-analyses were not feasible, based on results from the largest and most reliable trial (usually the WHI).

Table 5 Results of WHI at the End of the Intervention Phase, by Category and Subcategory of Outcome

Outcome^a^,^b^ | Estrogen Only^c^ vs. Placebo | Estrogen Plus Progestin^c^ vs. Placebo
Outcome^a^,^b^ | Hazard Ratio (95% CI) | Hazard Ratio (95% CI)
Cancer
Breast (invasive) | 0.79 (0.61 to 1.02)^102, 112^ | 1.24 (1.01 to 1.53)^102^
Cervical | Not reported | 1.44 (0.47 to 4.42)^81^
Colorectal | 1.15 (0.81 to 1.64)^102^ | 0.62 (0.43 to 0.89)^102^
Endometrial | Not reported | 0.83 (0.49 to 1.40)^102^
Lung | 1.05 (0.74 to 1.49)^102^ | 1.05 (0.76 to 1.45)^102^
Ovarian | Not reported | 1.41 (0.75 to 2.66)^102^
Cardiovascular events (all) | 1.11 (1.01 to 1.22)^102^ | 1.13 (1.02 to 1.25)^102^
Coronary heart disease | 0.94 (0.78 to 1.14)^102^ | 1.18 (0.95 to 1.45)^102^
Cognitive functioning and dementia
Mild cognitive impairment | 1.34 (0.95 to 1.89)^102^ | 1.07 (0.74 to 1.55)^102^
Probable dementia | 1.49 (0.83 to 2.66)^102, 117^ | 2.05 (1.21 to 3.48)^118^
Diabetes
Self-reported new diagnosis requiring treatment with drugs | 0.86 (0.76 to 0.98)^102^ | 0.81 (0.70 to 0.94)^81, 102^
Fractures
Hip | 0.67 (0.46 to 0.96)^102^ | 0.67 (0.47 to 0.95)^102^
Vertebral | 0.64 (0.44 to 0.93)^102^ | 0.68 (0.48 to 0.96)^102^
Total fractures | 0.72 (0.64 to 0.80)^102^ | 0.76 (0.69 to 0.83)^102^
Gallbladder events | 1.67 (1.35 to 2.06)^88^ | 1.59 (1.28 to 1.97)^88^
Gallbladder disease | 1.79 (1.44 to 2.22)^88^ | 1.61 (1.30 to 2.00)^88^
Cholecystectomy | 1.93 (1.52 to 2.44)^88^ | 1.67 (1.32 to 2.11)^88^
Urinary incontinence (stress, urge, or mixed)
Overall urinary incontinence | 1.53 (1.37 to 1.71) | 1.39 (1.27 to 1.52)
Stroke | 1.35 (1.07 to 1.70)^102^ | 1.37 (1.07 to 1.76)^102^
Thromboembolic events
Deep vein thrombosis | 1.48 (1.06 to 2.07)^102^ | 1.87 (1.37 to 2.54)^102^
Pulmonary embolism | 1.35 (0.89 to 2.05)^102^ | 1.98 (1.36 to 2.87)^102^
All-cause mortality | 1.04 (0.89 to 1.33)^112^ | 0.97 (0.81 to 1.16)^92^

a Assumes a constant rate of events across the study period, although rates varied depending on outcome (e.g., thromboembolic events occurred early during therapy, cancer cases later).

b Hazard ratios not reported for quality of life.

c Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI = confidence interval; WHI = Women's Health Initiative.

Table 6 Summary of Evidence: Estrogen-Only Trials

Key Question | Population, Intervention | No. of Studies; No. of Observations | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Overall Quality of Studies | Body of Evidence Limitations | EPC Assessment of Strength of Evidence | Applicability
KQ 1/KQ 2 | Menopausal women post-hysterectomy, Estrogen-only therapy | 5 RCTs;^24, 60, 62-64, 98, 102, 105, 112^ 239 events in 10,739 women contribute to effect estimate (based on 1 RCT^102^) | Invasive breast cancer (followup 7.2 years): Nonsignificant lower risk with HT (HR, 0.79 [95% CI, 0.61 to 1.02]) | Consistent/imprecise | Undetected | Fair | 3 studies followed participants for a relatively short duration (2–3 years) | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women without intact uterus Estrogen-only therapy | 1 RCT;^64^ 1 event in 1,017 women contribute to effect estimate | Cervical Cancer (followup 12.6 years): Relative risk not estimated due to low number of events | NA/imprecise | Suspected | Fair | 1 small study followed participants to evaluate a rare cancer outcome over a period of time that included the intervention and an open-label observational period | Insufficient | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen-only therapy | 1 RCT;^102, 113^ 123 events in 10,739 women contribute to effect estimate | Colorectal Cancer (followup 7.2 years): No significant risk increase/reduction with HT (HR, 1.15 [95% CI, 0.81 to 1.64]) | NA/imprecise | Undetected | Fair | None | Low | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen-only therapy | 1 RCT;^102, 108^ 123 events in 10,739 women contribute to effect estimate | Lung Cancer (followup 7.2 years): No significant risk increase/reduction with HT (HR, 1.05 [95% CI, 0.74 to 1.49]) | NA/imprecise | Undetected | Fair | None | Low | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women without intact uterus Estrogen-only therapy | 1 RCT;^63, 64^ 5 events in 1,017 women contribute to effect estimate | Ovarian Cancer (followup 12.6 years): no significant risk increase/reduction with HT (p=0.37); relative risk not reported | NA/imprecise | Suspected | Fair | 1 small study followed participants to evaluate a rare cancer outcome over a period of time that included the intervention and an open-label observational period | Insufficient | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 4 RCTs;^60, 62, 74, 111^ 422 events in 11,310 women contribute to effect estimate (based on 3 RCTs^60, 74, 111^) | Coronary heart disease (followup 6.8 years in meta-analysis): No significant risk reduction/increase with HT (RR, 0.95 [95% CI, 0.79 to 1.14]) | Consistent/precise | Undetected | Fair | None | High | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 1 RCT;^115, 117, 127^ 47 events in 2,947 women contribute to effect estimate | Probable dementia (followup 5.2 years): No significant risk increase or reduction with HT (HR, 1.49 [95% CI, 0.83 to 2.66]) | NA/imprecise | Undetected | Fair | None | Low | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 1 RCT;^102, 106^ 976 events in 9,917 women contribute to effect estimate | Diabetes (followup 7.1 years): Risk reduction with HT (HR, 0.86 [95% CI, 0.76 to 0.98]) | NA/reasonably precise | Undetected | Fair | Diabetes is self-reported | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 2 RCTs;^62, 81, 102, 112^ 1,227 events in 10,739 women contribute to effect estimate (based on 1 RCT^102^) | Fractures (followup 6.8 years): Significant risk decrease with HT (HR, 0.70 [95% CI, 0.63 to 0.79]) | Consistent/precise | Undetected | Fair | None | High | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 2 RCTs;^74, 88^ 371 events in 8,376 women contribute to effect estimate (based on 1 RCT^88^) | Gallbladder events (followup 7.2 years): Significant risk increase with HT (HR, 1.67 [95% CI, 1.35 to 2.06]) | Consistent/reasonably precise | Undetected | Fair | Gallbladder disease is self-reported | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 3 RCTs;^60, 62, 112^ 298 events in 10,739 women contribute to effect estimate (based on 1 RCT^102^) | Stroke (followup 7.2 years): Significant increase with HT (HR, 1.35 [95% CI, 1.07 to 1.70]) | Consistent/reasonably precise | Undetected | Fair | 3 studies followed participants for a relatively short duration (2–3 years) | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 2 RCTs;^78, 94^ 925 events in 3,073 women contribute to effect size (based on 1 RCT^94^) | Urinary incontinence (followup 1 year): Significant risk increase with HT (RR, 1.53 [95% CI, 1.37 to 1.71]) | Consistent/precise | Undetected | Fair | Urinary incontinence is self-reported | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 2 RCTs;^60, 112^ 144 (DVT) and 91 (PE) events in 10,739 women contribute to effect estimates (based on 1 RCT^102^) | Venous thromboembolism (followup 7.1 years): Nonsignificant increased risk of PE (HR, 1.35 [95% CI, 0.89 to 2.05]) and significant increased risk of DVT (HR, 1.48 [95% CI, 1.06 to 2.07]) in the WHI | Consistent/reasonably precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 1 RCT^102^ | Quality of life (followup 7.1 years): Similar scores on most items of the RAND-36 | NA/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 3 RCTs;^62, 63, 112^ 682 events in 11,961 women contribute to effect estimate | All-cause mortality (followup 6.8 years in meta-analysis): No significant risk increase/reduction with HT (RR, 1.01 [95% CI, 0.88 to 1.17]) | Consistent/precise | Undetected | Fair | None | High | Generally healthy post-menopausal women age ≥50 years

Abbreviations: CI = confidence interval; DVT = deep vein thrombosis; EPC = evidence-based practice; HR = hazard ratio; HT = hormonal therapy; KQ = Key Question; NA = not applicable; No. = number; p=p-value; PE = pulmonary embolism; RCT = randomized, controlled trial; RR = relative risk; WHI = Women's Health Initiative.

Table 7 Summary of Evidence: Estrogen Plus Progestin Trials

Key Question | Population, Intervention | No. of Studies; No. of Observations | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Overall Quality of Studies | Body of Evidence Limitations | EPC Assessment of Strength of Evidence | Applicability
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 5 RCTs;^23, 61, 68, 74, 84, 85, 90, 92, 98, 102, 123^ 420 events in 19,371 women contribute to effect estimates (based on 2 RCTs^68, 102^) | Invasive breast cancer (followup 4.1–5.6 years): Significant risk increase with HT (HR, 1.24 [95% CI, 1.01 to 1.53]) in WHI and nonsignificant increase with HT in HERS I (HR, 1.38 [95% CI, 0.82 to 2.31]) | Consistent/reasonably precise | Undetected | Fair | None | High | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT;^81^ 13 events in 16,608 women contribute to effect estimate | Cervical cancer (followup 5.6 years): No significant risk increase/reduction with HT (HR, 1.44 [95% CI, 0.47 to 4.42]) | NA, single study/imprecise | Undetected | Fair | 1 study followed participants for a relatively short duration (5.6 years) to evaluate a rare cancer outcome | Low | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with and without intact uterus Estrogen plus progestin therapy | 4 RCTs;^23, 59, 68, 87, 92, 98, 102, 123^ 152 events in 19,371 women contribute to effect estimates (based on 2 RCTs^68, 102^) | Colorectal Cancer (followup 4.1 to 5.6 years): Significant risk reduction with HT (HR, 0.62 [95% CI, 0.43 to 0.89]) in the WHI and nonsignificant risk reduction with HT (HR, 0.69 [95% CI, 0.32 to 1.49]) in HERS | Reasonably consistent/reasonably precise | Undetected | Fair | Studies followed participants for a relatively short duration (up to 5.6 years) to evaluate a cancer outcome | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 4 RCTs;^23, 62, 68, 74, 81, 92, 98, 102, 108^ 64 events in 19,371 women contribute to effect estimates (based on 2 RCTs^23, 68, 81, 92, 98, 102, 108^) | Endometrial Cancer (followup 4.1 to 5.6 years): No significant risk increase/reduction with HT (HR, 0.83 [95% CI, 0.49 to 1.40]) in the WHI and (HR, 0.39 [95% CI, 0.08 to 2.02]) in HERS | Reasonably consistent/reasonably precise | Undetected | Fair | Studies followed participants for a relatively short duration (up to 5.6 years) to evaluate a rare cancer outcome | Low | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with and without intact uterus Estrogen plus progestin therapy | 3 RCTs;^59, 68, 86, 102^ 191 events in 19,371 women contribute to effect estimates (based on 2 RCTs^68, 86, 102^) | Lung Cancer (followup 4.1 to 5.6 years): No significant risk increase/reduction with HT (HR, 1.05 [95% CI, 0.76 to 1.45]) in the WHI and (HR, 1.28 [95% CI, 0.70 to 2.33]) in HERS | Reasonably consistent/reasonably precise | Undetected | Fair | Studies followed participants for a relatively short duration (up to 5.6 years) to evaluate a cancer outcome | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT;^81, 102^ 40 events in 16,608 women contribute to effect estimate | Ovarian Cancer (followup 5.6 years): No significant risk increase/reduction with HT (HR, 1.41 [95% CI, 0.75 to 2.66]) | NA/imprecise | Undetected | Fair | Study followed participants for a relatively short duration (5.6 years) to evaluate a rare cancer outcome | Low | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 6 RCTs;^23, 59, 61, 62, 74, 123^ 341 events in 18,081 women contribute to effect estimate (based on 3 RCTs^23, 59, 61, 74^) | Coronary heart disease (followup 5.2 years in meta-analysis): Risk increase with HT (RR, 1.23 [95% CI, 1.00 to 1.52]) | Consistent/precise | Undetected | Fair | None | High | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT;^118^ 61 events in 4,532 women contribute to effect estimate | Probable dementia: (followup 4 years): Significant risk increase with HT (HR, 2.05 [95% CI, 1.21 to 3.48]) | NA/imprecise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 2 RCTs;^70, 97, 102 70, 102^ 701 events in 15,874 women contribute to effect estimate (based on 1 RCT^102^) | Diabetes (followup 5.6 years): Significant risk reduction with HT (HR, 0.81 [95% CI, 0.70 to 0.94]) | Consistent/precise | Undetected | Fair | Diabetes is self-reported | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 5 RCTs;^23, 59, 61, 62, 68, 83, 92, 102^ 1,995 events in 20,499 women contribute to effect estimate | Fractures (followup 2 to 5.2 years): Significant risk reduction with HT (RR, 0.80 [95% CI, 0.68 to 0.94]) | Consistent/precise | Undetected | Fair | None | High | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 2 RCTs;^74, 88^ 363 events in 14,203 women contribute to effect estimate (based on 1 RCT^88^) | Gallbladder events (followup 5.6 years): Significant risk increase with HT (HR, 1.59 [95% CI, 1.28 to 1.97]) | Consistent/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 3 RCTs;^59, 61, 101, 102^ 330 events in 17,385 women contribute to effect estimates (based on 2 RCTs^61, 101, 102^) | Stroke (followup 3.4 to 5.6 years): Significant increase with HT in WHI (HR, 1.37 [95% CI, 1.07 to 1.76]) Risk of any cerebrovascular event: Significant increase with HT in EPHT (HR, 1.06 [95% CI, 0.07 to 17.2]) | Consistent/reasonably precise | Undetected | Fair | Outcome measures heterogeneous; 1 trial reported on stroke incidence and 1 reported on composite risk of various cerebrovascular events (stroke, TIA) | High | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 2 RCTs;^71, 94^ 1,397 events in 5,182 women contribute to effect size (based on 1 RCT^94^) | Urinary incontinence (followup 1 year): Significant risk increase with HT (RR, 1.39 [95% CI, 1.27 to 1.52]) | Consistent/precise | Undetected | Fair | Urinary incontinence is self-reported | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 4 RCTs;^59, 61, 62, 89^ 182 (DVT) and 124 (PE) events in 16,602 women contribute to effect estimates (based on 1 RCT^102^) | Venous thromboembolism (followup 5.6 years): Significant increased risk of PE (HR, 1.98 [95% CI, 1.36 to 2.87]) and DVT (HR, 1.87 [95% CI, 1.37 to 2.54]) with HT in WHI at followup of 5.6 years | Consistent/reasonably precise | Undetected | Fair | 3 studies followed participants for a relatively short duration (2–3 years) | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women post-hysterectomy Estrogen-only therapy | 1 RCT^102^ | Quality of life (followup 5.2 years): Similar scores on most items of the RAND-36 | NA/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 1/KQ 2 | Menopausal women with intact uterus Estrogen plus progestin therapy | 3 RCTs;^62, 68, 92^ 752 events in 19,580 women contribute to effect estimate | All-cause mortality (followup 5.2 years in meta-analysis): No significant risk increase/reduction with HT (RR, 1.01 [95% CI, 0.88 to 1.17]) | Consistent/reasonably precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years

Abbreviations: CI = confidence interval; DVT = deep vein thrombosis; EPC = evidence-based practice; EPHT = Estonian Postmenopausal Hormone Therapy Trial; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; HT = hormone therapy; KQ = key question; NA = not applicable; No. = number; p = p-value; PE = pulmonary embolism; RCT = randomized, controlled trial; RR = relative risk; TIA = transient ischemic attack; WHI = Women's Health Initiative.

Table 8 Summary of Evidence: Subgroups

Key Question | Population, Intervention | No. of Studies; No. of Observations | Summary of Findings by Outcome | Consistency^a^/Precision | Reporting Bias | Overall Quality of Studies | Body of Evidence Limitations^b^ | EPC Assessment of Strength of Evidence | Applicability
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102, 104^ 600 events in 27,347 women | Invasive Breast Cancer: Age: Similar treatment effects in subgroups based on age | NA/reasonably precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102, 104^ 600 events in 27,347 women | Duration: Risk of invasive breast cancer increased for women who initiated estrogen plus progestin with increasing time since randomization (p=0.008 for trend) | NA/reasonably precise | Undetected | Fair | Post-hoc analysis | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102, 104^ 600 events in 27,347 women | Timing: Women who initiated estrogen plus progestin closer to menopause had a higher risk of invasive breast cancer than those who initiated later (p=0.03 for interaction) | NA/reasonably precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102, 104^ 600 events in 27,347 women | No difference in timing or duration of HT use for women taking estrogen-only therapy | NA/reasonably precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | No evidence | Cervical Cancer: No evidence | NA | Undetected | NA | N | Insufficient | NA
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | No evidence | Timing: No evidence | NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^87, 98, 102, 113^ 248 events in 27,347 women | Colorectal Cancer: Age: For estrogen-only, there was a significant trend toward lower risk among younger vs. older women, relative to placebo (p=0.02 for interaction); similar risks for estrogen plus progestin | NA/imprecise | Undetected | Fair | Estimates based on 2 studies with few events; lack of power to detect subgroup effects | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^87, 98, 102, 113^ 248 events in 27,347 women | Race/ethnicity or family history of colorectal cancer: Similar treatment effects in subgroups for both treatment regimens | NA/imprecise | Undetected | Fair | Estimates based on 2 studies with few events; lack of power to detect subgroup effects | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^87, 98, 102, 113^ 248 events in 27,347 women | Timing: Similar treatment effects in subgroups based on timing of intervention since menopause for both treatment regimens | NA/imprecise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT^102^ 57 events in 16,608 women | Endometrial Cancer: Similar treatment effects in subgroups based on age in the estrogen plus progestin and placebo groups | NA/imprecise | Undetected | Fair | Estimates based on a single study with few events; lack of power to detect subgroup effects | Insufficient | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT^102^ 57 events in 16,608 women | Timing: No evidence | NA/NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 271 events in 27,347 women | Lung Cancer: Similar treatment effects in subgroups based on age for both treatment regimens | NA/imprecise | Undetected | Fair | Estimates based on 2 studies with few events; lack of power to detect subgroup effects | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 271 events in 27,347 women | Timing: No evidence | NA/NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT^102^ 40 events in 16,608 women | Ovarian Cancer: No subgroup effects with respect to age for estrogen plus progestin | NA/imprecise | Undetected | Fair | Very few events | Insufficient | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | 1 RCT^102^ 40 events in 16,608 women | Timing: No evidence | NA/NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^35, 96, 111^ 711 event in >27,000 women | Coronary Heart Disease: Risk attributable to HT increased numerically with age for estrogen plus progestin, test of interaction was not statistically significant; there was a significant trend toward lower risk among younger vs. older women taking estrogen only for myocardial infarction, relative to placebo | NA/reasonably precise | Undetected | Fair | None | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^35, 96, 111^ 711 event in >27,000 women | Similar treatment effects in subgroups based on race/ethnicity | Consistent/reasonably precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^35, 96, 111^ 711 event in >27,000 women | Similar treatment effects in subgroups based on: hypertension, diabetes, high cholesterol requiring medication, coronary risk factors, years since bilateral oophorectomy, years since hysterectomy, or body mass index for both treatment regimens | Consistent/reasonably precise | Undetected | Fair | Post-hoc analysis | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^35, 96, 111^ 711 event in >27,000 women | Timing: Risk attributable to HT increased with time since menopause; test of interaction was not statistically significant (p=0.40) | Consistent/reasonably precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen only or estrogen plus progestin therapy | 1 RCT^116-118^ 108 events in 7,479 women | Probable Dementia: Similar treatment effects in subgroups based on race, history of diabetes, stroke, hypertension, or cardiovascular disease for estrogen only | NA/imprecise | Undetected | Fair | Estimates based on a single study | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen only or estrogen plus progestin therapy | 1 RCT^116-118^ 108 events in 7,479 women | Timing: Similar treatment effects in subgroups based on timing of intervention since menopause for estrogen plus progestin | NA/imprecise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 1 RCT^97, 102, 106^ 1,677 events in 25,791 women | Diabetes: Similar treatment effects in subgroups based on age, race/ethnicity for both treatment regimens | NA/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 1 RCT^97, 102, 106^ 1,677 events in 25,791 women | Similar treatment effects in subgroups based on hypertension, metabolic syndrome for estrogen only | NA/precise | Undetected | Fair | Post-hoc analysis | Low | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 1 RCT^97, 102, 106^ 1,677 events in 25,791 women | Timing: No evidence | NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women with intact uterus Estrogen only or estrogen plus progestin therapy | 1 RCT^81^ 1,227 events in 10,739 women Timing: 1 RCT^61^ 40 events in 777 women^61^ | Fractures: No significant difference by age for estrogen only | NA | Undetected | NA | None | Moderate | NA
KQ 3 | Menopausal women with intact uterus Estrogen only or estrogen plus progestin therapy | 1 RCT^81^ 1,227 events in 10,739 women Timing: 1 RCT^61^ 40 events in 777 women^61^ | Timing: Similar treatment effects based on timing of intervention since menopause for estrogen plus progestin | NA/precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^88^ 734 events in 22,579 women | Gallbladder disease: Similar treatment effects in subgroups based on age for both treatment regimens | NA/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^88^ 734 events in 22,579 women | Timing: No evidence | NA | NA | NA | NA | Insufficient | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 567 events in 27,347 women | Stroke: Similar treatment effects in subgroups based on age, race/ethnicity | NA/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 567 events in 27,347 women | Similar treatment effects in subgroups based on hypertension for both treatment regimens | NA/precise | Undetected | Fair | Post-hoc analysis | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 567 events in 27,347 women | Timing: Similar treatment effects in subgroups based on timing of intervention since menopause for both treatment regimens | NA/precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | No evidence | Urinary incontinence: No evidence | NA | Undetected | NA | NA | Insufficient
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | No evidence | Timing: No evidence | NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 546 events in 27,347 women | Venous Thromboembolism: Similar treatment effects in subgroups based on age and race/ethnicity for both treatment regimens | NA/precise | Undetected | Fair | None | Moderate | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 546 events in 27,347 women | Similar treatment effects in subgroups based on history of cardiovascular disease for estrogen only | NA/precise | Undetected | Fair | Post-hoc analysis | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^102^ 546 events in 27,347 women | Timing: Similar treatment effects in subgroups based on timing of intervention since menopause for both treatment regimens | NA/precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women with intact uterus Estrogen plus progestin therapy | No evidence | Quality of life: No evidence | NA | Undetected | NA | NA | Insufficient | NA
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^98, 112^ 1086 events in 27,347 women | All-cause mortality: There was a significant trend toward lower risk among younger vs. older women using estrogen only, relative to placebo (p=0.04 for interaction); in women using estrogen plus progestin difference did not reach statistical significance. | NA/precise | Undetected | Fair | None | Low | Generally healthy post-menopausal women age ≥50 years
KQ 3 | Menopausal women Estrogen only or estrogen plus progestin therapy | 2 RCTs^98, 112^ 1086 events in 27,347 women | Timing: Similar treatment effects in subgroups based on timing of intervention since menopause for both treatment regimens | NA/precise | Undetected | Fair | Post-hoc analysis; for women with hysterectomy without oophorectomy, exact timing of menopause is often difficult to determine | Low | Generally healthy post-menopausal women age ≥50 years

a Ratings of consistency pertain to effects of the same treatment regimen (i.e., either estrogen only or combination therapy). In situations where only a single study is available for each regimen, consistency was rated as not applicable (NA).

b We downgraded all subgroup analyses for multiplicity; in addition, we further downgraded post-hoc subgroup analyses.

Abbreviations: EPC = Evidence-based Practice Center; HT = hormone therapy; KQ = Key Question; NA = not applicable; No. = number; RCT = randomized, controlled trial.

### Estrogen Only: Cancer

#### Breast Cancer

##### Benefits and Harms of Hormone Therapy

Five RCTs (WHI [N=10,739],^24, 98, 102, 104, 105, 112^ ESPRIT [N=1,017],^63, 64^ EPAT [N=222],^60^ ERA [N=205],^62^ and PEPI [N=349]^74^) comparing estrogen only with placebo reported on breast cancer incidence (Appendix G Table 1). We did not pool trial results, primarily because of heterogeneity in study duration and outcome measures. Only two trials followed women for more than 3 years (WHI and ESPRIT), and only the WHI reported on risk of invasive breast cancer (vs. any breast cancer).

In the WHI, women assigned to estrogen alone had a nonsignificant decrease in invasive breast cancer risk compared with placebo during the 7.2-year (median) intervention phase (2.0% vs. 2.5%; HR, 0.79 [95% CI, 0.61 to 1.02]).^102, 112^ The risk remained numerically lower during the 6.6-year (median) postintervention phase after the trial had been stopped.^102^ The difference between groups was statistically significant during cumulative (trial and postintervention phase; median, 13 years) followup (HR, 0.79 [95% CI, 0.65 to 0.97]).^102^

In the ESPRIT trial, postmenopausal women ages 50 to 69 years who survived a first myocardial infarction were randomized to estrogen only or placebo. The risk of breast cancer in women randomized to estrogen only and placebo during the 2-year intervention period was similar (0.8% vs. 0.8%; RR, 0.98 [95% CI, 0.25 to 3.91]).^63^

Three other trials reported on breast cancer incidence over 2 to 3 years (EPAT,^60^ ERA,^62^ and PEPI trials^74^), and results were inconclusive. Only 4 cases of breast cancer were reported across the trials (2 cases each in the estrogen-only and placebo groups).

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no difference in breast cancer risk by subgroups based on age at randomization could be detected.^102^ Biennial analyses of invasive breast cancer risk during the intervention phase of the WHI demonstrated no evidence of a trend over time since randomization (p=0.29 for trend).^104^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of invasive breast cancer in the WHI trial was similar in women who initiated estrogen soon after menopause (<5 years) versus later (≥5 years).^98^

#### Cervical Cancer

##### Benefits and Harms of Hormone Therapy

One trial (ESPRIT^64^ [N=1,017]) reported 1 incident case of cervical cancer, identified via data linkage to U.K. cancer records, over a mean followup of 12.6 years, among women who received placebo, and no incident cases of cervical cancer among women who received estrogen-only hormone therapy (Appendix G Table 2). None of the other trials reported on cervical cancer.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Colorectal Cancer

##### Benefits and Harms of Hormone Therapy

One trial (WHI [N=10,739]) estimated the incidence of colorectal cancer among 5,310 women with previous hysterectomy who received estrogen-only hormone therapy and 5,429 women with previous hysterectomy who received placebo (Appendix G Table 3).^24, 98, 102, 112, 113^

During the WHI intervention phase, 1.2 percent of women who received estrogen-only hormone therapy and 1.1 percent of women who received placebo developed colorectal cancer (HR, 1.15 [95% CI, 0.81 to 1.64]).^102^

##### Differences in Treatment Effects Based on Subgroups

In the WHI intervention phase, there was a statistically significant trend toward higher risk of developing colorectal cancer in older women compared with younger women, relative to women taking placebo (p=0.02 for trend). Among women ages 50 to 59 years and 60 to 69 years at randomization, there were no statistically significant differences in the risk of colorectal cancer between women taking estrogen-only hormone therapy and placebo (HR, 0.71 [95% CI, 0.30 to 1.67] vs. HR, 0.88 [95% CI, 0.53 to 1.47], respectively). The risk of colorectal cancer among women ages 70 to 79 years was significantly higher for those taking estrogen-only therapy than for those taking placebo (HR, 2.24 [95% CI, 1.16 to 4.30]). The significant interaction with age at randomization was no longer present after a median cumulative followup of 13.0 years.^102^

The WHI did not detect any statistically significant subgroup effects regarding race/ethnicity, diabetes status, previous use of menopausal hormone therapy, or bilateral oophorectomy status after a mean of 7.1 years.^113^

##### Differences in Treatment Effects Based on Timing of the Intervention

No statistically significant differences in incidence of colorectal cancer emerged between women who received estrogen-only hormone therapy and those who received placebo according to years since menopause (i.e., <10 years, 10 to <20 years, and ≥20 years since menopause) in the WHI.^102^ The effect of hormone therapy on the risk of invasive colorectal cancer did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who initiated combined hormone therapy after 5 years following menopause.^98^

#### Endometrial Cancer

##### Benefits and Harms of Hormone Therapy

Five trials (ERA [N=205],^62^ EPAT [N=222],^60^ ESPRIT [N=1,017],^63, 64^ PEPI [N=349],^74^ and ULTRA [N=417]^77^) provided data on endometrial cancer among women who received estrogen-only hormone therapy or placebo. We present results in Appendix G Table 4 but do not discuss them here because of the well-known risk of endometrial hyperplasia and cancer associated with unopposed estrogen use.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Lung Cancer

##### Benefits and Harms of Hormone Therapy

One trial (WHI [N=10,739]) estimated the incidence of lung cancer among 5,310 women with previous hysterectomy who received estrogen-only hormone therapy and 5,429 women with previous hysterectomy who received placebo (Appendix G Table 5).^102, 108^

No statistically significant differences in lung cancer incidence emerged between women who received estrogen-only hormone therapy and women who received placebo. Only 1.2% of women who received estrogen-only hormone therapy and 1.1% of women who received placebo developed lung cancer during the WHI intervention phase over a median followup period of 7.2 years (HR, 1.05 [95% CI, 0.74 to 1.49]).^102^ During the postintervention followup period (mean duration, 6.8 years), the risk between treatment groups remained similar.^102^

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no statistically significant differences in risk among women based on age at randomization.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Ovarian Cancer

##### Benefits and Harms of Hormone Therapy

One trial (ESPRIT [N=1,017]) of women with previously documented myocardial infarction provided the incidence of ovarian cancer among women who received estrogen-only hormone therapy or placebo during the trial's 2-year intervention (Appendix G Table 6).^64^ The authors do not report ovarian cancer incidence at the end of the intervention phase.^63^ During long-term followup (average duration, 12.6 years) that included both the trial phase and the posttrial observational phase, there was no statistically significant difference in the incidence of ovarian cancer between the two groups (0.78% and 0.20% of women in the estrogen-only and placebo groups, respectively, developed ovarian cancer).^64^

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

### Estrogen Only: Other Chronic Conditions

#### Coronary Heart Disease

##### Benefits and Harms of Hormone Therapy

Four trials (EPAT [N=222],^60^ PEPI [N=349],^74^ WHI [N=10,739],^111^ and ERA [N=205]^62^) provided data on the risk of coronary heart disease in women who used estrogen only (Appendix G Table 7).

Of these, three trials (EPAT,^60^ PEPI,^74^ and WHI^111^) were similar enough to be combined in a meta-analysis. We did not include the ERA study in the meta-analysis because only women with an elevated cardiovascular risk were eligible for enrollment.^62^ Studies in the meta-analysis provide information about the prevention of coronary heart disease with estrogen only based on data for 11,310 women who had previously undergone hysterectomy. Treatment duration ranged from 2 to 7.1 years. The WHI and EPAT trials defined coronary heart disease as nonfatal myocardial infarction or coronary death;^111^ the definition used in the PEPI trial was unclear.^74^

A meta-analysis of these three trials rendered no statistically significant difference in coronary events between women taking estrogen therapy and those taking placebo (RR, 0.95 [95% CI, 0.79 to 1.14]). In the meta-analysis, 3.6 percent of women receiving estrogen-only therapy and 3.8 percent of those receiving placebo experienced a coronary event during a mean followup of 6.8 years. A sensitivity analysis including the ERA trial rendered similar results.

A long-term followup study of the WHI reported that 3.9 years after stopping the randomized treatment, the cardiovascular risk was still similar between women who received hormone therapy during the trial and those who were randomized to placebo (HR, 0.97 [95% CI, 0.75 to 1.25]).^112^

##### Differences in Treatment Effects Based on Subgroups

In the WHI trial, no statistically significant difference in risk of coronary heart disease attributable to hormone therapy could be detected between subgroups based on age, race/ethnicity, hypertension, diabetes, high cholesterol requiring medication, coronary risk factors, years since bilateral oophorectomy, years since hysterectomy, or body mass index.^35, 102, 111^ Although risk for coronary heart disease in women taking estrogen-only therapy increased numerically with age, this trend did not reach statistical significance. The HR for women ages 50 to 59 years was 0.60 (95% CI, 0.35 to 1.04) in favor of hormone therapy. By comparison, the HRs for women ages 60 to 69 years and 70 to 79 years at baseline were 0.95 (95% CI, 0.72 to 1.24) and 1.09 (95% CI, 0.80 to 1.49), respectively (p=0.08 for trend).^102^ Analyses that focused just on myocardial infarction yielded a statistically significant trend for increasing risk by age when comparing younger (ages 50 to 59 years) with older (ages 70 to 79 years) women (p=0.02 for trend). These findings, however, need to be viewed cautiously because only 48 women in the 50- to 59-year age group experienced a myocardial infarction.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

In the WHI, time since menopause did not have a statistically significant effect on the risk of coronary heart disease.^102^ Likewise, an analysis of WHI data that took the first use of hormone therapy (before enrollment into the WHI) into consideration to assess the effect of timing of hormone therapy did not find an effect of early initiation on the risk of coronary heart disease (p=0.40).^98^

The onset of menopause in women who had undergone hysterectomy without oophorectomy, however, cannot always be determined with certainty. Results, therefore, have to be interpreted cautiously.

#### Cognitive Functioning and Dementia

##### Benefits and Harms of Hormone Therapy

The WHI trials evaluated dementia or mild cognitive impairment (Appendix G Table 8). The WHIMS trial (N=2,947), a subset of the WHI trial, was limited to women ages 65 to 79 years at baseline, free of probable dementia, and recruited from 39 of 40 WHI trial centers. Participants in WHIMS were followed for approximately 5.2 years. WHISCA, a subset (N=434 in the estrogen arm, N=452 in the placebo arm) of the WHIMS trial, was limited to 14 of 39 trial centers and designed to evaluate changes in cognitive functioning over time, with the first assessment occurring 3 years after the start of treatment (because WHISCA was an ancillary trial to WHIMS).^127^ Participants in WHISCA were followed for approximately 3.6 years during the trial, and a further subset of WHISCA, in an extension study, was followed for 2.4 years after treatment. Neither WHIMS nor WHISCA found an elevated risk of probable dementia or mild cognitive impairment among women taking hormone therapy.^117, 121^ When using a composite outcome measure (probable dementia or mild cognitive impairment), the study found a statistically significantly higher risk among women taking estrogen-only therapy compared with women taking placebo (6.4% vs. 4.7%; cumulative HR, 1.38 [95% CI, 1.01 to 1.89]).^117^

Three trials (WHIMS [N=4,344],^115^ WHISCA [N=1,213],^120^ and ULTRA [N=417]^79^) measured global cognitive functioning using the Modified Mini-Mental State (3MS) examination; heterogeneity in timing precluded meta-analysis. The WHIMS and WHISCA trials are described above. The ULTRA trial randomized women to estrogen-only or placebo transdermal patches. Additionally, all participants received 400 mg of calcium twice daily and 400 IU of vitamin D once daily.^79^ The ULTRA trial followed participants for 2 years. The WHI trials found cognitive deficits during the trial period (change in 3MS score at 3.6 years during WHISCA trial, -0.092; p=0.02;^120^ change in 3MS score at 5.4 years at the end of the WHIMS trial, -0.26 [95% CI, -0.542 to 0.000]; p=0.04^115^). In a long-term extension of the WHISCA trial, with outcomes measured at 2.4 years after trial termination, these differences were not sustained.^120^ The ULTRA study found no differences.^79^

Three trials (WHISCA [N=1,213],^120, 121^ WHIMSY [N=1,326],^119^ and ULTRA [N=417]^79^) evaluated other measures of cognitive functioning (e.g., spatial ability, verbal knowledge, verbal fluency, verbal memory, figural memory, attention, and working memory); heterogeneity in outcome measures precluded meta-analysis. The WHISCA and ULTRA trials are described above. The WHIMSY trial, an extension of the WHI trial, was limited to enrolled active participants in the WHI trials who were ages 50 to 55 years at enrollment and agreed to be contacted for recruitment (N=1,326 assessed, N by treatment regimen not reported). The WHIMSY trial followed women for 7.2 years after the end of the trial. All three trials found no differences in groups as randomized for the majority of outcomes.

##### Differences in Treatment Effects Based on Subgroups

The WHIMS study reported no difference in the HR for probable dementia by race/ethnicity or history of diabetes, stroke, hypertension, or cardiovascular disease.^117^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Diabetes

##### Benefits and Harms of Hormone Therapy

The WHI (N=9,917)^102, 106^ was the only trial that provided information about the prevention of diabetes with estrogen only among women not receiving treatment for diabetes at baseline (Appendix G Table 9). Incident diabetes was self-reported and defined as a new diagnosis of diabetes by a physician followed by treatment with oral hypoglycemic drugs or insulin.^106^

During a median of 7.2 years of followup, 9.2 percent of women receiving estrogen therapy and 10.5 percent of those receiving placebo reported a new diabetes diagnosis. The difference in risk between these groups reached statistical significance (HR, 0.86 [95% CI, 0.76 to 0.98]).^102^ When the analysis focused on women who adhered to medication (took ≥80% of study pills or began open-label therapy), the difference in risk increased further (HR, 0.73 [95% CI, 0.60 to 0.88]).^106^ The overall reduction in diabetes risk was no longer observed 6.6 years postintervention (HR, 1.07 [95% CI, 0.92 to 1.25]).^102^

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any statistically significant subgroup effects with respect to race/ethnicity, age at screening, hypertension, or metabolic syndrome at baseline among women in the WHI.^106^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Fractures

##### Benefits and Harms of Hormone Therapy

The WHI (N=10,739) found a reduced risk of total osteoporotic fractures in the estrogen-only arm compared with placebo during the trial (10.2% vs. 14.1%; HR, 0.72 [95% CI, 0.64 to 0.80]),^102^ as did the ERA trial^62^ (Appendix G Table 10). The difference (for hip fractures) was no longer statistically significant in the postintervention phase of the WHI study (through 10.7.years).^112^ The ERA trial randomized women to the same treatment regimen as the WHI study and followed them for 3.2 years. The study found fewer fractures at all sites (6% vs. 14.3%) in the estrogen-only arm, but the RR was not statistically significant (calculated RR, 0.42 [95% CI, 0.17 to 1.04]).^62^

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any statistically significant subgroup effects with respect to age among women in the WHI.^81^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Gallbladder Disease

##### Benefits and Harms of Hormone Therapy

Two trials (PEPI [N=349]^74^ and WHI [N=8,376]^88^) provided information about the prevention of gallbladder disease with estrogen only based on data for 8,725 women with gallbladders and without gallbladder disease (Appendix G Table 11). Treatment duration was 3 years among women in PEPI and an average of 7.1 years among those in the WHI. Although the definition of gallbladder disease used in PEPI is unclear, it included cholecystitis and calculi in the WHI.^74, 88^ Gallbladder procedures, including biliary tract procedures such as cholecystectomy, were also reported for women in the WHI.^88^

The larger of the two trials, WHI, reported gallbladder events (disease or procedure) during followup for 5.5 percent of women receiving estrogen therapy and 3.4 percent of those taking placebo.^88^ The difference in gallbladder events between these groups was statistically significant (HR, 1.67 [95% CI, 1.35 to 2.06]).^88^ However, risk of gallbladder disease neutralized 6.6 years postintervention (HR, 0.98 [95% CI, 0.68 to 1.41]).^102^

The PEPI trial had few cases of gallbladder disease and reported inconclusive results.^74^

##### Differences in Treatment Effects Based on Subgroups

Risk of gallbladder events attributable to estrogen therapy among women in the WHI increased with age but did not reach statistical significance.^88^ No other evidence is available in the included studies on subgroups of interest.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Stroke

##### Benefits and Harms of Hormone Therapy

Three trials (WHI [N=10,739],^102, 112^ EPAT [N=222],^60^ and ERA [N=205]^62^) reported on risk of stroke (Appendix G Table 12). We did not pool trial results because of heterogeneity in study duration and outcome measures.

During the WHI 7.2-year (median) intervention phase, women receiving estrogen only had a statistically significantly higher risk of stroke compared with those receiving placebo (3.2% vs. 2.4%; HR, 1.35 [95% CI, 1.07 to 1.70]).^102^ During the postintervention period (3.9 years after stopping therapy), the risk between the two treatment groups became similar again; cumulatively (at 10.7 years of followup), stroke risk was higher in the estrogen-only group compared with the placebo group (4.4% vs. 3.8%; HR, 1.15 [95% CI, 0.97 to 1.37]).^102, 112^

The two smaller trials (EPAT^60^ and ERA^62^) reported on stroke risk among women randomized to estrogen or placebo; few events occurred overall and results were inconclusive. In the EPAT trial, one participant (randomized to placebo) had a cerebrovascular accident at 2 years.^60^ In the ERA trial, the risk of stroke or transient ischemic attack was similar in the estrogen-only and placebo groups (5 vs. 6 events, respectively).^62^

##### Differences in Treatment Effects Based on Subgroups

In the WHI estrogen-only trial, no differences in stroke risk by subgroups, including race/ethnicity, age, prior cardiovascular disease, hypertension, or diabetes could be detected.^110^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of stroke in the WHI was similar among women who initiated estrogen soon after menopause (<5 years) versus later (≥5 years).^98^

#### Urinary Incontinence

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=3,073 continent]^94^ and ULTRA [N=239 continent]^78^) provided results on incident urinary incontinence (self-reported) (Appendix G Table 13). The WHI followed continent women through year 1 and then evaluated incontinence at year 2. The ULTRA study followed participants for 2 years.^79^ Both studies found higher risk of urinary incontinence in the treatment arms for all time points, but the only statistically significant risk was at 1 year (WHI trial, 36.5% vs. 23.8%; RR, 1.53 [95% CI, 1.37 to 1.71]).^94, 102^ Results drawing on smaller samples at 2 years (ULTRA trial, 39.0% vs. 36.8%; odds ratio, 1.2 [95% CI, 0.7 to 2.2])^78^ and 3 years of treatment did not show any statistically significant differences (WHI trial, 28.1% vs. 19.1%; RR, 1.47 [95% CI, 0.92 to 2.36]).^94^

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Venous Thromboembolism

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=10,739]^102, 112^ and EPAT [N=222]^60^) reported on risk of thromboembolism (Appendix G Table 14). In the WHI, women randomized to estrogen alone had an increased risk of deep vein thrombosis compared with placebo during the 7.1-year (mean) intervention phase (1.6% vs. 1.0%; HR, 1.48 [95% CI, 1.06 to 2.07]);^102^ the risk of pulmonary embolism was also higher in the estrogen group than in the placebo group, but results were not significant (0.98% vs. 0.72%; HR, 1.35 [95% CI, 0.89 to 2.05]).^102^ There was no difference between groups for risk of deep vein thrombosis or pulmonary embolism 3.9 years after stopping therapy in the postintervention period.^112^ The EPAT trial reported no venous thromboembolic events in either group during 2 years of followup.^60^

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no differences for subgroups by race/ethnicity, age, or history of cardiovascular disease.^109^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of venous thromboembolism in the WHI was similar among women who initiated estrogen soon after menopause (<5 years) versus later (≥5 years).^98^

#### Health-Related Quality of Life

##### Benefits and Harms of Hormone Therapy

The WHI (N=10,739)^102^ was the only trial that reported on health-related quality of life (Appendix G Table 15). It used the RAND-36 form, which assesses physical functioning, physical role, bodily pain, general health, vitality, social functioning, emotional role, and mental health. Women in both groups had similar scores on all items except for emotional role and social functioning, for which women taking placebo had statistically significantly better scores than women taking estrogen-only therapy (p=0.04 and p=0.01, respectively).

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### All-Cause Mortality

##### Benefits and Harms of Hormone Therapy

Three trials (ERA [N=205],^62^ ESPRIT [N=1,017],^63^ and WHI [N=10,739]^112^) provided information about the risk of death from any cause among 11,961 women receiving estrogen therapy (Appendix G Table 16). The average treatment duration of these trials ranged from 2 to 7.1 years.^62, 63, 112^ A meta-analysis of these trials rendered no statistically significant difference in all-cause mortality between women receiving estrogen therapy and those receiving placebo (RR, 1.01 [95% CI, 0.88 to 1.17]) during a mean followup of 6.8 years.

The WHI, the largest of the three trials, reported an HR of 1.04 (95% CI, 0.89 to 1.22), with deaths among 5.6 and 5.5 percent of women in the active and placebo groups, respectively.^112^ The difference in risk between the two groups remained similar at followup 3.9 years after stopping the randomized treatment (HR, 1.00 [95% CI, 0.84 to 1.18]).^112^

##### Differences in Treatment Effects Based on Subgroups

Interaction with age reached statistical significance in the WHI, with a significant trend toward lower risk of death in younger women receiving estrogen therapy compared with older women relative to women receiving placebo (p=0.04 for trend).^112^ The HR was 0.70 (95% CI, 0.46 to 1.09) among women ages 50 to 59 years compared with 1.01 (95% CI, 0.79 to 1.29) among women ages 60 to 69 years and 1.21 (95% CI, 0.95 to 1.56) among women ages 70 to 79 years.

##### Differences in Treatment Effects Based on Timing of the Intervention

An analysis of WHI data considered the time between menopause and the first use of hormone therapy (before enrollment into the WHI).^98^ The effect of estrogen-only therapy on all-cause mortality did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who initiated hormone therapy after 5 years following menopause.^98^

### Estrogen Plus Progestin: Cancer

#### Breast Cancer

##### Benefits and Harms of Hormone Therapy

Six trials (WHI [N=16,608],^23, 84, 85, 90, 92, 98, 102, 104^ HERS [N=2,763],^68^ PEPI [N=700],^74^ EPHT [N=777],^61^ ERA [N=209],^62^ and WISDOM [N=4,385])^123^ comparing estrogen plus progestin with placebo reported on breast cancer incidence (Appendix G Table 1). We did not pool trial results because of heterogeneity in study duration and outcome measures. Only two trials followed women for more than 4 years (WHI and HERS), and only the WHI reported on the risk of invasive breast cancer (vs. any breast cancer).

The WHI is the largest trial; during the intervention phase (median, 5.6 years), women assigned to estrogen plus progestin had a significantly increased risk of invasive breast cancer compared with women taking placebo (2.4% vs. 1.9%; HR, 1.24 [95% CI, 1.01 to 1.53]).^102^ The risk of invasive breast cancer in women who took estrogen plus progestin remained significantly increased compared with women who took placebo during a median postintervention followup of 8.2 years (HR, 1.32 [95% CI, 1.08 to 1.61]).^102^ In the HERS trial, more women randomized to estrogen plus progestin developed breast cancer during the 4.1-year intervention phase than did women receiving placebo, but the results were not statistically significant (2.5% vs. 1.8%; HR, 1.38 [95% CI, 0.82 to 2.31]).^68^

Four other trials reported on breast cancer incidence.^61, 62, 74, 128^ In three small trials (ERA, PEPI and EPHT), few cases occurred overall, and risk of breast cancer incidence was similar between groups randomized to estrogen plus progestin and placebo over 3 to 4 years (no cases overall in ERA and 3 vs. 3 cases, respectively, across PEPI and EPHT); few cases of breast cancer were reported overall.^61, 62, 74^ The fourth trial, WISDOM (N=4,385), was stopped after 1 year because of the WHI results that indicated excess breast cancer risk in women receiving estrogen plus progestin; breast cancer incidence was similar between groups at 1 year (5 vs. 7 cases, respectively).^123^

##### Differences in Treatment Effects Based on Subgroups

In the WHI estrogen plus progestin trial, incidence of invasive breast cancer did not differ based on age at randomization.^102^ Biennial analyses of invasive breast cancer risk during the intervention phase of the WHI provided evidence of a trend over time (p=0.008 for trend). The risk of invasive breast cancer increased numerically with time since randomization (2 years after: HR, 0.71 [95% CI, 0.47 to 1.08]; 4 years after: HR, 1.36 [95% CI, 0.95 to 1.94]; 6 years after: HR, 1.65 [95% CI, 1.17 to 2.32]).^104^

##### Differences in Treatment Effects Based on Timing of the Intervention

In the WHI estrogen plus progestin trial, risk of invasive breast cancer decreased with an increasing gap in time since menopause (p=0.03 for interaction).^98^

#### Cervical Cancer

##### Benefits and Harms of Hormone Therapy

The WHI (N=16,608) evaluated the incidence of cervical cancer among women with an intact uterus who received either estrogen plus progestin or placebo (Appendix G Table 2).^81^ The incidence of cervical cancer did not differ significantly between women who received estrogen plus progestin hormone therapy and women who received placebo (HR, 1.44 [95% CI, 0.47 to 4.42]) during a median followup period of 5.6 years; 0.09 percent of women receiving hormone therapy and 0.06 percent of women receiving placebo were diagnosed with cervical cancer.^81^ WHI investigators did not provide cervical cancer incidence from the postintervention and postintervention extension phases.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Colorectal Cancer

##### Benefits and Harms of Hormone Therapy

Four trials (WHI [N=16,608],^23, 87, 92, 98, 102^ EMS [N=142],^59^ HERS [N=2,763],^68^ and WISDOM [N=4,385]^123^) reported on the incidence of colorectal cancer (Appendix G Table 3). In the WHI intervention phase, women receiving estrogen plus progestin were less likely to develop colorectal cancer than women in the placebo group (HR, 0.62 [95% CI, 0.43 to 0.89]); 0.59 percent of women in the estrogen plus progestin therapy group and 0.93 percent of women in the placebo group developed colorectal cancer over a median followup period of 5.6 years.^102^ Over the entire median followup period of 13.2 years, the risk of colorectal cancer remained lower in the hormone therapy arm (HR, 0.80 [95% CI, 0.63 to 1.01]).^102^ In the HERS trial, there was a numeric decrease in the risk of colorectal cancer with estrogen plus progestin use (HR, 0.69 [95% CI, 0.32 to 1.49]) over a mean of 4.1 years.^68^

The EMS and WISDOM trials reported no statistically significant differences in risk of colorectal cancer. Event rates in these studies, however, were low (no events in EMS and 4 events in WISDOM), and very short followup time periods (i.e., <2 years) precluded them from being combined with the WHI and HERS trial data in meta-analysis.

##### Differences in Treatment Effects Based on Subgroups

In the WHI intervention phase, the incidence of colorectal cancer did not differ significantly between women who received estrogen plus progestin hormone therapy and women who received placebo according to the following variables: age,^102^ race/ethnicity, and family history of colorectal cancer.^87^

##### Differences in Treatment Effects Based on Timing of the Intervention

The incidence of colorectal cancer in the WHI did not differ significantly between women who received hormone therapy and women who received placebo according to the number of years since menopause (i.e., <10 years, 10 to <20 years, and ≥20 years since menopause) in the WHI intervention phase.^102^ The effect of estrogen plus progestin on the risk of invasive colorectal cancer did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who initiated it after 5 years following menopause.^98^

#### Endometrial Cancer

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=16,608]^23, 81, 92, 98, 102, 103, 108^ and HERS^68^ [N=2,763]) estimated the incidence of endometrial cancer among a total of 9,886 women with an intact uterus who received estrogen plus progestin hormone therapy and 9,485 women with an intact uterus who received placebo (Appendix G Table 4).

In both trials, the incidence of endometrial cancer did not differ significantly between women who received estrogen plus progestin hormone therapy and women who received placebo. During the WHI's intervention phase (median followup, 5.6 years), 0.32 percent of women who received estrogen plus progestin and 0.37 percent of women who received placebo developed endometrial cancer (HR, 0.83 [95% CI, 0.49 to 1.40]).^102^ Likewise, during the HERS trial phase (mean followup, 4.1 years), no statistically significant differences in risk could be detected (0.14% vs. 0.36%; HR, 0.39 [95% CI, 0.08 to 2.02]).^68^

During the WHI postintervention period, statistically significantly fewer women who were randomized to hormone therapy during the trial phase developed endometrial cancer (HR, 0.58 [95% CI, 0.40 to 0.86]) compared with women who had received placebo.^102^

Two additional trials (ERA [N=209]^62^ and PEPI [N=700]^74^) reported no endometrial cancer cases as adverse events over a period of 3 years; the trials were too small and short in duration to draw inferences on differences in risk or to combine in meta-analysis with the WHI and HERS.

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no significant differences among 10-year age groups at randomization in the incidence of endometrial cancer between women who received estrogen plus progestin hormone therapy and those who received placebo.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

The effect of estrogen plus progestin on the risk of invasive endometrial cancer in the WHI did not differ significantly between women who started estrogen plus progestin hormone therapy within the first 5 years after menopause and women who began it after 5 years following menopause.^98^

#### Lung Cancer

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=16,608]^86, 102^ and HERS [N=2,763]^68^) estimated the incidence of lung cancer among a total of 9,886 women with an intact uterus who received estrogen plus progestin and 9,485 women with an intact uterus who received placebo (Appendix G Table 5).

In both the WHI and HERS, lung cancer incidence did not differ significantly between women who received estrogen plus progestin and those who received placebo. In the WHI intervention phase (median followup, 5.6 years), 0.92 percent of women who received estrogen plus progestin and 0.86 percent of women who received placebo developed lung cancer (HR, 1.05 [95% CI, 0.76 to 1.45]).^102^ In the HERS trial phase (mean followup, 4.1 years), 1.74 percent of women who received estrogen plus progestin and 1.37 percent of women who received placebo developed lung cancer (HR, 1.28 [95% CI, 0.70 to 2.33]).^68^

The risk between groups remained similar during the postintervention followup.^68, 102^

A small trial (EMS [N=142]^59^) reported only a single lung cancer case among women receiving estrogen plus progestin and no cases among women receiving placebo during a comparatively short 2-year trial period, precluding it from being combined with the WHI and HERS in meta-analysis.^59^

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no significant differences in the incidence of lung cancer emerged among 10-year age groups at randomization between women who received estrogen plus progestin and women who received placebo.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Ovarian Cancer

##### Benefits and Harms of Hormone Therapy

The WHI (N=16,608) evaluated the incidence of invasive ovarian cancer among women with an intact uterus who received either estrogen plus progestin hormone therapy or placebo (Appendix G Table 6).^81, 102^ The incidence of invasive ovarian cancer did not differ significantly between groups (HR, 1.41 [95% CI, 0.75 to 2.66]); 0.28 percent of women who received estrogen plus progestin and 0.20 percent of women who received placebo developed invasive ovarian cancer over a median followup of 5.6 years during the intervention phase.^102^

Risk remained similar during the postintervention followup (median followup of 8.2 years; HR, 1.12 [95% CI, 0.65 to 1.90]).^102^

##### Differences in Treatment Effects Based on Subgroups

In the WHI, there were no significant differences in the incidence of invasive ovarian cancer among 10-year age groups at randomization between women who received estrogen plus progestin and those who received placebo.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

### Estrogen Plus Progestin: Other Chronic Conditions

#### Coronary Heart Disease

##### Benefits and Harms of Hormone Therapy

Overall, six trials (EMS [N=142],^59^ EPHT [N=777)],^61^ PEPI [N=700],^74^ WHI [N=16,608],^23^ WISDOM [N=4,385],^123^ and ERA [N=209]^62^) provided information about preventing coronary heart disease with estrogen plus progestin (Appendix G Table 7).

Of these, three trials (EPHT,^61^ PEPI,^74^ and WHI^23^) were similar enough to be combined in a meta-analysis. We did not include the ERA study, which enrolled only women with an elevated cardiovascular risk,^62^ the EMS trial^59^ because its definition of cardiovascular events also included deep vein thrombosis and cerebrovascular events, and the WISDOM trial because it had a followup time of only 1 year.^123^ Trials included in the meta-analysis provided data on 18,081 women with treatment durations of 2 to 5.2 years. Results of the meta-analysis showed a numerically higher risk of coronary events in women treated with hormone therapy than in those treated with placebo (2.1% vs. 1.7%; RR, 1.23 [95% CI, 0.996 to 1.520]) during a mean followup of 5 years. Sensitivity analyses including ERA, EMS, and WISDOM rendered a statistically significant difference. The WHI reported an HR of 1.18 (95% CI, 0.95 to 1.45) for coronary events.^102^ Long-term followup of women in the WHI showed that 2.4 years after stopping the randomized hormone therapy, the cardiovascular risk was similar between women who took this hormone therapy during the trial and those who received placebo (HR, 1.04 [95% CI, 0.89 to 1.21]).^92^

The WISDOM trial was prematurely closed because of findings of the WHI. However, after 1 year of followup (6,498 women-years), women taking estrogen plus progestin had a statistically significantly higher risk of cardiovascular events (0.3% vs. 0.0%; p=0.016) than women taking placebo.^123^

##### Differences in Treatment Effects Based on Subgroups

WHI subgroup analyses indicated no significant differences in subgroups based on race/ethnicity, age, years since menopause, hypertension, diabetes, or cardiovascular disease at baseline.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

Subgroup analysis in the WHI indicated that women who had started hormone therapy closer to menopause (within 10 years of menopause) did not have the same elevated risk of coronary heart disease as women who had initiated hormone therapy later. The HR for coronary heart disease in women with less than 10 years of menopause was 0.90 (95% CI, 0.56 to 1.45). In women with more than 20 years of menopause, the HR was 1.52 (95% CI, 1.07 to 2.17) (p=0.08 for trend).^102^ When the analyses focused just on myocardial infarction, women who initiated estrogen plus progestin therapy closer to menopause did not have the elevated risk of myocardial infarction that women who started therapy more than 20 years after menopause experienced (p=0.01). Findings, however, need to be viewed cautiously because only 67 women who initiated hormone therapy within 10 years of menopause experienced a myocardial infarction.^102^

An additional analysis based on WHI data took into consideration the time between menopause and the first use of hormone therapy (before enrollment into the WHI) to assess the effect of timing.^98^ This analysis, therefore, addresses the effect of timing better than analyses that focus exclusively on the time between menopause and randomization. The effect of estrogen plus progestin on the risk of cardiovascular events did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who started it after 5 years following menopause (p=0.42 for interaction).^98^

Two other trials did not meet our eligibility criteria because they assessed only surrogate endpoints for cardiovascular disease. They did, however, address the timing hypothesis. Specifically, the KEEPS (Kronos Early Estrogen Prevention Study) and ELITE (Early versus Late Intervention Trial with Estradiol) trials used change in carotid artery intima-media thickness as the primary outcome.^29, 129^ Secondary endpoints included changes in markers of cardiovascular risk. KEEPS and ELITE enrolled women free from cardiovascular disease and stratified them according to time since menopause.

KEEPS enrolled healthy women ages 42 to 58 years within 3 years of menopause. It compared women receiving low-dose daily oral conjugated equine estrogen (0.45 mg/day) or transdermal estrogen (17β-estradiol, 50 μg/day), both with cyclic progesterone (200 mg for 12 days) treatment, with women receiving placebo. After 4 years of followup, investigators did not detect any statistically significant differences in the primary endpoint and found only mixed results for secondary endpoints.^129^

By contrast, ELITE used a higher oral estrogen dose (17β-estradiol, 1 mg/day) than KEEPS and vaginal micronized progesterone (45 mg/day for 10 days) for 5 years. Compared with placebo, hormone therapy resulted in a significantly lower rate of atherosclerosis progression among early postmenopausal women (<6 years since menopause) but not among late postmenopausal women (>10 years since menopause). The clinical significance of this difference, however, is unclear.

#### Cognitive Functioning and Dementia

##### Benefits and Harms of Hormone Therapy

One WHI trial (WHIMS [N=4,532]^118^) evaluated the risk of probable dementia or mild cognitive impairment among women taking estrogen plus progestin (Appendix G Table 8). WHIMS, a subset of the WHI trial, was limited to women ages 65 to 79 years at baseline, free of probable dementia, and recruited from 39 of 40 WHI trial centers. Participants in WHIMS were followed for approximately 5.4 years. Women using estrogen plus progestin had a higher risk of probable dementia than those taking placebo (1.8% vs. 0.9%; HR, 2.05 [95% CI, 1.21 to 3.48]). The trial did not find an elevated risk of mild cognitive impairment.^118^

Three studies (HERS, KEEPS-Cog, and WHI) comprising four trials (HERS [N=1,328],^72^ KEEPS-Cog [N=693],^73^ WHIMS [N=4,532],^115, 116^ and WHISCA [N=1,213]^120^) measured global cognitive functioning using the Modified Mini-Mental Status Examination (MMSE). The HERS trial had a treatment regimen similar to that used in the WHI studies. It included 662 women randomized to estrogen plus progestin and 666 women randomized to placebo; participants were followed for 4.2 years. HERS found no cognitive deficits through 4 years of followup.^72^

WHISCA was a subset (N=690 in the estrogen plus progestin arm, N=726 in the placebo arm) of the WHIMS trial. It was limited to 14 of 39 trial centers and designed to evaluate changes in cognitive functioning over time; the first assessment occurred 3 years after the start of treatment.^127^ Participants in WHISCA were followed for approximately another 2 years; a further subset of WHISCA, in an extension study, were followed for 4 years after treatment. Deficits in cognitive functioning measured during the trial period (2 years) among WHIMS participants for the active arm were not sustained for women in WHISCA.^120^

KEEPS-Cog, an ancillary study to KEEPS, comprised women who consented to participate in a study of cognitive function. Women were age 52.6 years on average and 1.4 years past their last menstrual period. The study randomized women to either oral or transdermal estrogen plus progestin or placebo pills and patches. The study found no differences between women randomized to estrogen plus progestin therapy and those randomized to placebo in change in 3MS score over a 4-year period of observation. Four trials (EMS [N=142],^59^ HERS [N=1,328],^72^ WHISCA [N=1,416],^122^ and WHIMSY [N=1,326]^119^) evaluated other measures of cognitive functioning; heterogeneity in outcome measures precluded meta-analysis. The HERS and WHISCA trials are described above. The WHIMSY trial, an extension of the WHI trial, was limited to 1,326 enrolled active participants in treatment or placebo arms in the WHI trials who were ages 50 to 55 years at enrollment and agreed to be contacted for recruitment (N=1,326 assessed, N by treatment regimen not reported). The WHIMSY trial followed women for 7.2 years after the end of the trials. The EMS trial randomized 70 women to estrogen plus progestin and 72 women to placebo and followed them for 2 years. Women in HERS were followed for 4.2 years. All trials found no differences in groups as randomized for the majority of outcomes.

##### Differences in Treatment Effects Based on Subgroups

WHIMS found no difference in possible dementia by history of diabetes,^118^ stroke,^118^ hypertension,^117^ cardiovascular disease,^117^ or race/ethnicity.^117^ It also found no difference in the rate of change in three MMSE scores by race/ethnicity, body mass index, history of cardiovascular disease, hypertension, diabetes, or length of use.^116^

##### Differences in Treatment Effects Based on Timing of the Intervention

WHIMS found no difference in the rate of change in three MMSE scores by time to initiation of hormone therapy after the last menstrual period.^116^

#### Diabetes

##### Benefits and Harms of Hormone Therapy

Two trials (HERS [N=2,029]^70^ and WHI [N=15,874]^97, 102^) provided information about the prevention of diabetes with estrogen plus progestin among 17,903 women without diabetes or not receiving treatment for diabetes at baseline (Appendix G Table 9). Incident diabetes was defined in HERS as having a fasting glucose level of 6.9 mmol/L or greater (≥126 mg/dL), self-report of new diabetes or diabetes-related complications (diabetic neuropathy, diabetic retinopathy, diabetic foot ulcer, diabetic renal disease, or hypoglycemia if reported by a woman taking an antidiabetic medication), or initiation of hypoglycemic medication; this analysis was conducted post hoc and should be considered cautiously.^70^ In the WHI, incident diabetes was limited to self-reported new diagnoses of diabetes by a physician followed by treatment with oral hypoglycemic drugs or insulin.^97^

Estrogen plus progestin therapy protected against incident diabetes among women in HERS (mean followup, 4.1 years; HR, 0.65 [95% CI, 0.48 to 0.89]) and WHI (mean followup, 5.6 years; HR, 0.81 [95% CI, 0.70 to 0.94]).^70, 97^ In the WHI, the larger trial of the two, new diabetes diagnoses were reported during followup by 4.0 percent of women randomized to active treatment and 4.8 percent of those taking placebo.^97, 102^ However, this reduction in risk of diabetes was no longer observed 8.2 years postintervention (HR, 1.19 [95% CI, 1.05 to 1.34]).^102^

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any statistically significant subgroup effects with respect to race/ethnicity, age at screening, or hypertension at baseline for women in the WHI.^97^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Fractures

##### Benefits and Harms of Hormone Therapy

Five trials (EMS [N=142],^59^ EPHT [N=777],^61^ ERA [N=209],^62^ HERS [N=2,763],^68^ and WHI [N=16,608]^23, 83, 92, 102^) provided information on the rate of fractures (Appendix G Table 10). These trials spanned reporting periods from 2 through 5.2 years. The studies varied widely in sample size, from a total of 142 patients in the smallest study (EMS) to 16,608 in the largest (WHI). Studies defined fractures in varying ways; some specified hip or vertebral fractures only, while others included all osteoporotic or all fractures, regardless of site.

A random-effects meta-analysis of these five trials measuring outcomes during or at the end of the trial period (N=20,499) yielded an RR of 0.80 (95% CI, 0.68 to 0.94). In the meta-analysis, 8.6 percent of women taking estrogen plus progestin and 10.9 percent of women taking placebo experienced fractures.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Gallbladder Disease

##### Benefits and Harms of Hormone Therapy

Two trials (PEPI [N=700]^74^ and WHI [N=14,203]^88^) provided information about the prevention of gallbladder disease with estrogen plus progestin among 14,903 women with gallbladders and without gallbladder disease (Appendix G Table 11). Treatment duration was 3 years for women in PEPI and 5.6 years, on average, for women in the WHI. The WHI's definition of gallbladder disease included cholecystitis and calculi; the definition used in PEPI is unclear.^74, 88^ Gallbladder procedures were also reported in the WHI, which included biliary tract procedures such as cholecystectomy.^88^

The WHI, which is the larger of the two trials, reported gallbladder events (disease or procedure) during followup for 3.1 percent of women randomized to active treatment and 2.0 percent of those taking placebo; this difference was statistically significant (HR, 1.59 [95% CI, 1.28 to 1.97]).^88^ Risk of gallbladder disease decreased postintervention but continued to favor placebo over estrogen plus progestin therapy (mean 5.6 years intervention: HR, 1.61 [95% CI, 1.30 to 2.00];^88^ median 8.2 years postintervention: HR, 1.24 [95% CI, 1.01 to 1.52]^102^).

The PEPI trial had few cases of gallbladder disease and reported inconclusive results.^74^

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any subgroup effects with respect to age of women in the WHI.^88^ We found no other evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Stroke

##### Benefits and Harms of Hormone Therapy

Three trials reported on risk of stroke (WHI [N=16,608],^24, 98, 101, 102, 112^ EMS [N=142],^59^ and EPHT [N=777]^61^) (Appendix G Table 12). We did not pool trial results because of heterogeneity in study duration and outcome measures.

During the WHI intervention phase (median, 5.6 years), stroke risk was significantly higher with estrogen plus progestin than with placebo (1.9% vs. 1.3%; HR, 1.37 [95% CI, 1.07 to 1.76]); during postintervention followup, stroke risk was similar for these two groups (HR, 1.04 [95% CI, 0.86 to 1.26]).^102^ Cumulatively, stroke risk was higher in the estrogen plus progestin group compared with placebo (HR, 1.16 [95% CI, 1.00 to 1.35]).^102^

The two other trials comparing estrogen plus progestin and placebo reported on the incidence of various cerebrovascular events as harms of treatment.^59, 61^ In EMS, few events occurred over 2 years (3 events total), and the results were inconclusive.^59^ In EPHT, risk of any cerebrovascular event (composite stroke, transient ischemic attack, and subarachnoid hemorrhage) was higher among women randomized to estrogen plus progestin than placebo (5.7% vs. 2.4%; HR, 2.46 [95% CI, 1.14 to 5.34]).^61^

##### Differences in Treatment Effects Based on Subgroups

No difference was seen in stroke risk in the WHI based on subgroups of women by age, race/ethnicity, or coexisting condition.^101^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of stroke in the WHI was similar for women who started estrogen plus progestin soon after menopause (<5 years) and those who started later (≥5 years).^98^

#### Urinary Incontinence

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=5,182] and HERS [N=1,208]) provided results on incident urinary incontinence (self-reported) in women who had been continent at baseline (Appendix G Table 13).^71, 94^ The WHI followed continent women through year 1 and then evaluated incontinence at year 2 for those continent at year 1. The HERS trial had a similar treatment regimen as the WHI studies and followed women for 4.2 years. Both studies showed a consistently higher risk of urinary incontinence at all time points for the estrogen plus progestin group compared with placebo. In the WHI, 31.2 percent of women taking hormone therapy reported incident incontinence at year 1 compared with 22.5 percent of women taking placebo (RR, 1.39 [95% CI, 1.27 to 1.52]).^94^ At year 3, the risk remained statistically significantly elevated (RR, 1.81 [95% CI, 1.16 to 2.84]).^94^ In the HERS trial, women taking estrogen plus progestin had a higher risk of incontinence compared with women taking placebo at the 4.2-year followup (odds ratio, 1.6 [95% CI, 1.3 to 1.9]).^71^

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Venous Thromboembolism

##### Benefits and Harms of Hormone Therapy

Four trials (WHI [N=16,608],^89, 92, 98, 102^ ERA [N=209],^62^ EMS [N=142],^59^ and EPHT [N=777]^61^) reported on the incidence of venous thromboembolism (Appendix G Table 14). We did not pool trials because of heterogeneity in study duration and outcome measures.

In the WHI, women randomized to estrogen plus progestin had an increased risk of pulmonary embolism (1.0% vs. 0.5%; HR, 1.98 [95% CI, 1.36 to 2.87]) and deep vein thrombosis (1.4% vs. 0.8%; HR, 1.87 [95% CI, 1.37 to 2.54]) compared with women in the placebo group over a median followup of 5.6 years.^89, 102^ The groups did not differ for risk of deep vein thrombosis or pulmonary embolism during the 2.4-year postintervention period after women stopped therapy.^92^

In three smaller trials (N=142 to 777), groups did not differ in risk of venous thromboembolism among participants randomized to estrogen plus progestin or placebo over 2 to 3 years (2 vs. 0 events across all three trials).^59, 61, 62^

##### Differences in Treatment Effects Based on Subgroups

In the WHI, risk of pulmonary embolism or deep vein thrombosis did not differ for the treatment and placebo groups by subgroups based on age.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of venous thromboembolism in the WHI was similar for women who began hormone therapy soon after menopause (<5 years) and for those who started later (≥5 years).^98^

#### Health-Related Quality of Life

##### Benefits and Harms of Hormone Therapy

The WHI (N=16,608)^102^ was the only trial that reported on health-related quality of life (Appendix G Table 15). It used the RAND-36 form, which assesses physical functioning, physical role, bodily pain, general health, vitality, social functioning, emotional role, and mental health. Women in both groups had similar scores on all items except for physical functioning (p<0.001), physical role (p=0.02), bodily pain (p<0.001), and general health (p=0.02), for which women taking hormone therapy had statistically significantly better scores than did women taking placebo.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### All-Cause Mortality

##### Benefits and Harms of Hormone Therapy

Three trials (ERA [N=209],^62^ HERS [N=2,763],^68^ and WHI [N=16,608]^92^) provided information about the risk of death from any cause (i.e., all-cause mortality) among 19,580 women with treatment of estrogen plus progestin (Appendix G Table 16). The average length of treatment for these trials ranged from 3.2 to 5.6 years (weighted mean, 5.2 years).^62, 68, 92^ A meta-analysis of these trials yielded no statistically significant difference in all-cause mortality between women taking hormone therapy or placebo (RR, 1.01 [95% CI, 0.88 to 1.17]).

The WHI, the largest of the three trials, reported an HR of 0.97 (95% CI, 0.81 to 1.16); 2.9 percent of women in both treatment groups died.^92^ The risk of death among women who had received estrogen plus progestin and those who had received placebo at followup 2.4 years after stopping hormone therapy was not significantly different (HR, 1.15 [95% CI, 0.95 to 1.39]).^92^ However, when the analysis focused on women in the postintervention phase without prior hormone therapy use who adhered to medication (took ≥80% of study pills), the difference in risk of death was statistically significant (HR, 1.53 [95% CI, 1.04 to 2.24]).^92^

Risk of death from breast cancer (HR, 1.96 [95% CI, 1.00 to 4.04])^84^ and lung cancer (HR, 1.71 [95% CI, 1.16 to 2.52])^86^ was higher among women randomized to estrogen plus progestin than among those taking placebo 2.4 years after stopping hormone therapy.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

An analysis of WHI data considered the time between menopause and the first use of hormone therapy (before enrollment into the WHI).^98^ The effect of estrogen plus progestin on all-cause mortality did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who started it after 5 years following menopause.