# Chapter 2 Methods

The methods for this review follow the guidance provided in the USPSTF Procedure Manual.^38^

## Key Questions and Analytic Framework

The investigators, USPSTF members, and AHRQ Medical Officers developed the scope, Key Questions (KQs), and analytic framework (Figure 1) that guided our literature search and review. Specifically, the KQs are:

1. What are the benefits of menopausal hormone therapy when used for the primary prevention of chronic conditions?
2. What are the harms of menopausal hormone therapy when used for the primary prevention of chronic conditions?
3. Do the benefits and harms of menopausal hormone therapy differ by subgroup (race/ethnicity; women with premature menopause; women with surgical menopause; age during hormone therapy use; duration of use; type, dose, and mode of delivery of hormone therapy; and presence of comorbid conditions) or by timing of intervention (initiation of hormone therapy during perimenopause vs. postmenopause)?

Figure 1 Analytic Framework

a Definitions of perimenopausal and postmenopausal women are based on STRAW+ 10 criteria ( Harlow SD, Gass M, Hall JE, . Executive summary of the Stages of Reproductive Aging Workshop +10: addressing the unfinished agenda of staging reproductive aging. Menopause. 2012;19(4):387-95.)22343510 .

Abbreviation: KQ=key question

Figure 1 is the analytic framework. It begins on the left with the population of interest: peri- and postmenopausal women. To the right is an overarching arrow for the framework representing KQs 1 and 3. It begins with the interventions of “hormone therapy: estrogen or estrogen/progestin” on the left and ends with a box on the far right that represents the final outcomes, “improved health outcomes” and “reduction in mortality.” A second horizontal arrow leads straight from the right side of the text “perimenopausal and postmenopausal women” to the center of the framework, representing “intermediate outcomes,” and continues as a dotted arrow to the same final health outcomes box mentioned above. From the arrow leading to intermediate outcomes a third squiggly arrow descends to an oval circle with the text “adverse effects” to illustrate the focus of KQ2 and KQ3.

We will also answer the following contextual questions:

1. What is the average treatment duration of hormone therapy in women who initiate its use for the treatment of menopausal symptoms?
2. Does the use of hormone therapy differ by subgroup?

Appendix A documents our various search strategies; Appendix B lists the inclusion and exclusion criteria based on relevant populations, interventions, comparators, outcomes, timing, and settings (PICOTS) and other elements such as study designs; Appendix C gives the criteria for rating the quality of RCTs according to the USPSTF approach; Appendix D is the flowchart for the literature review, based on PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) guidance; Appendix E lists all studies excluded at the full-text review stage; Appendix F documents our critical appraisal decisions, specifically the ratings for each domain of the quality ratings for each trial; Appendix G includes outcome-specific tables containing all data reported for a given outcome from the included trials used for our main analyses; and Appendix H includes forest plots for outcomes with sufficient data to complete meta-analysis.

## Search Strategies

We searched MEDLINE® (via PubMed), the Cochrane Library, Embase, and International Pharmaceutical Abstracts for English-language articles published from June 1, 2011, through August 1, 2016. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant PICOTS elements. Appendix A describes all the search strategies.

We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, HSRProj, the World Health Organization's International Clinical Trials Registry Platform, NIH RePORTER, and Drugs@FDA.gov. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. We also manually reviewed all literature suggested by peer reviewers or public comment respondents and, if appropriate, incorporated it into the final review.

Between August 2016 and August 2017, we conducted ongoing surveillance through article alerts and targeted searches of high-impact journals to ensure inclusion of major studies affecting the conclusions or understanding of the evidence and the related USPSTF recommendation.

## Study Selection

We selected hormone therapy studies on the basis of inclusion and exclusion criteria developed for each KQ based on the PICOTS approach and other elements such as study designs. The basic criteria are described below, and Appendix B provides more details. We imported all citations identified through searches and other sources into EndNote Version 7 (Clarivate Analytics, Philadelphia).

Two investigators independently reviewed titles and abstracts. We then dually and independently reviewed the full text of all articles that either reviewer marked for potential inclusion. We resolved disagreements by discussion and consensus; if necessary, we sought adjudication of conflicts from other experienced members of the review team. Appendix E lists studies that we excluded at the full-text review stage.

In addition to the searches for the updated literature, we incorporated all included citations from the previous report, which covered the publication period of January 2002 through November 2011.^39^ Additionally, to ensure that our update was cumulative of all relevant evidence, we reviewed all included citations from three recent systematic reviews^19, 40, 41^ and included all relevant citations that met our criteria for fair or good quality.

### Populations

We included studies of generally healthy perimenopausal and postmenopausal women who were eligible for hormone therapy. Women with and without menopausal symptoms were included if the focus of the analysis was either on the primary prevention of chronic conditions or on the harms of hormone therapy. In some cases, we included studies that may have had populations for which hormone therapy use was intended for secondary prevention (e.g., for slowing the progression of coronary artery atherosclerosis). We excluded postmenopausal women with contraindications for hormone therapy use.

### Interventions

We searched for studies that examined the use of systemic therapy with estrogen-only formulations or combination preparations of estrogen plus progestin for the primary prevention of chronic conditions. We limited our evaluation to medications that have been approved by the U.S. Food and Drug Administration for this purpose and that are available for use in the United States. Table 1 lists the drugs in these two classes by generic name and gives the brand names, the type of product (i.e., patch, pill, or injection), and information on dosage. We focused our analysis on studies that present the effect of the intervention by type of hormone therapy (i.e., estrogen only or estrogen plus progestin). We included studies that do not differentiate between type of hormone therapy in the evidence tables, but we do not discuss them in detail in the results.

### Comparators

We included placebo-controlled trials and studies with inactive treatments as a comparator.

### Outcomes

Because of the main focus on primary prevention of chronic conditions, we included trials that measured various metrics for the following array of such diagnoses or events: several types of cancer (breast, cervical, endometrial, ovarian, colorectal, and lung), coronary heart disease, stroke, and thromboembolism. We also included trials that assessed cognitive functioning and dementia, diabetes (new diagnoses requiring medication), fractures, gallbladder disease (cholecystitis and cholelithiasis), and urinary incontinence (stress, urge, and overall). Finally, we included studies that measured all-cause mortality. If we encountered studies on the secondary prevention of, for instance, myocardial infarction, we still included them for other primary outcomes (e.g., fractures) but not for the specific secondary prevention target.

With respect to harms, we sought information on adverse events, unanticipated negative consequences, or side effects attributable to hormone therapy.

Our analysis prioritized outcomes that were prespecified. We generally do not present the full results for multiple measures of a single construct (e.g., for cognitive function), unless the results were statistically significant. We also elected to prioritize individual rather than composite outcomes, when both were available.

### Timing

We searched for studies that reported on outcomes of 1 year or more of hormone therapy for the outcomes outlined above (duration of the intervention). We also evaluated the effect of the timing of the intervention relative to menopause when such data were available but did not base inclusion or exclusion decisions on this criterion.

### Settings

For all KQs, we included trials conducted in all primary care or primary care–like settings but not in inpatient, hormone specialist, or institutional settings such as nursing homes or similar facilities. With respect to geography, we searched for studies conducted in the United States or in countries designated by the United Nations Development Programme as having a very high Human Development Index.^42^

### Study Designs

In our searches, we included the following study designs: RCTs, controlled trials, and systematic reviews. We also included large controlled cohort studies (>10,000 women) for outcomes for which we had no evidence from trials or systematic reviews. We included data from long-term followup studies of trials if they provided information on how elevated or reduced risk changed after women had stopped hormone therapy. We present these findings in the context of results from the randomized trials.

Because we had sufficient evidence from randomized trials, we did not use any observational studies to address the KQs. Systematic reviews were used only to identify studies (from their reference lists) that we might otherwise have missed.

## Data Abstraction and Quality Rating

We abstracted pertinent information from each included study; details included methods and the PICOTS elements. A second investigator checked all data abstractions for completeness and accuracy. We resolved differences by consensus or adjudication by a third senior investigator.

Using predefined criteria developed by the USPSTF, two investigators independently assessed the quality of each study as good, fair, or poor.^43^ The USPSTF criteria are listed in Appendix C; Appendix F lists our ratings for each domain for each eligible study. Disagreements were resolved by discussion and consensus. We rated trials with fatal flaws as poor quality (i.e., high risk of bias). Fatal flaws that resulted in poor-quality ratings included initially assembled groups that were not close to being comparable or were not maintained throughout the study, overall attrition of at least 20 percent or differential attrition of at least 15 percentage points between groups, and use of unreliable or invalid measurement instruments or unequal application among groups (including not masking outcome assessment). For RCTs, the lack of intention-to-treat analysis was also a reason for rating a trial as poor quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular or narrative format. To determine whether meta-analyses were appropriate, we assessed both the number of trials available and their clinical and methodological heterogeneity following established guidance.^44^ To do this, we qualitatively assessed the populations, similarities and differences in treatments used, and similarities in outcomes and timing of outcomes assessed.

When at least three similar trials were available, we conducted quantitative synthesis of studies with random-effects models using the inverse-variance weighted method (DerSimonian and Laird).^45^

For all quantitative syntheses, we calculated the chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates attributable to heterogeneity rather than due to chance) to assess statistical heterogeneity in effects between studies.^46, 47^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.^48^ The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence (SOE) for heterogeneity (e.g., p-value from the chi-squared test or a confidence interval [CI] for I^2^). However, as precision and the number of subjects increase, I^2^ may become inflated toward 100 percent and may not reflect clinically relevant heterogeneity.^49^

We conducted all the quantitative analyses using Comprehensive Meta-Analysis Version 3 (Biostat, Englewood, NJ).

We rated the SOE for each major outcome for each KQ using the domains set out in the AHRQ guidance:^50^ study limitations,^51^ consistency,^52^ precision,^53^ directness,^54^ and reporting bias.^55^ We also considered other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, and strength of association (magnitude of effect).^56^

Two reviewers assessed each SOE domain for each key outcome and developed the overall SOE grades. The reviewers were two senior members of the review team (including at least one subject matter expert and one methodologist); they resolved any differences by consensus discussion.

SOE grades reflect the confidence that the reviewers have that various estimates of effect are close to true effects with respect to the KQs in a systematic review. A high grade indicates confidence that the estimate of effect lies close to the true effect for this outcome, the body of evidence has few or no deficiencies, and the findings are stable. A moderate grade suggests that although the estimate of effect lies close to the true effect for this outcome, the body of evidence has some deficiencies, and some doubt persists as to the stability of the findings. A low grade suggests limited confidence about the estimate of effect, with the need for additional studies. Insufficient evidence means that we have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome.

## Expert Review and Public Comment

The draft analytic framework and draft research questions were made available for public comment and subsequently revised. A draft of this report was made available for public comment and reviewed by content experts, USPSTF members, and AHRQ Medical Officers. It was revised based on comments received.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.