# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2012 recommendation on use of hormone therapy for postmenopausal women to prevent chronic health conditions such as cardiovascular disease,^1^ types of cancer, and osteoporotic fractures. In 2012, the USPSTF recommended against the use of estrogen plus progestin for the prevention of chronic conditions in postmenopausal women (grade D recommendation) and against the use of estrogen for the prevention of chronic conditions in postmenopausal women who have had a hysterectomy (grade D recommendation).^1^ These recommendations do not apply to women younger than age 50 years who have had surgical menopause.

The purposes of this report are to update evidence about the benefits and harms of hormone therapy for preventing chronic conditions in postmenopausal women and to examine whether outcomes vary among women in different subgroups. Use of hormone therapy for treating women with menopausal symptoms, such as vasomotor hot flashes or vulvovaginal complaints (e.g., dryness or dyspareunia), or for other indications is outside the scope of this review.

## Condition Definition

Menopause is the cessation of the menstrual cycle and the end of a woman's reproductive years; it is defined retrospectively, 12 months after the final menstrual period.^2^ Natural menopause results from the relative depletion of ovarian follicles responsive to the gonadotropins and the consequent decline in estrogen and progesterone concentration. The Stages of Reproductive Aging Workshop describes menopause as a series of four stages along a reproductive continuum.^3^ Early perimenopause results from anovulatory menstrual cycles and is characterized by irregularity in menstrual cycle length and duration. Late perimenopause is marked by progressive menstrual irregularity. Early postmenopause is the interval within 4 years of the final menstrual period, and late postmenopause is 5 or more years after the final menstrual period.

In the past, menopause was viewed as a risk factor for several chronic conditions attributable primarily to two (related) bodies of evidence: 1) large observational studies showing an increased risk of chronic conditions in relationship to age at natural menopause^4, 5^ (as well as increased incidence of biomarkers associated with chronic conditions, such as elevated lipid levels^6^) and 2) observational data showing that estrogen may have a positive effect on both the incidence of chronic conditions^7, 8^ and intermediate outcomes related to the risk of chronic conditions (e.g., increase in arterial wall thickness).

“Chronic conditions” refers to common, preventable diseases and conditions treated in primary care settings. These can include heart disease, osteoporosis (and subsequent fractures), cognitive impairment, some types of cancer, and others. These conditions all have multiple risk factors, such as lack of physical activity, poor nutrition, tobacco use, and others. Before 2002, hormone therapy was believed to help prevent these conditions based on evidence from observational studies,^8, 9^ and it was commonly prescribed for primary prevention in women with and without menopausal symptoms.

## Prevalence and Burden

Natural menopause occurs at a median age of 51.3 years.^10^ Surgery (bilateral oophorectomy), chemotherapy, or radiation can induce premature menopause (defined as menopause that occurs before the age of 40 years). In the absence of a known cause (e.g., radiation), menopause before age 40 years is considered to be abnormal and is referred to as primary ovarian insufficiency.^11^ In some women, menopause is associated with its own morbidity. Approximately 85 percent of women transitioning through menopause report experiencing symptoms such as vasomotor symptoms (hot flashes, sleep disturbances, psychological symptoms [depressive symptoms, anxiety, or mood disturbances]), urogenital problems, and sexual dysfunction.^10, 12^

The prevalence and incidence of most chronic diseases increase with age, and the average U.S. woman who reaches menopause is expected to live another 30 years.^13^ However, the excess risk that can be attributed to menopause alone is uncertain for at least two reasons: 1) the hormone events associated with natural menopause and aging do not happen in isolation^12^ and 2) chronic conditions are multifactorial. The evidence supporting menopause as a risk factor for chronic disease is strongest for cardiovascular disease and osteoporosis. Currently, the American College of Cardiology/American Heart Association Guidelines^14^ recognize the postmenopausal state as a risk factor for cardiovascular disease, assigning it the same weight as male sex. However, data are conflicting on whether the type of menopause (surgical or natural) affects cardiovascular risk; in a large cohort of U.S. women (N=121,700), bilateral oophorectomy, but not natural menopause, was associated with an increased risk of cardiovascular disease.^15^

## Interventions

### Hormone Therapy

Currently, hormone therapy is approved by the U.S. Food and Drug Administration^16, 17^ only for treatment of menopausal symptoms and prevention and treatment of osteoporosis, with the advice that “estrogens and progestins should be used at the lowest doses for the shortest duration to reach treatment goals, although it is not known at what dose there may be less risk of serious side effects.”^17^ Hormone therapy includes the use of various forms, doses, and regimens of estrogen with or without progestin.^18^ Hormone therapy can be taken orally, vaginally, or intranasally or as an implant, skin patch, cream, or gel. Women who have not had a previous hysterectomy use a combination therapy of estrogen plus progestin (sometimes denoted combined hormone therapy, but hereafter in this report specified as estrogen plus progestin) to prevent endometrial proliferation and endometrial cancer, whereas women with a previous hysterectomy use only estrogen (estrogen-only hormone therapy). Products approved for use in the United States are listed in Table 1.

Table 1 Hormone Therapies Approved by the U.S. Food and Drug Administration^17,127^

Category of Hormone Therapy and Generic Name | Brand Name | Product Type | Dosage^a^
Estrogen-Only Formulations
Estradiol^b^ | Alora | Patch | 0.025–0.1 mg worn for 24 hours twice weekly
Estradiol^b^ | Climara | Patch | 0.025–0.1 mg worn for 24 hours once weekly
Estradiol^b^ | Estrace | Pill | 0.5–2 mg/day
Estradiol^b^ | Estraderm | Patch | 0.05–0.1 mg continuously or cyclically^c^
Estradiol^b^ | Menostar | Patch | 0.014 mg worn for 24 hours once weekly
Estradiol^b^ | Minivelle | Patch | 0.025–0.1 mg worn for 24 hours twice weekly
Estradiol^b^ | Vivelle | Patch | 0.0375–0.1 mg/day
Estradiol^b^ | Vivelle-Dot | Patch | 0.025–0.1 mg worn for 24 hours twice weekly
Estradiol Acetate^b^ | Femtrace | Pill | 0.45–1.8 mg/day
Esterifield Estrogen^b^ | Menest | Pill | 0.3–1.25 mg/day cyclically^c^
Estropipate^d^ | Ogen | Pill | 0.75–3 mg/day
Conjugated Estrogens^e^ | Premarin | Pill, injection | 0.3 mg/day cyclically,^c^ single 25-mg injection
Synthetic Conjugated Estrogens^f^ | Enjuvia | Pill | 0.3 mg/day
Combination Estrogen plus Progestin Formulations
Estradiol^b^ + Drospirenone^g^ | Angeliq | Pill | Drospirenone 0.25–0.5 mg/day with estradiol 0.5–1.0 mg/day
Estradiol^b^ + Norethindrone Acetate^f^ | Activella | Pill | Estradiol 0.5–1.0 mg/day with norethindrone 0.1 mg/day
Estradiol^b^ + Norgestimate^g^ | Prefest | Pill | Repeat estradiol 1 mg/day for 3 days followed by estradiol 1 mg/day with norgestimate 0.09 mg/day for 3 days
Estradiol^b^ + Levonorgestrel^g^ | Climara Pro | Patch | Estradiol 0.045 mg with levonorgestrel 0.015 mg worn for 24 hours once weekly
Estradiol^b^ + Norethindrone Acetate^g^ | Combipatch | Patch | Estradiol 0.05 mg with norethindrone 0.14–0.25 mg worn for 24 hours once weekly
Conjugated Estrogene + Medroxyprogesterone Acetate^g^ | Prempro | Pill | Conjugated estrogen 0.625 mg/day with MPA 5 mg/day
Ethinyl Estradiol^b^ + Norethindrone Acetate^f^ | Femhrt | Pill | Ethinyl estradiol 0.0025 mg/day with norethindrone acetate 0.500 mg/day

a Dosages are based on the package inserts for the brand name formulations.

b Estradiol can be from natural sources or prepared synthetically.

c Cyclically means “within a cycle” (e.g., repeat 3 weeks of treatment and 1 week off).

d Natural estrogenic substance prepared from purified crystalline estrone.

e Conjugated estrogens, such as conjugated equine estrogens, are derived wholly or partially from the urine of pregnant mares or synthetic estrone and equilin.

f Synthetic conjugated estrogens are prepared using plant sources, such as yams and soy, and use only synthetic resources.

g Synthetic progestin.

Abbreviation: MPA = medroxyprogesterone acetate.

Formulations of oral estrogen may include estradiol (derived from Mexican yam), estradiol valerate (a prodrug for estradiol), synthetic conjugated estrogen, ethinyl estradiol, or conjugated equine estrogen (derived from horse mare urine).^19^ The progestogens include synthetic derivatives of progesterone or progestins (e.g., norethindrone, norethindrone acetate, levornorgstrel, drosperinone, norgestimate, and medroxyprogesterone acetate) and natural progesterones derived from plants (e.g., orally administered micronized progesterone). Natural progesterones are identical to the steroid produced by the corpus luteum.

For estrogen plus progestin therapy, progestin can be taken either every day (continuous combined therapy) or cyclically with estrogens taken daily and progestins taken for part of the month (sequentially combined hormone therapy). Progestins and natural progesterones differ in their metabolic action and risk of harms such as adverse effects on blood lipids, breast tenderness, or headaches.^19^

A recent review supported by the Agency for Healthcare Research and Quality (AHRQ) synthesized evidence from 283 randomized, controlled trials (RCTs), published through January 2014, analyzing the effectiveness of treatments for menopausal symptoms. Symptoms of interest included vasomotor, psychological, and urogenital symptoms; quality of life; sexual function; and sleep disturbance.^20^ The authors concluded that although estrogens are the most effective treatment for vasomotor symptom relief and confer the greatest improvement in quality-of-life measures, they are also associated with potential long-term harms. Potential harms of long-term hormone therapy include increased risk of venous thromboembolism, stroke, breast cancer, and other conditions. Finally, the authors concluded that compared with placebo, nonhormonal treatments show similar effects as estrogens for other common symptoms, such as psychological symptoms, urogenital symptoms, and sleep disturbance.^20^

### Current Clinical Practice

The number of women using hormone therapy has declined significantly in recent years.^21^ Between 1988 and 1994, an estimated 44 percent of postmenopausal women in the United States reported current or past use of at least one form of hormone therapy.^22^ Results from the Women's Health Initiative (WHI),^23, 24^ a large U.S.-based RCT of hormone therapy versus placebo, were first released in 2002; findings indicated that hormone therapy use is associated with important adverse health effects. Between 2003 and 2004, use of all formulations of hormone therapy decreased to 11.9 percent among non-Hispanic white women; however, among non-Hispanic black and Hispanic women, prevalence did not decline substantially until 2005 to 2006. In 2010, the prevalence of hormone therapy use was estimated at 4.7 percent overall—2.7 percent for estrogen only and 1.7 percent for estrogen plus progestin.^25^

Despite the results of the WHI and an overall decline in hormone therapy use, current recommendations by professional societies are inconsistent. Some guidelines recommend hormone therapy for women at increased risk of osteoporosis and fracture.^26, 27^ Data also suggest that the overall net benefit of hormone therapy use may be increased for women who initiate treatment during the menopause transition or early postmenopause rather than late postmenopause. This approach is often referred to as the “timing hypothesis” (i.e., a critical window for favorable outcomes of hormone therapy treatment).^28^ The hypothesis proposes that hormone therapy given at or soon after menopause reduces the risk of cardiovascular disease but the potential beneficial effects will be attenuated or not experienced when hormone therapy is initiated several years after menopause.^29^

The timing hypothesis arose initially from data from the Framingham study, which indicated that natural menopause increases the risk of cardiovascular disease. Studies in female monkeys^30^ and large observational studies in women^8, 31, 32^ corroborated the hypothesis that early commencement of hormone therapy prevents the progression of atherosclerosis. The purported health benefits of early hormone therapy have been extended to lower mortality,^33^ reduced risk of dementia, and better cognition.^34^ Most of these claims are based on observational studies; post hoc subgroup analyses of the WHI also reported benefits of an early commencement of hormone therapy.^35^

### Summary of Guidelines From Other Groups

Several organizations have issued clinical practice guidelines related to using hormone therapy in postmenopausal women for the prevention of chronic conditions (Table 2). No current guidelines recommend the routine use of hormone therapy for primary or secondary prevention of heart disease, and most recommend against the use of hormone therapy for prevention of any chronic conditions. Both the American College of Obstetricians and Gynecologists guidelines^26^ and the American Association of Clinical Endocrinologists guidelines^27^ note that hormone therapy is approved for women at increased risk of osteoporosis and fracture. The American College of Obstetricians and Gynecologists guidelines also mention the uncertainty about whether the potential cardiovascular benefits for women may differ based on early versus late initiation of hormone therapy.^26, 36^ The North American Menopause Society guidelines^37^ focus primarily on considerations for women with symptoms; they note that the balance of potential health benefits and risks should be weighed individually for each woman.

Table 2 Clinical Practice Guidelines and Recommendations About Use of Hormone Therapy for Prevention of Chronic Conditions

Organization, Year | Recommendations
Canadian Task Force on Preventive Health Care, 2004^132^ | Recommends against the use of estrogen only and estrogen plus progestin therapy for the primary prevention of chronic diseases in menopausal women (Grade D recommendation).
American Association of Clinical Endocrinologists, 2011^133^ | Recommends against the use of menopausal hormone therapy for primary or secondary prevention of cardiovascular disease (Grade D; Best Evidence Level 1). Recommends that menopausal hormone therapy should be used for the prevention and treatment of osteoporosis within the context of the overall benefit-vs-risk analysis of each patient. Recommendations note that data from multiple randomized, controlled trials substantiate the efficacy of estrogens in preserving bone mass and, less consistently, preventing fractures, but nonhormonal therapeutic options for bone health exist (Grade A; Best Evidence Level 1). Hormone therapy for the prevention or treatment (or both) of dementia is not recommended (Grade D; Best Evidence Level 1). Recommendations note that menopausal hormone therapy should be prescribed to women in conjunction with a thorough discussion of the possible relationship between menopausal hormone therapy and breast cancer. Guidelines note that current evidence suggests that combination estrogen and progestational agent regimens are associated with a possible higher risk of breast cancer than is therapy with estrogen alone (Grade A; Best Evidence Level 1). Concordant with current FDA warnings, recommends that women who are at increased risk of thromboembolic disease should not take estrogen-containing therapy while noting that there is evidence that transdermal estradiol may not increase this risk (Grade D; Best Evidence Level 1).
American Heart Association, 2011^134^ | Recommends against the use of hormone therapy and selective estrogen-receptor modulators for primary and secondary prevention of cardiovascular disease in women (Class III, Level of Evidence A).
American Academy of Family Physicians, 2012^135^ | Recommends against the use of estrogen plus progestin for the prevention of chronic conditions in postmenopausal women (Grade: D recommendation). Recommends against the use of estrogen for the prevention of chronic conditions in postmenopausal women who have had a hysterectomy (Grade: D recommendation).
American College of Obstetricians and Gynecologists, 2013–2014^36^ | Recommends against the use of menopausal hormone therapy for primary and secondary prevention of coronary heart disease because of insufficient evidence for benefit. The guidelines also note the following consideration: Recent evidence suggests that women in early menopause who are in good cardiovascular health and are at low risk of adverse cardiovascular outcomes should be considered candidates for the use of estrogen therapy or conjugated equine estrogen plus a progestin for relief of menopausal symptoms. There is some evidence that lends support to the “timing hypothesis,” which posits that cardiovascular benefit may be derived when estrogen therapy or hormone therapy is used close to the onset of menopause, but the relationship of duration of therapy to cardiovascular outcomes awaits further study. Hormone therapy (i.e., estrogen only or estrogen plus progestin) positively affects bone health; it is approved for use in women with an increased risk of osteoporosis^136^ and fracture.
American College of Physicians, 2015^137^ | Recommends the U.S. Preventive Services Task Force Web site and the North American Menopause Society^138^ guidelines.

Abbreviation: FDA = U.S. Food and Drug Administration.