# Appendix H Forest Plots of Meta-Analyses

Appendix H Figure 1 Forest Plot of Meta-Analyses: Estrogen Only, Coronary Heart Disease

Abbreviations: CI = confidence interval; EPAT = Estrogen in the Prevention of Atherosclerosis Trial; HT = hormone therapy; PEPI = Postmenopausal Estrogen/Progestin Interventions; WHI = Women's Health Initiative.

Appendix H Figure 1 displays a forest plot of the relative risks of developing coronary heart disease after receiving estrogen-only therapy vs. placebo in 3 trials. The relative risk was 0.95 with a 95% confidence interval of 0.78 to 1.14 in the WHI II trial. The relative risk was 0.50 with a 95% confidence interval of 0.05 to 5.43 in the EPAT trial. The relative risk was 2.98 with a 95% confidence interval of 0.12 to 72.72 in the PEPI trial. Meta-analysis of these 3 trials resulted in a relative risk of 0.95 with a 95% confidence interval of 0.79 to 1.14.

Appendix H Figure 2 Forest Plot of Meta-Analyses: Estrogen Only, All-Cause Mortality

Abbreviations: CI = confidence interval; ERA = Estrogen Replacement and Atherosclerosis Study; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HT = hormone therapy; WHI = Women's Health Initiative.

Appendix H Figure 2 displays a forest plot of the relative risks of dying after receiving estrogen-only therapy vs. placebo in 3 trials. The relative risk was 1.03 with a 95% confidence interval of 0.88 to 1.21 in the WHI II trial. The relative risk was 0.81 with a 95% confidence interval of 0.51 to 1.27 in the ESPRIT trial. The relative risk was 1.40 with a 95% confidence interval of 0.50 to 3.89 in the ERA trial. Meta-analysis of these 3 trials resulted in a relative risk of 1.01 with a 95% confidence interval of 0.88 to 1.17.

Appendix H Figure 3 Forest Plot of Meta-Analyses: Estrogen Plus Progestin, Coronary Heart Disease

Abbreviations: CI = confidence interval; EMS = Estrogen Memory Study; EPHT = Estonian Postmenopausal Hormone Therapy Trial; HT = hormone therapy; PEPI = Postmenopausal Estrogen/Progestin Interventions; WHI = Women's Health Initiative.

Appendix H Figure 3 displays a forest plot of the relative risks of developing coronary heart disease after receiving estrogen plus progestin therapy vs. placebo in 3 trials. The relative risk was 1.22 with a 95% confidence interval of 0.98 to 1.51 in the WHI I trial. The relative risk was 2.92 with a 95% confidence interval of 0.16 to 53.96 in the PEPI trial. The relative risk was 4.62 with a 95% confidence interval of 0.22 to 95.86 in the EPHT trial. Meta-analysis of these 3 trials resulted in a relative risk of 1.23 with a 95% confidence interval of 1.00 to 1.52.

Appendix H Figure 4 Forest Plot of Meta-Analyses: Estrogen Plus Progestin, Fractures

Abbreviations: CI = confidence interval; EMS = Estrogen Memory Study; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ERA = Estrogen Replacement and Atherosclerosis Study; HERS = Heart and Estrogen Replacement Study; HT = hormone therapy; WHI = Women's Health Initiative.

Appendix H Figure 4 displays a forest plot of the relative risks of experiencing a fracture after receiving estrogen plus progestin therapy vs. placebo in 5 trials. The relative risk was 0.47 with a 95% confidence interval of 0.20 to 1.11 in the ERA trial. The relative risk was 0.34 with a 95% confidence interval of 0.01 to 8.27 in the EMS trial. The relative risk was 0.55 with a 95% confidence interval of 0.30 to 1.03 in the EPHT trial. The relative risk was 0.95 with a 95% confidence interval of 0.76 to 1.18 in the HERS I trial. The relative risk was 0.78 with a 95% confidence interval of 0.71 to 0.86 in the WHI trial. Meta-analysis of these 5 trials resulted in a relative risk of 0.80 with a 95% confidence interval of 0.68 to 0.94.

Appendix H Figure 5 Forest Plot of Meta-Analyses: Estrogen Plus Progestin, All-Cause Mortality

Abbreviations: CI = confidence interval; ERA = Estrogen Replacement and Atherosclerosis Study; HERS = Heart and Estrogen Replacement Study; HT = hormone therapy; WHI = Women's Health Initiative.

Appendix H Figure 5 displays a forest plot of the relative risks of dying after receiving estrogen plus progestin therapy vs. placebo in 3 trials. The relative risk was 1.00 with a 95% confidence interval 0.84 to 1.19 in the WHI I trial. The relative risk as 1.07 with a 95% confidence interval of 0.84 to 1.35 in the HERS trial. The relative risk was 0.50 with a 95% confidence interval of 0.13 to 1.97 in the ERA trial. Meta-analysis of these 3 trials resulted in a relative risk of 1.01 with a 95% confidence interval of 0.88 to 1.17.