# Appendix G Data on Outcomes for All Trials Reporting on That Outcome

Appendix G Table 1 Evidence Table of Trials Reporting Incidence of Breast Cancer

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EPAT Estrogen-only trial Hodis, 2001^60^ | 111 Estrogen 111 Placebo | [underlined: Followup: 2 years] Breast cancer 0 vs. 1
EPHT Estrogen plus progestin trial Veerus, 2006^61^ | 404 Estrogen plus progestin 373 Placebo | [underlined: Followup: Mean 3.4 years] Breast Cancer 1 vs. 2; HR, 0.55 (95% CI, 0.05 to 6.06)
ERA Estrogen-only and estrogen plus progestin trial Herrington, 2000^62^ | 100 Estrogen alone 104 Estrogen plus progestin 105 Placebo | [underlined: Followup: Mean 3.2 years] Breast cancer (not defined) 1 vs. 0 vs. 0; p=0.35
ESPRIT Estrogen-only trial Cherry (ESPRIT Team), 2002^63^; Cherry, 2014^64^ | 513 Estrogen^b^ 504 Placebo | [underlined: Followup: 2 years]^63^ Any breast cancer (measured via ICD codes) 4 (0.8%) vs. 4 (0.8%); RR, 0.98 (95% CI, 0.25 to 3.91); p=1.00 [underlined: Cumulative followup: Mean 12.6 years]^c64^ Any breast cancer (measured via ICD codes) HR, 0.47 (95% CI, 0.19 to 1.15)
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 66 Estrogen 121 Estrogen plus progestin 186 Placebo | [underlined: Followup: 3 years] Breast Cancer Analysis did not stratify by treatment regimen 2 (hormone therapy) vs. 2; p=1.0
HERS Estrogen plus progestin trial Hulley, 2002^68^ | 1380 Estrogen plus progestin 1383 Placebo Cumulative followup: 1156 Estrogen plus progestin 1383 Placebo | [underlined: Followup: 4.1 years] 34 (2.5%) vs. 25 (1.8%); HR, 1.38 (95% CI, 0.82 to 2.31); p=0.22 [underlined: Followup: Mean 2.7 years postintervention] HR, 1.08 (95% CI, 0.52 to 2.24); p=0.83 [underlined: Cumulative followup: 6.8 years] HR, 1.27 (95% CI, 0.84 to 1.94); p=0.26
PEPI Estrogen-only and estrogen plus progestin trial Writing Group for PEPI trial, 1995^74^ | 175 Estrogen 174 Estrogen plus progestin (cyclic) 174 Estrogen plus progestin (continuous) 178 Estrogen plus progestin (micronized) 174 Placebo | [underlined: Followup: 3 years] Breast cancer 1 (estrogen) vs. 2 (estrogen plus progestin) vs. 4 (estrogen plus micronized progestin) vs. 1 (placebo); p=0.29
STOP-IT Estrogen-only and estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Breast cancer (not defined) Analysis did not stratify by treatment regimen 0 (hormone therapy with or without calcitriol) vs. 4 (calcitriol only and placebo)
WAVE Estrogen-only and estrogen plus progestin trial Waters, 2002^80^ | 124 Estrogen 86 Estrogen plus progestin 213 Placebo | [underlined: Followup: Mean 2.8 years] Breast Cancer (any) Analysis did not stratify by treatment regimen 3 vs. 1; p=0.37
WHI Estrogen-only trial Anderson, 2004;^24^ Anderson, 2012;^105^ LaCroix, 2011^112^; Prentice 2009^98^; Manson, 2013^102^; Chlebowski, 2015^104^ | 5,310 Estrogen 5,429 Placebo Postintervention extension followup: 3,778 Estrogen 3,867 Placebo | [underlined: Followup: Median 7.2 years]^102, 112^ Invasive breast cancer 104 (2.0%) vs. 135 (2.5%); HR, 0.79 (95% CI, 0.61 to 1.02); p=0.07 Subgroups: No significant difference by age at randomization^102^ Biennial analysis (2, 4, 6, and 8 years since randomization)^104^ P=0.29 for trend^104^ Risk for invasive breast cancer based on timing of intervention:^98^ No significant association; p=0.20 for gap time interaction [underlined: Followup: Median 6.6 years postintervention and postintervention extension]^102^ Invasive breast cancer HR, 0.80 (95% CI, 0.58 to 1.11); p=0.19 [underlined: Cumulative followup: Median 13.0 years]^102^ Invasive breast cancer HR, 0.79 (95% CI, 0.65 to 0.97); p=0.02
WHI Estrogen plus progestin trial Writing Group for the WHI, 2002;^23^ Heiss, 2008;^92^ Chlebowski, 2003;^85^ Chlebowski, 2010;^84^ Gramling, 2009;^90^ Prentice 2009^98^; Manson, 2013^102^; Chlebowski, 2015^104^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention extension followup: 6,545 Estrogen plus progestin 6,243 Placebo | [underlined: Followup: Median 5.6 years]^102^ Invasive breast cancer 206 (2.4%) vs. 155 (1.9%); HR, 1.24 (95% CI, 1.01 to 1.53) Overall breast cancer mortality^84^ 25 (0.3%) vs. 12 (0.2%); HR, 1.96 (95% CI, 1.00 to 4.04); p=0.049 Subgroups: No significant difference by age^102^ Time since randomization^104^ 2 years since randomization: HR, 0.71 (95% CI, 0.47 to 1.08) 4 years since randomization: HR, 1.36 (95% CI, 0.95 to 1.94) 6 years since randomization: HR, 1.65 (1.17 to 2.32) P=0.008 for trend Risk for invasive breast cancer based on timing of intervention:^98^ Initiation of hormone therapy within 5 years of menopause: HR, 2.06 (95% CI, 1.30 to 3.27) Initiation of hormone therapy after 5 years of menopause: HR, 1.30 (95% CI, 0.57 to 2.99) P=0.03 for gap time interaction [underlined: Followup: Mean 2.4 years postintervention]^92^ Invasive breast cancer HR, 1.27 (95% CI, 0.91 to 1.78) [underlined: Followup: Median 8.2 years postintervention and postintervention extension]^102^ HR, 1.32 (95% CI, 1.08 vs. 1.61); p=0.007 [underlined: Cumulative followup: 13.2 years]^102^ HR, 1.28 (95% CI, 1.11 to 1.48); p<0.001
WISDOM Estrogen plus progestin trial Vickers, 2007^123^ | 2,196 Estrogen plus progestin 2,189 Placebo | [underlined: Followup: Mean 1 year] Breast cancer incidence 5 vs. 7 Breast cancer mortality 0 vs. 0

a Intervention dosages are listed in Table 3 by trial.

b All women enrolled in the initial trial were followed by data linkage to UK mortality and cancer records.

c At enrollment, 24% of women reported having a hysterectomy. After the 2-year intervention period, women with an intact uterus were sent a letter each year for the first 5 years after stopping treatment to remind them to seek medical attention if they experienced vaginal bleeding. No attempt was made after the end of the 2-year intervention to obtain medical information from women or their physicians about the use of medications or health events.

Abbreviations: CI = confidence interval; ERA = Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; EPAT = Estrogen in the Prevention of Atherosclerosis; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; ICD = International Classification of Diseases; PEPI = Postmenopausal Estrogen and Progestin Interventions Trial; RR = relative risk; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WAVE = Women's Angiographic Vitamin and Estrogen; WHI = Women's Health Initiative; WISDOM = Women's International Study of Long-Duration Oestrogen After Menopause.

Appendix G Table 2 Evidence Table of Trials Reporting Incidence of Cervical Cancer

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
ESPRIT Estrogen-only trial Cherry, 2014^64^ | 513 Estrogen only^b^ 504 Placebo^b^ | [underlined: Cumulative followup: Mean 12.6 years]^c^ 0 vs. 1
WHI Estrogen plus progestin trial Anderson, 2003^81^ | 8,506 Estrogen plus progestin 8,102 Placebo | [underlined: Followup: Median 5.6 years] 8 (0.09%) vs. 5 (0.06%); HR, 1.44 (95% CI, 0.47 to 4.42)

a Intervention dosages are listed in Table 3 by trial.

b At enrollment, 24% of enrolled women reported having a hysterectomy. After the 2-year intervention period, women with an intact uterus were sent a letter each year for the first 5 years after stopping treatment to remind them to seek medical attention if they experienced vaginal bleeding. No attempt was made after the end of the 2-year intervention to obtain medical information from women or their physicians about the use of medications or health events.

c Cancer incidence was determined by data linkage to UK cancer records for a mean 12.6 years after enrollment.

Abbreviations: CI = confidence interval; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HR = hazard ratio; WHI = Women's Health Initiative.

Appendix G Table 3 Evidence Table of Trials Reporting Incidence of Colorectal Cancer

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EMS Estrogen plus progestin trial Tierney, 2009^59^ | 70 Estrogen plus progestin 72 Placebo | [underlined: Followup: 2 years] 0 vs. 0
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 66 Estrogen 121 Estrogen plus progestin 186 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by treatment regimen 3 vs. 1; p=0.62
HERS Estrogen plus progestin trial Hulley, 2002^68^ | 1,380 Estrogen plus progestin 1,383 Placebo Cumulative followup: 1156 Estrogen plus progestin 1383 Placebo | [underlined: Followup: Mean 4.1 years] 11 (0.80%) vs. 16 (1.16%); HR, 0.69 (95% CI, 0.32 to 1.49); p=0.43 [underlined: Cumulative followup: Mean 6.8 years] HR, 0.81 (95% CI, 0.46 to 1.45); p=0.48
PEPI Estrogen-only and estrogen plus progestin trial Writing Group for PEPI trial, 1995^74^ | 175 Estrogen only 174 Estrogen plus progestin (cyclic) 174 Estrogen plus progestin (continuous) 178 Estrogen plus progestin (micronized) 174 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by treatment regimen 2 colon cancer cases
STOP-IT Estrogen-only and Estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by treatment regimen 1 (hormone therapy with or without calcitriol) vs. 6 (calcitriol only and placebo)
WHI Estrogen-only trial Anderson, 2004;^24^ Ritenbaugh, 2008;^113^ Prentice, 2009;^98^ LaCroix, 2011;^112^ Manson, 2013^102^ | 5,310 Estrogen only 5,429 Placebo Postintervention followup: 4,794 Estrogen only 4,872 Placebo Postintervention extension followup: 4,851 Estrogen only 4,935 Placebo | [underlined: Followup: Median 7.2 years] 65 (1.22%) vs. 58 (1.07%); HR, 1.15 (95% CI, 0.81 to 1.64); p=0.44^102^ Invasive colorectal cancer^113,b^b HR, 1.12 (95% CI, 0.77 to 1.63); p=0.55 Invasive colon cancer^113,b^b HR, 1.26 (95% CI, 0.84 to1.88); p=0.26 Invasive rectal cancer^113,b^b HR, 0.53 (95% CI, 0.18 to 1.56); p=0.25 Subgroups:^113,b^b No significant difference by race or ethnic group, bilateral oophorectomy status, family history of colorectal cancer, treated diabetes status Age at randomization^102^ Among women 50–59 years at randomization: HR, 0.71 (95% CI, 0.30 to 1.67) Among women 60–69 years at randomization: HR, 0.88 (95% CI, 0.53 to 1.47) Among women 70–79 years at randomization: HR, 2.24 (95% CI, 1.16 to 4.30) p=0.02 for trend Risk for colorectal cancer based on timing of intervention:^98^ No significant association; p for gap time interaction=0.34 [underlined: Followup: Median 6.6 years postintervention and postintervention extension]^102^ HR, 1.10 (95% CI, 0.68 to 1.78); p=0.69 [underlined: Cumulative followup: Median 13.0 years]^102^ HR, 1.13 (95% CI, 0.85 to 1.51); p=0.39 Subgroups:^102^ No significant difference by age at randomization
WHI Estrogen plus progestin trial Writing Group for the Women's Health Initiative Investigators, 2002;^23^ Chlebowski, 2004;^87^ Heiss, 2008;^92^ Prentice, 2009;^98^ Manson, 2013^102^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,060 Estrogen plus progestin 7,687 Placebo Postintervention extension followup:^e^ 6,545 Estrogen plus progestin 6,243 Placebo | [underlined: Followup: Median 5.6 years] 50 (0.59%) vs. 75 (0.93%); HR, 0.62 (95% CI, 0.43 to 0.89); p=0.009^102^ Invasive colorectal cancer^87,d^d HR, 0.56 (95% CI, 0.38 to 0.81); p=0.003 [underlined: I]nvasive colon cancer^87,d^d HR, 0.54 (95% CI, 0.36 to 0.82); p=0.004 Invasive rectal cancer^87,d^d HR, 0.66 (95% CI, 0.26 to 1.64); p=0.37 Subgroups: No significant difference by age at randomization,^102^ race or ethnic group, family history of colorectal cancer,^87, 98,d^d Risk for colorectal cancer based on timing of intervention:^98^ No significant association; p for gap time interaction=0.42 [underlined: Followup: Median 8.2 years postintervention and postintervention extension]^102^ HR, 0.97 (95% CI, 0.70 to 1.33); p=0.83 [underlined: Cumulative followup: Median 13.2 years]^102^ HR, 0.80 (95% CI, 0.63 to 1.01); p=0.06 Subgroups:^102^ No significant difference by age at randomization
WISDOM Estrogen plus progestin trial Vickers 2007^123^ | 2,196 Estrogen plus progestin^f^ 2,189 Placebo^f^ | [underlined: Followup: Median 11.9 months] 2 vs. 2

a Intervention dosages are listed in Table 3 by trial.

b The mean followup for some of these analyses (Ritenbaugh, 2008 and Prentice, 2009) was 7.1 years, suggesting that the results are based on an earlier adjudication of intervention phase data than the most recent intervention data from Manson, 2013.^102^

c Women were ineligible if they were deceased or provided no contact through the postintervention phase. By the end of the postintervention phase, 7,878/8,506 (93% of women randomized to estrogen plus progestin) and 7,530/8,102 (93% of women randomized to placebo) were eligible for the postintervention extension phase.

d The analysis was based on 122 centrally adjudicated colorectal cancers, which were diagnosed before 7/8/2002, the date participants were instructed to discontinue their study medication.

e The mean followup for this analysis was 5.5 years, suggesting that the results are based on an earlier adjudication of intervention phase data than the most recent intervention data from Manson, 2013.^102^

f The estrogen plus progestin arm includes 1,862 women with an intact uterus and 334 women with a prior hysterectomy who had agreed to be randomized to estrogen plus progestin, estrogen only, or placebo (the women randomized to estrogen only included women who agreed to placebo (n=341) and women who did not agree to placebo (n=485), so there is a selection bias that precludes us from including any results for the estrogen-only women.

Abbreviations: CI = confidence interval; EMS = Estrogen Memory Study; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; PEPI = Postmenopausal Estrogen/Progestin Interventions Trail; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WHI = Women's Health Initiative; WISDOM = Women's International Study of Long-Duration Oestrogen After Menopause.

Appendix G Table 4 Evidence Table of Trials Reporting Incidence of Endometrial Cancer

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EPAT Estrogen-only trial Hodis, 2001^60^ | 133 (60%) of enrolled women had an intact uterus 111 Estrogen only 111 Placebo | [underlined: Followup: 2 years]^b^ 0 (0.0%) vs. 0 (0.0%)
ERA Estrogen only and estrogen plus progestin trial Herrington, 2000^62^ | 120 (39%) of enrolled women had an intact uterus, including 44 (44%) women in the estrogen-only arm, 40 (38%) women in the estrogen plus progestin arm, and 36 (34%) women in the placebo arm 100 Estrogen only 104 Estrogen plus progestin 105 Placebo | [underlined: Followup: 3.2 years] 0 (0.0%) vs. 0 (0.0%) vs. 0 (0.0%)
ESPRIT Estrogen-only trial Cherry, 2002;^63^ Cherry, 2014^64^ | At enrollment, 24% of women had an intact uterus, including 373 (73%) of women in the active treatment arm^d^ 513 Estrogen only 504 Placebo | [underlined: Followup: 2 years]^63^ 0 (0.0%) vs. 0 (0.0%) [underlined: Cumulative followup: Mean 12.6 years]^64^ HR, 0.52 (95% CI, 0.05 to 5.80)
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 243 (65%) of enrolled women had an intact uterus, including 121 (65%) in the hormone therapy arm and 122 (66%) in the placebo arm. Women with an intact uterus received estrogen plus progestin; women with a hysterectomy received estrogen only. 187 Hormone therapy 186 Placebo | [underlined: Followup: 3 years] 1 vs. 0; p=1.0^d^
HERS Estrogen plus progestin trial Hulley, 2002^68^ | All enrolled women had an intact uterus 1,380 Estrogen plus progestin 1,383 Placebo Cumulative followup: 1156 Estrogen plus progestin 1383 Placebo | [underlined: Followup: Mean 4.1 years] 2 (0.14%) vs. 5 (0.36%); HR, 0.39 (95% CI, 0.08 to 2.02); p=0.26 [underlined: Cumulative followup: Mean 6.8 years] HR, 0.25 (95% CI, 0.05 to 1.18); p=0.08
PEPI Estrogen-only and estrogen plus progestin trial Writing Group for PEPI trial, 1995^74^ | Approximately 68% of women had an intact uterus; women with an intact uterus had to have a normal endometrial biopsy at baseline 175 Estrogen only 174 Estrogen plus progestin (cyclic) 174 Estrogen plus progestin (continuous) 178 Estrogen plus progestin (micronized) 174 Placebo | [underlined: Followup: 3 years] 1 (estrogen only) vs. 0 (estrogen plus progestin) vs. 0 (estrogen plus micronized progestin) vs. 0 (placebo)
STOP-IT Estrogen only and estrogen plus progestin Gallagher, 2001^75^ | 199 (41%) of enrolled women had an intact uterus; women with a prior hysterectomy who were randomized to receive estrogen plus progestin, with or without calcitriol, received estrogen only 121 Estrogen plus progestin 122 Estrogen plus progestin plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by treatment regimen 0 (hormone therapy with or without calcitriol) vs. 1 (calcitriol only or placebo)
ULTRA Estrogen-only trial Johnson, 2005^77^ | All enrolled women had an intact uterus 208 Estrogen only 209 Placebo | [underlined: Followup: 2 years] 0 (0.0%) vs. 0 (0.0%); difference, 0.0 (95% CI, -4.2 to 3.1); p=1.000^e^
WHI Estrogen plus progestin trial Writing Group for the Women's Health Initiative Investigators, 2002;^23^ Anderson, 2003;^81^ Heiss, 2008;^92^ Prentice, 2009;^98^ Chlebowski, 2010;^108^ Manson, 2013^102, 103^ | Women with an intact uterus 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,060 Estrogen plus progestin 7,687 Placebo Postintervention extension followup:^f^ 6,545 Estrogen plus progestin 6,243 Placebo | [underlined: Followup: Median 5.6 years]^102^ 27 (0.32%) vs. 30 (0.37%); HR, 0.83 (95% CI, 0.49 to 1.40); p=0.49 Subgroups:^102^ No significant difference by age at randomization [underlined: Followup: Median 8.2 years postintervention and postintervention extension]^102^ HR, 0.58 (95% CI, 0.40 to 0.86); p=0.007 [underlined: Cumulative followup: Median 13.2 years]^102^ HR, 0.67 (95% CI, 0.49 to 0.91); p=0.01 Subgroups:^102^ No significant difference by age at randomization

a Intervention dosages are listed in Table 3 by trial.

b Adverse event reporting was only among women who received uterine biopsies (30 women in the estrogen-only arm and 5 women in the placebo arm).

c Women with an intact uterus were sent an annual letter for 5 years reminding them to seek medical attention if they experienced vaginal bleeding.

d The mean followup was 5.5 years, suggesting that the results are based on an earlier adjudication of intervention phase data than the most recent intervention data from Manson, 2013.^102^

d Because women with an intact uterus received estrogen plus progestin if they were randomized to the hormone therapy arm, this woman had received estrogen plus progestin.

e Analysis focused on women with endometrial biopsy results, including 188 women in the estrogen-only arm and 177 women in the placebo arm.

f Women were ineligible if they were deceased or provided no contact through the postintervention phase. By the end of the postintervention phase, 7,878/8,506 (93% of women randomized to estrogen plus progestin) and 7,530/8,102 (93% of women randomized to placebo) were eligible for the postintervention extension phase.

Abbreviations: CI = confidence interval; EPAT = Estrogen in the Prevention of Atherosclerosis Trial; ERA = Estrogen Replacement and Atherosclerosis; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; PEPI = Postmenopausal Estrogen/Progestin Interventions Trial; STOP IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; ULTRA = Ultra-Low-Dose Transdermal Estrogen Replacement Assessment; vs. = versus; WHI = Women's Health Initiative.

Appendix G Table 5 Evidence Table of Trials Reporting Incidence of Lung Cancer

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EMS Estrogen plus progestin trial Tierney, 2009^59^ | 70 Estrogen plus progestin 72 Placebo | [underlined: Followup: 2 years] 1 vs. 0
HERS Estrogen plus progestin trial Hulley, 2002^68^ | 1,380 Estrogen plus progestin 1,383 Placebo Cumulative followup: 1156 Estrogen plus progestin 1383 Placebo | [underlined: Followup: Mean 4.1 years] 24 (1.74%) vs. 19 (1.37%); HR, 1.28 (95% CI, 0.70 to 2.33); p=0.43 [underlined: Cumulative followup: Mean 6.8 years] Unadjusted ITT: HR, 1.39 (95% CI, 0.84 to 2.28); p=0.20 Adjusted ITT: HR, 1.43 (95% CI, 0.87 to 2.37) Adjusted As-Treated: HR, 1.73 (95% CI, 0.93 to 3.21)
PEPI Estrogen-only and estrogen plus progestin trial Writing Group for PEPI trial, 1995^74^ | 175 Estrogen only 174 Estrogen plus progestin (cyclic) 174 Estrogen plus progestin (continuous) 178 Estrogen plus progestin (micronized) 174 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by treatment regimen 2 lung cancer cases
WHI Estrogen-only trial Chlebowski, 2010;^108^ Manson, 2013^102^ | 5,310 Estrogen only 5.429 Placebo Postintervention followup: 4,794 Estrogen only 4,872 Placebo Postintervention extension followup: 4,851 Estrogen only 4,935 Placebo | [underlined: Followup: Median 7.2 years]^102^ 62 (1.17 %) vs. 61 (1.12%); HR, 1.05 (95% CI, 0.74 to 1.49); p=0.79 Subgroups:^102^ No significant difference by age at randomization [underlined: Followup: Mean 7.9 years]^108^,^b^ Lung cancer HR, 1.17 (95% CI, 0.81 to 1.69); p=0.39 Non-small cell lung cancer HR, 1.10 (95% CI, 0.74 to 1.64); p=0.62 Small cell lung cancer HR, 1.57 (95% CI, 0.56 to 4.41); p=0.39 [underlined: Followup: Median 6.6 years postintervention and postintervention extension]^102^ HR, 0.90 (95% CI, 0.61 to 1.34); p=0.61 [underlined: Cumulative followup: Median 13.0 years]^102^ HR, 0.98 (95% CI, 0.75 to 1.27); p=0.87 Subgroups:^102^ No significant difference by age at randomization
WHI Estrogen plus progestin trial Chlebowski, 2009;^86^ Manson, 2013^102^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,060 Estrogen plus progestin 7,687 Placebo Postintervention extension followup:^c^ 6,545 Estrogen plus progestin 6,243 Placebo | [underlined: Followup: Median 5.6 years]^102^ 78 (0.92%) vs. 70 (0.86%); HR, 1.05 (95% CI, 0.76 to 1.45); p=0.78 Subgroups:^102^ No significant difference by age at randomization [underlined: Followup: Mean 7.9 years]^86,b^ Lung cancer HR, 1.23 (95% CI, 0.92 to 1.63); p=0.16 Nonsmall cell HR, 1.28 (95% CI, 0.94 to 1.73); p=0.12 Small cell lung cancer HR, 0.96 (95% CI, 0.44 to 2.07); p=0.91 [underlined: Followup: Median 8.2 years postintervention and postintervention extension]^102^ HR, 1.13 (95% CI, 0.86 to 1.47); p=0.38 [underlined: Cumulative followup: Median 13.2 years]^102^ HR, 1.10 (95% CI, 0.89 to 1.35); p=0.38 Subgroups:^102^ No significant difference by age at randomization

a Intervention dosages are listed in Table 3 by trial.

b Authors state ascertainment of lung cancer cases is through 3/31/2005, which is the end of the postintervention phase according to Manson^102^; this would mean these results are for trial and posttrial phases combined together.

c Women were ineligible if they were deceased or provided no contact through the postintervention phase. By the end of the postintervention phase, 7,878/8,506 (93% of women randomized to estrogen plus progestin) and 7,530/8,102 (93% of women randomized to placebo) were eligible for the postintervention extension phase.

Abbreviations: CI = confidence interval; EMS = Estrogen Memory Study; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; ITT = intention to treat; PEPI = Postmenopausal Estrogen/Progestin Interventions; WHI = Women's Health Initiative.

Appendix G Table 6 Evidence Table of Trials Reporting Incidence of Ovarian Cancer

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
ESPRIT Estrogen-only trial Cherry, 2014^64^ | 513 Estrogen only^b^ 504 Placebo^b^ | [underlined: Followup: Mean 12.6 years] 4 (0.78%) vs. 1 (0.20%); Fisher's exact test p=0.37
WHI Estrogen plus progestin trial Anderson, 2003;^81^ Manson, 2013^102^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,060 Estrogen plus progestin 7,687 Placebo Postintervention extension followup:^c^ 6,545 Estrogen plus progestin 6,243 Placebo | [underlined: Followup: Median 5.6 years]^102^ 24 (0.28%) vs.16 (0.20%); HR, 1.41 (95% CI, 0.75 to 2.66); p=0.28 Subgroups:^102^ No significant difference by age at randomization [underlined: Followup: Median 8.2 years postintervention and postintervention extension]^102^ HR, 1.12 (95% CI, 0.65 to 1.90); p=0.69 [underlined: Cumulative followup: Median 13.2 years]^102^ HR, 1.24 (95% CI, 0.83 to 1.87); p=0.30 Subgroups:^102^ Among women 50–59 years at randomization: HR, 0.55 (95% CI, 0.24 to 1.25) Among women 60–69 years at randomization: HR, 1.25 (95% CI, 0.72 to 2.18) Among women 70–79 years at randomization: HR, 3.82 (95% CI, 1.27 to 11.52) p=0.005 for trend

a Intervention dosages are listed in Table 3 by trial.

b Women were ineligible if they were deceased or provided no contact through the postintervention phase. By the end of the postintervention phase, 7,878/8,506 (93% of women randomized to estrogen plus progestin) and 7,530/8,102 (93% of women randomized to placebo) were eligible for the postintervention extension phase.

c At enrollment, 24% of women reported having a hysterectomy. After the 2-year intervention period, women with an intact uterus were sent a letter each year for the first 5 years after stopping treatment to remind them to seek medical attention if they experienced vaginal bleeding. No attempt was made after the end of 2-year intervention to obtain medical information from women or their physicians about the use of medications or health events.

Abbreviations: CI = confidence interval; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HR = hazard ratio; WHI = Women's Health Initiative.

Appendix G Table 7 Evidence Table of Trials Reporting Incidence of Coronary Heart Disease

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EMS Estrogen plus progestin trial Tierney, 2009^59^ | 70 Estrogen plus progestin 72 Placebo | [underlined: Followup: Mean 2 years] Any cardiovascular event 11 (15.7%) vs. 8 (11.1%); no statistically significant differences between groups
EPAT Estrogen-only trial Hodis,2001^60^ | 111 Estrogen 111 Placebo | [underlined: Followup: Mean 2 years] Cardiovascular events 3 (2.7%) vs. 4 (3.6%); p>0.2
EPHT Estrogen plus progestin trial Veerus, 2006^61^ | 404 Estrogen plus progestin 373 Placebo | [underlined: Followup: Mean 3.4 years] CHD 66 (16.3%) vs. 62 (16.6%); HR, 1.03 (95% CI, 0.73 to 1.46)
ERA Estrogen-only and estrogen plus progestin trial Herrington, 2000^62^ | Women with angiographically verified coronary disease 100 Estrogen 104 Estrogen plus progestin 105 Placebo | [underlined: Followup: Mean 3.2 years] Cardiovascular events 29 (29.0%) vs. 28 (26.9%) vs. 34 (32.4%); p=0.69
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 66 Estrogen 121 Estrogen plus progestin 186 Placebo | [underlined: Followup: Mean 3 years] Myocardial infarction Analysis did not stratify by treatment regimen 1 (0.5%) vs. 3 (1.6%); p=0.37
PEPI Estrogen-only and estrogen plus progestin trial Writing Group for PEPI trial, 1995^74^ | 175 Estrogen only 174 Estrogen plus progestin (cyclic) 174 Estrogen plus progestin (continuous) 178 Estrogen plus progestin (micronized) 174 Placebo | [underlined: Followup: Mean 3 years] CHD 1 (estrogen: 0.6%) vs. 1 (estrogen plus progestin: 0.3%) vs. 3 (estrogen plus micronized progestin: 1.7%) vs. 0 (placebo); p=0.29
STOP-IT Estrogen-only and estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: Mean 3 years] Cardiovascular events Analysis did not stratify by treatment regimen 8 (hormone therapy with or without calcitriol: 3.3%) vs. 7 (calcitriol only or placebo: 2.8%)
WAVE Estrogen-only and estrogen plus progestin trial Waters, 2002^80^ | Women with a coronary stenosis of 15%–75% 124 Estrogen (with or without vitamin C and E) 86 Estrogen plus progestin (with or without vitamin C and E) 213 Placebo (with or without vitamin C and E) | [underlined: Followup: Mean 2.8 years] Nonfatal myocardial infarction or cardiovascular death Analysis did not stratify by treatment regimen 18 (8.6%) vs. 12 (5.6%)
WHI Estrogen-only trial Anderson, 2004;^24^ Manson, 2003;^96^ Rossouw, 2007;^35^ Hsia, 2006;^111^ Prentice 2009;^98^ LaCroix, 2011;^112^ Manson, 2013^102^ | 5,310 Estrogen 5,429 Placebo Postintervention followup: 3,778 Estrogen 3,867 Placebo | [underlined: Followup: Mean 7.1 years] Overall CHD (nonfatal myocardial infarction, death due to CHD)^111^ 201 (3.8%) vs. 217 (4.0%); HR, 0.95 (95% CI, 0.79 to 1.16) Subgroups:^111,102^ No significant difference by race or ethnic group, age, years since bilateral oophorectomy, hypertension, diabetes, high cholesterol requiring medication, coronary risk factors, CVD at baseline, or CHD at baseline Younger women had a lower risk for myocardial infarction than older women relative to placebo (p=0.02) ^102^ Risk for CHD based on timing of intervention: No significant association; p=0.40 for gap time interaction^98^ No significant association; p=0.16 for trend^102^ [underlined: Followup: Mean 3.9 years postintervention]^112^ Overall CHD (nonfatal myocardial infarction, death due to CHD) HR, 0.97 (95% CI, 0.75 to 1.25)
WHI Estrogen plus progestin trial Writing Group for the WHI, 2002;^23^ Manson, 2003;^96^ Rossouw, 2007;^35^ Heiss, 2008;^92^ Prentice 2009;^98^ Manson, 2013^102^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,052 Estrogen plus progestin 7,678 Placebo | [underlined: Followup: Mean 5.2 years]^102^ Overall CHD (nonfatal myocardial infarction, death due to CHD) 196 (2.0%) vs. 159 (2.0%); HR, 1.18 (95% CI, 0.95 to 1.45) Nonfatal myocardial infarction 151 (1.8%) vs. 114 (1.4%); HR, 1.28 (95% CI, 1.00 to 1.63) CHD death 39 (0.5%) vs. 34 (0.4%); HR, 1.10 (95% CI, 0.70 to 1.75) Subgroups:^96, 102^ No significant difference by race or ethnic group, age, hypertension, diabetes, CVD at baseline, or CHD at baseline Risk based on timing of intervention: Overall CHD No significant association; p=0.42 for gap time interaction^98^ No significant association; p=0.08 for trend^102^ Nonfatal myocardial infarction^102^ <10 years after menopause: HR, 0.91 10–<20 years after menopause: HR, 1.16 ≥20 years after menopause: HR, 1.99 p=0.01 for trend [underlined: Followup: Mean 2.4 years postintervention]^92^ Overall CHD HR, 1.04 (95% CI, 0.89 to 1.21)
WISDOM Estrogen plus progestin trial Vickers, 2007^123^ | 826 Estrogen 2,196 Estrogen plus progestin 2,189 Placebo | [underlined: Followup: Mean 1 year] Cardiovascular events 2 (0.2%) vs. 7 (0.3%) vs. 0 (0.0%); p=0.016

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; DOPS = Danish Osteoporosis Prevention Study; EMS = Estrogen Memory Study; EPAT = Estrogen in the Prevention of Atherosclerosis Trial; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ERA = Estrogen Replacement and Atherosclerosis; HR = hazard ratio; PEPI = Postmenopausal Estrogen/Progestin Interventions Trial; RR = relative risk; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WHI = Women's Health Initiative; WISDOM = Women's International Study of Long Duration Oestrogen After Menopause.

Appendix G Table 8 Evidence Table of Trials Reporting Incidence of Cognitive Function and Dementia

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
Study Author, Year | Population | PD Incidence | MCI Incidence | Other Dementia Diagnosis Outcomes | 3MS Scores | Other Measures
EMS Estrogen plus progestin trial Tierney, 2009^59^ | Women with normal to just below normal scores on cognitive battery tests, but free of dementia: 70 Estrogen plus progestin 72 Placebo | NR | NR | NR | NR | [underlined: Followup: 1 year] CVLT short-delay verbal recall p=0.15 [underlined: Followup: 2 years] CVLT short-delay verbal recall p=0.11
HERS Estrogen plus progestin trial Grady, 2002^72^ | 662 Estrogen plus progestin 666 Placebo | NR | NR | NR | [underlined: Followup: 4.2 years] 93.1 (SD, 6.4) vs. 93.4 (SD, 6.4); difference, -0.4 (95% CI, -1.1 to 0.4); p=0.36 | [underlined: Followup: 4.2 years] Verbal fluency 15.9 (SD, 4.8) vs. 16.6 (SD, 4.8); difference, -0.7 (95% CI, -1.3 to -0.1); p=0.02 No other differences between groups for Boston Naming, Word List Memory, Word List Recall, or Trials B
KEEPS-Cog Estrogen plus progestin trial Gleason, 2015^73^ | 431 Estrogen plus progestin 262 Placebo | NR | NR | NR | [underlined: Followup: 4 years] Oral estrogen Beta estimate, 1.02 × 10-^2^ (95% CI, -4.45 × 10-^3^ to 2.48 × 10-^2^); p=0.178 Transdermal estrogen Beta estimate, -9.40 × 10-^4^ (95% CI, -1.57 × 10-^2^ to 1.38 × 10-^2^); p=0.840 | NR
ULTRA Estrogen-only trial Yaffe, 2006^79^ | 417 Enrolled 208 Estrogen 209 Placebo | NR | NR | NR | [underlined: Followup: 2 years] Baseline 3MS ≤90: 5.90 vs. 7.10; difference, -1.21 (95% CI, -5.05 to 2.64); p=0.53 Baseline 3MS >90: 0.57 vs. 0.87; difference, -0.30 (95% CI, -0.74 to 0.14); p=0.18 | [underlined: Followup: 2 years] No differences between groups on Logical Memory, Brief Visuospatial Memory Test, Word List, Trails B, Modified Boston Naming Test, Verbal Fluency
WHIMS Estrogen-only trial Shumaker, 2004,^117^ Espeland, 2004^115^ | Women without probable dementia Dementia outcomes, WHI:^117^ 1,464 Estrogen 1,483 Placebo General cognitive function, enrolled in WHIMS >6 months after initiation of assigned WHI therapy and with >1 postrandom-ization 3MS score:^115^ 1,387 Estrogen 1,421 Placebo Subgroup analysis: 1,464 Estrogen 1,483 Placebo | [underlined: Followup: 5.2 years]^117^ 28 (1.9%) vs. 19 (1.3%); cumulative HR, 1.49 (95% CI, 0.83 to 2.66); p=0.18 Subgroups:^117^ No difference in the hazard rate for probable dementia by race or history of cardiovascular disease, diabetes, hypertension, or stroke | [underlined: Followup: 5.2 years]^117^ 76 (5.2%) vs. 58 (3.9%); cumulative HR, 1.34 (95% CI, 0.95 to 1.89); p=NS | [underlined: Followup: 5.2 years]^117^ PD or MCI: 93 (6.4%) vs. 69 (4.7%); cumulative HR, 1.38 (95% CI, 1.01 to 1.89); p=0.04 | [underlined: Followup: Mean 5.4 years]^115^ Mean difference in change from baseline, -0.26 (95% CI, -0.52 to 0.00); p=0.04 | NR
WHIMS Estrogen plus progestin trial Shumaker, 2003;^118^ Shumaker, 2004;^117^ Rapp, 2003;^116^ Espeland, 2004^115^ | Women without probable dementia Dementia and cognitive impairment outcomes:^118^ 2,229 Estrogen plus progestin 2,303 Placebo Cognitive function outcomes:^115^ 2,131 Estrogen plus progestin 2,213 Placebo | [underlined: Followup: ∼4 years]^118^ 40 (1.8%) vs. 21 (0.9%); cumulative HR, 2.05 (95% CI, 1.21 to 3.48); p=0.01 Subgroups:^118^ No difference in the hazard rate for probable dementia by race or history of cardiovascular disease, diabetes, hypertension, or stroke | [underlined: Followup: ∼4 years]^118^ 56 (2.5%) vs. 55 (2.4%); cumulative HR, 1.07 (95% CI, 0.74 to 1.55); p=0.72 | [underlined: Followup: ∼4 years]^118^ PD or MCI: 85 (3.8%) vs. 66 (2.9%); cumulative HR, 1.37 (95% CI, 0.99 to1.89) | [underlined: Followup: 5.4 years]^115^ Mean difference in change from baseline, -0.18 (95% CI, -0.37 to 0.00); p=0.055 Subgroups:^116^ No difference in the rate of change by race, length of use, or history of cardiovascular disease, diabetes, or hypertension Timing:^116^ No difference in the rate of change by time to initiation of therapy after last menstrual period | NR
WHIMSY Estrogen-only and estrogen plus progestin trial Espeland, 2013^119^ | 696 Hormone therapy 630 Placebo | NR | NR | NR | NR | [underlined: Followup: 7.2 years postintervention] Verbal fluency 18.90 (estrogen: SE, 0.33) vs. 19.91 (placebo: SE, 0.34) No other differences between groups for Telephone Interview for Cognitive Status–Modified, East Boston Memory Test, Verbal Memory, Attention, Executive Function, Working Memory, Composite
WHIMSY Estrogen-only and estrogen plus progestin trial Espeland, 2013^119^ | 696 Hormone therapy 630 Placebo | NR | NR | NR | NR | [underlined: Followup: 7.2 years] Verbal fluency 21.04 (estrogen plus progestin: SE, 0.25) vs. 20.65 (placebo: SE, 0.27) No other differences between groups for Telephone Interview for Cognitive Status–Modified, East Boston Memory Test, Verbal Memory, Attention, Executive Function, Working Memory, Composite
WHISCA Estrogen-only trial Resnick, 2009^121^; Espeland, 2010^120^ | Dementia outcomes, WHISCA:^121^ 434 Estrogen 452 Placebo Cognitive measures, WHISCA extension:^120^ 601 Hormone therapy 612 Placebo | [underlined: Followup: 2.7 years] (during WHISCA, after being enrolled in WHI for 3 years)^121^ 4 (0.9%) vs. 2 (0.4%); calculated RR, 2.08 (95% CI, 0.38 to 11.31); p=0.40 | [underlined: Followup: 2.7 years] (during WHISCA, after being enrolled in WHI for 3 years)^121^ 18 (4.1%) vs. 15 (3.3%); calculated RR, 1.25 (95% CI, 0.64 to 2.45); p=0.52 | NR | [underlined: Followup: 3.6 years] (during WHISCA, after being enrolled in WHI for 3 years)^120^ Mean decrement in global cognitive function, -0.092 (SE, 0.039); p=0.02 [underlined: Followup: Mean 2.4 years posttrial] (after being enrolled in WHI for 3 years and WHISCA for 3.6 years)^120^ Mean decrement in global cognitive function, -0.081 (SE, 0.047); p=0.09 | [underlined: Followup: Mean 3.6 years] (during trial)^120^ Verbal knowledge -0.100 (SE, 0.051); p=0.05 Verbal fluency -0.118 (SE, 0.054); p=0.03 Figural memory -0.132 (SE, 0.048); p=0.006 Spatial ability -0.137 (SE, 0.057); p=0.02 Verbal memory and attention and working memory not significant at p=0.05 [underlined: Followup: 2.4 years postintervention]^120^ Spatial ability -0.179 (SE, 0.063); p=0.004 Verbal knowledge, verbal fluency, verbal memory, figural memory, attention and working memory differences not significant at p=0.05
WHISCA Estrogen plus progestin trial Resnick, 2006;^122^ Espeland, 2010^120^ | Probable dementia or cognitive impairment, WHIMS:^122^ 690 Estrogen plus progestin 726 Placebo Cognitive measures, WHISCA extension:^120^ 601 Hormone therapy 612 Placebo | [underlined: Followup: 1.4 years] (during WHISCA, after being enrolled in WHI for 3 years)^122^ 5 (0.7%) vs. 6 (0.8%); calculated RR, 0.88 (95% CI, 0.27 to 2.86); p=0.83 | [underlined: Followup: 1.4 years] (during WHISCA, after being enrolled in WHI for 3 years)^122^ 6 (0.9%) vs. 13 (1.8%); calculated RR, 0.49 (95% CI, 0.19 to 1.27); p=0.14 | NR | [underlined: Followup: Mean 2 years] (during WHISCA, after being enrolled in WHI for 3 years)^120^ Mean decrement in global cognitive function, -0.080 (SE, 0.034); p=0.02 [underlined: Followup: Mean 4 years posttrial] (after being enrolled in WHI for 3 years and in WHISCA for 2 years)^120^ Mean decrement in global cognitive function, -0.059 (SE, 0.032); p=0.06 | [underlined: Followup: Mean 3 years] (pre-WHISCA, 2 years during WHISCA trial)^120^ Spatial ability, verbal knowledge, verbal fluency, verbal memory, figural memory, attention and working memory not statistically significant at p=0.05 [underlined: Followup: Mean 4 years posttrial]^120^ Spatial ability, verbal knowledge, verbal fluency, verbal memory, figural memory, attention and working memory not statistically significant at p=0.05

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: 3MS = Modified Mini-Mental State Examination; CI = confidence interval; EMS = Estrogen Memory Study; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; MCI = mild cognitive impairment; NR = not reported; NS = not significant; PD = probable dementia; RR = relative risk; SD = standard deviation; SE = standard error; ULTRA = Ultra-Low-Dose Transdermal Estrogen Replacement Assessment; WHI = Women's Health Initiative; WHIMS = Women's Health Initiative Memory Study; WHIMSY = Women's Health Initiative Memory Study of Younger Women; WHISCA = Women's Health Initiative Study of Cognitive Aging.

Appendix G Table 9 Evidence Table of Trials Reporting Incidence of Diabetes

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 66 Estrogen 121 Estrogen plus progestin 186 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by regimen 2 (1.1%) vs. 6 (3.2%); p=0.17
HERS Estrogen plus progestin trial Kanaya, 2003^70^ | Women without self-reported diabetes at baseline 999 Estrogen plus progestin 1,030 Placebo | [underlined: Followup: Mean 4.1 years] Overall 62 (6.2%) vs. 98 (9.5%); NNT, 30 (95% CI, 18 to 103); p=0.006 Of those with normal glucose at baseline 38/904 (4.2%) vs. 52/907 (5.7%); p=0.13 Of those with impaired fasting glucose at baseline 24/95 (25.3%) vs. 46/123 (37.4%); p=0.06 Risk for incident diabetes HR, 0.65 (95% CI, 0.48 to 0.89)
WHI Estrogen-only trial Bonds, 2006;^106^ Manson, 2013^102^ | Women not receiving treatment for diabetes at baseline 4,900 Estrogen 5,017 Placebo | [underlined: Followup: Mean 7.1/median 7.2 years] Overall^102^ 449 (9.2%) vs. 527 (10.5%); HR, 0.86 (95% CI, 0.76 to 0.98); p=0.02 Of those who adhered to ≥80% of medication^106^ HR, 0.73 (95% CI, 0.60 to 0.88) Subgroups:^106^ No significant difference by race/ethnicity, age at screening, hypertension, or metabolic syndrome at baseline [underlined: Followup: Median 6.6 years postintervention]^102^ HR, 1.07 (95% CI, 0.92 to 1.25)
WHI Estrogen plus progestin trial Margolis, 2004;^97^ Manson, 2013^102^ | Women not receiving treatment for diabetes at baseline 8,132 Estrogen plus progestin 7,742 Placebo | [underlined: Followup: Mean 5.6 years]^97^ 328 (4.0%) vs. 373 (4.8%); HR, 0.81 (95% CI, 0.70 to 0.94); p=0.005 Subgroups:^97^ No significant difference by race/ethnicity, age at screening, or hypertension at baseline [underlined: Followup: Median 8.2 years postintervention]^102^ HR, 1.19 (95% CI, 1.05 to 1.34)

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI = confidence interval; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; NNT = number needed to treat; RR = relative risk; WHI = Women's Health Initiative.

Appendix G Table 10 Evidence Table of Trials Reporting Incidence of Fractures

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EMS Estrogen plus progestin trial Tierney 2009^59^ | 70 Estrogen plus progestin 72 Placebo | [underlined: Followup: 2 years] Hip fractures 0 (0.0%) vs. 1 (1.4%)
EPHT Estrogen plus progestin trial Veerus, 2006^61^ | 404 Estrogen plus progestin 373 Placebo | [underlined: Followup: 5 years] Bone fractures^b^ 15 (3.7%) vs. 25 (6.7%) HR, 0.52 (95% CI, 0.27 to 0.98)
ERA Estrogen-only and estrogen plus progestin trial Herrington 2000^62^ | 100 Estrogen 104 Estrogen plus progestin 105 Placebo | [underlined: Followup: 3.2 years] Fractures (all sites) 6 (6.0%) vs. 7 (6.7%) vs. 15 (14.3%) Estrogen: Calculated RR, 0.42 (95% CI, 0.17 to 1.04); p=0.06 Estrogen plus progestin: Calculated RR, 0.47 (95% CI, 0.24 to 1.11); p=0.09
HERS Estrogen plus progestin trial Hulley, 2002^68^ | 1,380 Estrogen plus progestin 1,383 Placebo | [underlined: Followup: Mean 4.1 years] Hip 15 vs. 13; HR, 1.16 (95% CI, 0.55 to 2.44); p=0.69 Wrist 29 vs. 29; HR, 1.01 (95% CI, 0.60 to 1.68); p=0.98 Vertebral 14 vs. 19; HR, 0.74 (95% CI, 0.37 to 1.48); p=0.40 Other 91 vs. 101; HR, 0.91 (95% CI, 0.69 to 1.21); p=0.52 Any 140 vs. 148; HR, 0.96 (95% CI, 0.76 to 1.20); p=0.70
STOP-IT Estrogen plus progestin trial Gallagher 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Vertebral fractures Analysis did not stratify by regimen 2 (hormone therapy with or without calcitriol) vs. 1 (calcitriol only or placebo)
WHI Estrogen-only trial LaCroix, 2011;^112^ Anderson, 2004;^81^ Manson, 2013^102^ | 5,310 Estrogen 5,429 Placebo Postintervention followup: 3,778 Estrogen 3,867 Placebo | [underlined: Followup time: Median 7.2 years]^81, 102^ Vertebral 44 (0.8%) vs. 70 (1.3%); HR, 0.64 (95% CI, 0.44 to 0.93) Hip 48 (0.9%) vs. 74 (1.4%); HR, 0.67 (95% CI, 0.46 to 0.96) Total 544 (10.2%) vs. 767 (14.1%); HR, 0.72 (95% CI, 0.64 to 0.80) Subgroups: No significant difference by age [underlined: Followup: Mean 5.9 years]^112^ Hip fractures HR, 0.67 (95% CI, 0.46 to 0.96) [underlined: Followup: Mean 10.7 years postintervention]^112^ Hip fractures HR, 1.27 (95% CI, 0.88 to 1.82) [underlined: Cumulative followup: Median 13.0 years]^112^ Hip fractures HR, 0.92 (95% CI, 0.71 to 1.18) Subgroups: No significant difference by age
WHI Estrogen plus progestin trial Heiss, 2008;^92^, Cauley, 2003;^83^ Rossouw, 2002^23^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,052 Estrogen plus progestin 7,678 Placebo | [underlined: Followup: Mean 5.6 years]^92, 102^ Hip fractures 53 vs. 75; HR, 0.67 (95% CI, 0.47 to 0.96) Vertebral fractures 56 vs. 78; HR, 0.68 (95% CI, 0.48 to 0.96) Other osteoporotic fractures 650 vs. 800; HR, 0.75 (95% CI, 0.68 to 0.83) Total (hip, vertebral, or other osteoporotic fractures) 741 vs. 903; HR, 0.76 (95% CI, 0.69 to 0.83) [underlined: Followup: Mean 2.4 years postintervention]^92^ Hip fractures HR, 0.92 (95% CI, 0.64 to 1.34) Vertebral fractures HR, 0.96 (95% CI, 0.64 to 1.44) Other osteoporotic fractures HR, 0.87 (95% CI, 0.74 to 1.03) Total (hip, vertebral, or other osteoporotic fractures) HR, 0.91 (95% CI, 0.78 to 1.06)

a Intervention dosages are listed in Table 3 by trial.

b Bone fractures defined as diagnoses Sx2 (x=1-9) according to ICD-10 (fracture of neck, fractures of ribs, sternum and thoracic spine, fracture of lumbar spine and pelvis, fracture of shoulder and upper arm, fracture of forearm, fracture at wrist and hand level, fracture of femur, fracture of lower leg, including ankle).

Abbreviations: CI = confidence interval; EMS = Estrogen Memory Study; EPHT = Estonian Postmenopausal Hormones Therapy Trial; ERA = Estrogen Replacement and Atherosclerosis Trial; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; RR = relative risk; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WHI = Women's Health Initiative.

Appendix G Table 11 Evidence Table of Trials Reporting Incidence of Stroke

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 66 Estrogen 121 Estrogen plus progestin 186 Placebo | [underlined: Follow-up: 3 years] Gallstones Analysis did not stratify by regimen 1 (0.5%) vs. 1 (0.5%)
PEPI Estrogen-only and estrogen plus progestin trial PEPI, 1995^74^ | 175 Estrogen only 174 Estrogen plus progestin (cyclic) 174 Estrogen plus progestin (continuous) 178 Estrogen plus progestin (micronized) 174 Placebo | [underlined: Followup: 3 years] Gallbladder disease 2 (estrogen: 1.1%) vs. 9 (estrogen plus progestin: 2.6%) vs. 4 (estrogen plus micronized progestin: 2.2%) vs. 2 (placebo: 1.1%)
STOP-IT Estrogen-only and estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Gallstones or cholecystitis Analysis did not stratify by regimen 8 (hormone therapy with or without calcitriol: 3.3%) vs. 3 (calcitriol only or placebo: 1.2%)
WHI Estrogen-only trial Cirillo, 2005;^88^ LaCroix, 2011;^112^ Manson, 2013^102^ | Women without cholecystectomy or gallbladder disease at baseline 4,141 Estrogen 4,235 Placebo | [underlined: Followup: Mean 7.1 years]^88^ Gallbladder event incidence 228 (5.5%) vs. 143 (3.4%); HR, 1.67 (95% CI, 1.35 to 2.06); p<0.001 Cholecystectomy 192 (4.6%) vs. 104 (2.5%); HR, 1.93 (95% CI, 1.52 to 2.44); p<0.001 Global gallbladder disease 223 (5.4%) vs. 130 (3.1%); HR, 1.79 (95% CI, 1.44 to 2.22); p<0.001 Cholecystitis 186 (4.5%) vs. 107 (2.5%); HR, 1.80 (95% CI, 1.42 to 2.28); p<0.001 Subgroups:^88^ No significant difference by age [underlined: Followup: Median 6.6 years postintervention]^102^ Gallbladder disease HR, 0.98 (95% CI, 0.68 to 1.41); p=0.92
WHI Estrogen plus progestin trial Cirillo, 2005;^88^ Manson, 2013^102^ | Women without cholecystectomy or gallbladder disease at baseline 7,308 Estrogen plus progestin 6,895 Placebo | [underlined: Followup: Mean 5.6 years]^88^ Gallbladder event incidence 228 (3.1%) vs. 135 (2.0%); HR, 1.59 (95% CI, 1.28 to 1.97); p<0.001 Cholecystectomy 190 (2.6%) vs. 107 (1.6%); HR, 1.67 (95% CI, 1.32 to 2.11); p<0.001 Global gallbladder disease 223 (3.1%) vs. 130 (1.9%); HR, 1.61 (95% CI, 1.30 to 2.00); p<0.001 Cholecystitis 192 (2.6%) vs. 117 (1.7%); HR, 1.54 (95% CI, 1.22 to 1.94); p<0.001 Subgroups:^88^ No significant difference by age [underlined: Followup: Median 8.2 years postintervention]^102^ Gallbladder disease HR, 1.24 (95% CI, 1.01 to 1.52); p=0.04

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI = confidence interval; HR = hazard ratio; PEPI = Postmenopausal Estrogen/Progestin Interventions; RR = relative risk; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WHI = Women's Health Initiative

Appendix G Table 12 Evidence Table of Trials Reporting Incidence of Stroke

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EMS Estrogen plus progestin trial Tierney, 2000^59^ | 70 Estrogen plus progestin 72 Placebo | [underlined: Followup: 2 years] Intracerebral hemorrhage 1 (1.4%) (fatal) vs. 0; p=NS Transient ischemic attack 1 (1.4%) vs. 1 (1.4%); p=NS
EPAT Estrogen-only trial Hodis,2001^60^ | 111 Estrogen^b^ 111 Placebo^b^ | [underlined: Followup: 2 years] Cerebrovascular accidents 0 vs. 1
EPHT Estrogen plus progestin trial Veerus, 2006^61^ | 404 Estrogen plus progestin 373 Placebo | [underlined: Follow-up: Mean 3.4 years] Any cerebrovascular disease^c^ 23 (5.7%) vs. 9 (2.4%); HR, 2.46 (95% CI, 1.14 to 5.34) Stroke 1 (0.2%) vs 1 (0.3%); HR, 1.06 (95% CI,0.07 to 17.2)
ERA Estrogen-only and estrogen plus progestin trial Herrington, 2000^62^ | Women with angiographically verified coronary disease 100 Estrogen 104 Estrogen plus progestin 105 Placebo | [underlined: Followup][underlined: : Mean 3.2 years] Stroke or transient ischemic attack 5 vs. 6 vs. 6; p=1.0
STOP-IT Estrogen-only and estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: Mean 3 years] Cerebrovascular accidents Analysis did not stratify by regimen 10 (hormone therapy with or without calcitriol) vs. 7 (calcitriol only or placebo)
WAVE Estrogen-only and estrogen plus progestin trial Waters, 2002^80^ | Women with a coronary stenosis of 15%–75% 124 Estrogen (with or without vitamin C and E) 86 Estrogen plus progestin (with or without vitamin C and E) 213 Placebo (with or without vitamin C and E) | [underlined: Followup: Mean 2.8 years] Stroke Analysis did not stratify by regimen 9 (4.3%) vs. 4 (1.9%); p=0.17
WHI Estrogen-only trial Hendrix, 2006;^110^ LaCroix, 2011;^112^ Manson, 2013;^102^ Prentice, 2009^98^ | 5,310 Estrogen 5,429 Placebo Postintervention followup: 3,778 Estrogen 3,867 Placebo | [underlined: Followup: Median][underlined: 7.2 years]^102^ All stroke 169 (3.2%) vs. 129 (2.4%); HR, 1.35 (95% CI, 1.07 to 1.70); p=0.01 Subgroups:^110^ No significant difference by race or ethnicity, age, prior CVD, diabetes, hypertension Risk for stroke based on timing of intervention:^98^ No significant association; p=0.96 for gap time interaction [underlined: Followup: Mean 3.9 years postintervention]^112^ All stroke HR, 0.89 (95% CI, 0.64 to 1.24) [underlined: Cumulative followup: Median 13.0 years]^102^, ^112^ All stroke HR, 1.15 (95% CI, 0.97 to 1.37)
WHI Estrogen plus progestin trial Wassertheil-Smoller, 2003;^101^ Heiss, 2008;^92^ Cushman, 2004;^89^ Manson, 2013^102^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,052 Estrogen plus progestin 7,678 Placebo | [underlined: Followup: Mean 5.6 years] All stroke^102^ 159 (1.9%) vs. 109 (1.3%); HR, 1.37 (95% CI, 1.07 to 1.76) Ischemic stroke^101^ 125 vs. 81; HR, 1.44 (95% CI, 1.09 to 1.90) Hemorrhagic stroke^101^ 18 vs. 20; HR, 0.82 (95% CI, 0.43 to 1.56) Subgroups: No significant difference by race/ethnicity, age, diabetes, or hypertension Risk for stroke based on timing of intervention:^98^ No significant association; p=1.00 for gap time interaction [underlined: Followup: Mean 2.4 years postintervention]^102^ All Stroke HR, 1.04 (95% CI, 0.89 to 1.23) [underlined: Cumulative followup: Median 13.2 years]^102^ All stroke HR, 1.16 (95% CI, 1.00 to 1.35)

a Intervention dosages are listed in Table 3 by trial.

b Unopposed micronized 17V-estradiol (1mg/d).

c Defined as diagnoses of one of the following (ICD-10 or 160-169 codes): subarachnoid hemorrhage, intracerebral hemorrhage, cerebral infarction, stroke, occlusion and stenosis of precerebral arteries, occlusion and stenosis of cerebral arteries, other cerebrovascular diseases, cerebrovascular disorders, sequelae of cerebrovascular disease.

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; EMS = Estrogen Memory Study; EPAT = Estrogen in the Prevention of Atherosclerosis; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ERA = Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HR = hazard ratio; RR = relative risk; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WAVE = Women's Angiographic Vitamin and Estrogen Trial; WHI = Women's Health Initiative.

Appendix G Table 13 Evidence Table of Trials Reporting Incidence of Urinary Incontinence

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
HERS Estrogen plus progestin trial Steinauer, 2005^71^ | Women reporting no episodes of incontinence in the past week at baseline 597 Estrogen plus progestin 611 Placebo | [underlined: Followup: 4.2 years] Weekly urinary incontinence 382 vs. 302, OR,1.6 (95% CI, 1.3 to 1.9); p<0.001 Stress urinary incontinence OR, 1.7 (95% CI, 1.5 to 2.1); p<0.001 Urge urinary incontinence OR, 1.5 (95% CI, 1.2 to 1.8); p<0.001
ULTRA Estrogen-only trial Waetjen, 2005^78^ | Women who were continent at baseline 122 Estrogen (calculated) 117 Placebo (calculated) | [underlined: Followup: 2 years] 39.0% vs. 36.8%; OR, 1.2 (95% CI, 0.7 to 2.2); p=0.74
WHI Estrogen-only trial Hendrix, 2005^94^ | Women with urinary incontinence data at baseline and 1 year 1,526 Estrogen (all continent at baseline, 96 continent at 1 year) 1,547 Placebo (all continent at baseline, 136 continent at 1 year) | [underlined: Followup: 1 year] Incident urinary incontinence 557 (36.5%) vs. 368 (23.8%); RR, 1.53 (95% CI, 1.37 to 1.71) Stress urinary incontinence 266 (17.4%) vs. 131 (8.5%); RR, 2.15 (95% CI, 1.77 to 2.62); p<0.001 Urge urinary incontinence 210 (13.8%) vs. 184 (11.9%); RR, 1.32 (95% CI, 1.10 to 1.58); p=0.003 Mixed urinary incontinence 76 (5.0%) vs. 50 (3.2%); RR, 1.79 (95% CI, 1.26 to 2.53); p=0.001 [underlined: Followup: 3 years] 27/96 (28.1%) vs. 26/136 (19.1%) of continent women at baseline and 1 year reported incident urinary incontinence at 3 years; RR, 1.47 (95% CI, 0.92 to 2.36)
WHI Estrogen plus progestin trial Hendrix, 2005^94^ | Women with urinary incontinence data at baseline and 1 year 2,675 Estrogen plus progestin (all continent at baseline, 153 continent at 1 year) 2,507 Placebo (all continent at baseline, 185 continent at 1 year) | [underlined: Followup: 1 year] Incident urinary incontinence 834 (31.2%) vs. 563 (22.5%); RR, 1.39 (95% CI, 1.27 to 1.52) Stress urinary incontinence 429 (16.0%) vs. 218 (8.7%); RR, 1.87 (95% CI, 1.61 to 2.18); p<0.001 Urge urinary incontinence 304 (11.4%) vs. 272 (10.8%); RR, 1.15 (95% CI, 0.99 to 1.34); p=0.06 Mixed urinary incontinence 99 (3.7%) vs. 69 (2.8%); RR, 1.49 (95% CI, 1.10 to 2.01); p=0.01 [underlined: Followup: 3 years] 39/153 (25.5%) vs. 26/185 (14.1%) of continent women at baseline and 1 year reported incident urinary incontinence at 3 years; RR, 1.81 (95% CI, 1.16 to 2.84)

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI = confidence interval; HERS = Heart and Estrogen/Progestin Replacement Study; OR = odds ratio; RR = relative risk; ULTRA = Ultra Low-Dose Transdermal Estrogen Replacement Assessment; WHI = Women's Health Initiative.

Appendix G Table 14 Evidence Table of Trials Reporting Incidence of Venous Thromboembolism

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
EMS Estrogen plus progestin trial Tierney, 2000^59^ | 70 Estrogen plus progestin 72 Placebo | [underlined: Followup: 2 years] Deep vein thrombosis 1 vs. 0; p=NS
EPAT Estrogen-only trial Hodis, 2001^60^ | 111 Estrogen 111 Placebo | [underlined: Followup: 2 years] Deep vein thrombosis or pulmonary embolism 0 (0.0%) vs. (0.0%)
EPHT Estrogen plus progestin trial Veerus, 2006^61^ | 404 Estrogen plus progestin 373 Placebo | [underlined: Followup: Mean 3.4 years] Venous thromboembolism 0 (0.0%) vs. 0 (0.0%)
ERA Estrogen-only and estrogen plus progestin trial Herrington, 2000^62^ | 100 Estrogen 104 Estrogen plus progestin 105 Placebo | [underlined: Followup: 3.2 years] 1 vs. 0 vs. 0; p=0.35
Greenspan, et al Estrogen-only and estrogen plus progestin trial Greenspan, 2005^65^ | 66 Estrogen 121 Estrogen plus progestin 186 Placebo | [underlined: Followup: 3 years] Deep vein thrombosis Analysis did not stratify by regimen 2 vs. 1; p=1.0
STOP-IT Estrogen-only and estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Deep vein thrombosis Analysis did not stratify by regimen 4 (hormone therapy with or without calcitriol) vs. 1 (calcitriol only or placebo)
WAVE Estrogen-only and estrogen plus progestin trial Waters, 2002^80^ | Women with a coronary stenosis of 15%–75% 124 Estrogen (with or without vitamin C and E) 86 Estrogen plus progestin (with or without vitamin C and E) 213 Placebo (with or without vitamin C and E) | [underlined: Followup: 2.8 years] Deep vein thrombosis or pulmonary embolism Analysis did not stratify by treatment regimen 4 vs. 4; p=0.93
WHI Estrogen-only trial LaCroix, 2011;^112^ Curb, 2006;^109^ Prentice, 2009;^98^ Manson, 2013^102^ | 5,310 Estrogen 5,429 Placebo Postintervention followup: 3,778 Estrogen 3,867 Placebo | [underlined: Followup: Mean 7.1 years]^102, 112^ Deep vein thrombosis 85 (1.6%) vs. 59 (1.0%); HR, 1.48 (95% CI, 1.06 to 2.07); p=0.02 Pulmonary embolism 52 (0.98%) vs. 39 (0.72%); HR, 1.35 (95% CI, 0.89 to 2.05); p=0.15 Subgroups:^109^ No significant difference by race or ethnicity, age, or history of CVD Risk for venous thromboembolism based on timing of intervention:^98^ No significant association; p=0.65 for gap time interaction [underlined: Followup: Mean 3.9 years postintervention]^112^ Deep vein thrombosis HR, 0.63 (95% CI, 0.41 to 0.98); p=0.003 Pulmonary embolism HR, 0.98 (95% CI, 0.62 to 1.55); p=0.29 [underlined: Cumulative followup: Median 13.0 years]^102^ Deep vein thrombosis HR 1.05 (95% CI, 0.82 to 1.33) Pulmonary embolism HR, 1.15 (95% CI, 0.87 to 1.51)
WHI Estrogen plus progestin trial Heiss, 2008;^92^ Cushman, 2004;^89^ Manson, 2013;^102^ Prentice, 2009^98^ | 8,506 Estrogen plus progestin 8,102 Placebo Postintervention followup: 8,052 Estrogen plus progestin 7,678 Placebo | [underlined: Followup: Median 5.6 years] Venous thrombosis^89^ 167 vs. 76; HR, 2.06 (95% CI, 1.57 to 2.70) Deep vein thrombosis^102^ 122 (1.4%) vs. 61 (0.8%); HR, 1.87 (95% CI, 1.37 to 2.54); p<0.001 Pulmonary embolism^102^ 87 (1.0%) vs. 41 (0.5%); HR, 1.98 (95% CI, 1.36 to 2.87); p<0.001 Subgroups:^102^ No significant difference by age Risk for venous thromboembolism based on timing of intervention:^98^ No significant association; p=0.45 for gap time interaction [underlined: Followup: Mean 2.4 years postintervention]^92^ Deep vein thrombosis HR, 1.07 (95% CI, 0.66 to 1.75) Pulmonary embolism HR 1.07 (95% CI, 0.62 to 1.86) [underlined: Cumulative Followup: Median 13.0 years]^89, 92, 102^ Deep vein thrombosis HR, 1.05 (95% CI, 0.82 to 1.33) Pulmonary embolism HR, 1.15 (95% CI, 0.87 to 1.51)

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; EMS = Estrogen Memory Study; EPAT = Estrogen in the Prevention of Atherosclerosis; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ERA = Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HR = hazard ratio; NS = not significant; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WAVE = Women's Angiographic Vitamin and Estrogen Trial; WHI = Women's Health Initiative.

Appendix G Table 15 Evidence Table of Trials Reporting Incidence of Quality of Life

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
WHI Estrogen-only trial Manson, 2013^102^ | 5,310 Estrogen 5,429 Placebo | [underlined: Followup: Mean 7.1 years]^102^ RAND 36: Similar scores on all items except for emotional role (81.0 vs. 82.2; p=0.04) and social functioning (85.8 vs. 86.9; p=0.01), for which women taking placebo had statistically significantly better scores than women taking estrogen-only therapy
WHI Estrogen plus progestin trial Manson, 2013;^102^ Hays, 2003^91^ | 8,506 Estrogen plus progestin 8,102 Placebo | [underlined: Followup: Mean 5.6 years]^102^ RAND 36: Similar scores on all items except for physical functioning (82.6 vs. 81.8; p<0.001), physical role (77.4 vs. 76.2; p=0.02), bodily pain (77.6 vs. 75.6; p<0.001), and general health (76.6 vs. 76.1; p=0.02), for which women taking hormone therapy had statistically significantly better scores than women taking placebo

a Intervention dosages are listed in Table 3 by trial.

Abbreviation: WHI = Women's Health Initiative.

Appendix G Table 16 Evidence Table of Trials Reporting Incidence of All-Cause Mortality

Study Author, Year | Population | Results (Treatment^a^ vs. Placebo)
ERA Estrogen-only and estrogen plus progestin trial Herrington, 2000^62^ | 100 Estrogen 104 Estrogen plus progestin 105 Placebo | [underlined: Followup: Mean 3.2 years] 8 (8.0%) vs. 3 (2.9%) vs. 6 (5.7%); p=0.28
ESPRIT Estrogen-only trial Cherry, 2002;^63^ Cherry, 2014^64^ | 513 Estrogen 504 Placebo | [underlined: Followup: 2 years]^63^ 32 (6.2%) vs. 39 (7.7%); Rate ratio, 0.79 (95% CI, 0.50 to 1.27); p=0.34 [underlined: Cumulative followup: Mean 14.1 years]^64^ HR, 1.07 (95% CI, 0.88 to 1.29)
HERS Estrogen plus progestin trial Hulley, 2002^68^ | 1,380 Estrogen plus progestin 1,383 Placebo Cumulative followup: 1,156 Estrogen plus progestin 1,383 Placebo | [underlined: Followup: Mean 4.1 years] 130 (9.4%) vs. 123 (8.9%); HR, 1.06 (95% CI, 0.83 to 1.36); p=0.62 [underlined: Cumulative followup: Mean 6.8 years] HR, 1.10 (95% CI, 0.92 to 1.31); p=0.29
STOP-IT Estrogen-only and estrogen plus progestin trial Gallagher, 2001^75^ | 121 Hormone therapy 122 Hormone therapy plus calcitriol 123 Calcitriol only 123 Placebo | [underlined: Followup: 3 years] Analysis did not stratify by regimen 3 (hormone therapy with or without calcitriol: 1.2%) vs. 2 (calcitriol only or placebo: 0.8%)
WAVE Estrogen-only and estrogen plus progestin trial Waters, 2002^80^ | 124 Estrogen (with or without vitamin C and E) 86 Estrogen plus progestin (with or without vitamin C and E) 213 Placebo (with or without vitamin C and E) | [underlined: Followup: Mean 2.8 years] Analysis did not stratify by treatment regimen 14 (6.7%) vs. 8 (3.8%)
WHI Estrogen-only trial LaCroix, 2011;^112^ Manson, 2013;^102^ Prentice, 2009^98^ | 5,310 Estrogen 5,429 Placebo | [underlined: Followup: Mean 7.1 years]^112^ 300 (5.6%) vs. 297 (5.5%); HR, 1.04 (95% CI, 0.89 to 1.22) Subgroups:^112^ In women ages 50–59 years at randomization: HR, 0.73 (95% CI, 0.53 to 1.00) In women ages 60–69 years at randomization: HR, 1.04 (95% CI, 0.88 to 1.24) In women ages 70–79 years at randomization: HR, 1.12 (95% CI, 0.94 to 1.33) p=0.04 for trend Risk for death based on timing of intervention:^98^ In women without prior HT use No significant association; p=0.14 for gap time interaction [underlined: Followup: Mean 3.9 years postintervention]^112^ HR, 1.00 (95% CI, 0.84 to 1.18) [underlined: Cumulative followup: Mean 10.7 years]^112^ HR, 1.02 (95% CI, 0.91 to 1.15)
WHI Estrogen plus progestin trial Heiss, 2008;^92^ Manson, 2013;^102^ Prentice, 2009^98^ | 8,506 Estrogen plus progestin 8,102 Placebo | [underlined: Followup: Mean 5.6 (weighted mean 5.2) years]^92^ 250 (2.9%) vs. 239 (2.9%); HR, 0.97 (95% CI, 0.81 to 1.16) Risk for death based on timing of intervention:^98^ No significant association; p=0.36 for gap time interaction [underlined: Followup: Mean 2.4 years postintervention]^92^ HR, 1.15 (95% CI, 0.95 to 1.39) Of those who adhered to ≥80% of medication^92^ HR, 1.53 (95% CI, 1.04 to 2.24) [underlined: Followup: Median 8.2 years postintervention]^102^ HR, 1.01 (95% CI, 0.91 to 1.11); p=0.90

a Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI = confidence interval; ERA = Estrogen Replacement and Atherosclerosis Trial; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HERS = Heart and Estrogen/Progestin Replacement Study; HR = hazard ratio; HT = hormone therapy; STOP-IT = Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WAVE = Women's Angiographic Vitamin and Estrogen Trial; WHI = Women's Health Initiative.