# Appendix F Ratings for Domains of Quality Ratings of Randomized, Controlled Trials

Trial | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Outcome Assessors Masked? | Care Providers Masked? | Patient Masked? | Loss to Followup ≤20% and Differential Attrition ≤15%? | Intention-to-Treat Analysis? | Other Biases? | Quality Rating
DOPS (Denmark) | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes^a^ | Poor
Clarke 2002 (UK) | Unclear | Unclear | Yes | Yes | No | No | No | Yes | No | Poor
EMS (Canada) | Yes | Yes | Mostly, except for prior HT use and amnestic mild cognitive impairment | Yes | Yes | Yes | Yes | Unclear | No | Fair
EPAT (US) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes^b^ | Fair
EPHT (Estonia) | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Fair
ERA (US) | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes^c^ | Fair
ESPRIT (UK) | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | No | Fair
Greenspan 2005 (US) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Notelovitz 2002 (US) | Unclear | Unclear | Yes | Yes | Yes | Yes | No | No | Yes^d^ | Poor
HERS (US) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
KEEPS-Cog (US) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
Pefanco 2007 (US) | Yes | Unclear | Yes | Yes | Unclear | Yes | No | No | No | Poor
PEPI (US) | Yes | Unclear | Unclear | Yes | Unclear | Yes | Unclear | No | Yes^e^ | Fair
STOP-IT (US) | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | No | Fair
ULTRA (US) | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
WAVE (US, Canada) | Yes | Unclear | Yes | Yes | Yes | Yes | No | Unclear | No | Fair
WHI (US) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
WHIMS (US) | Yes | Yes | Mostly, except for history of stroke, and hypertension | Yes | Yes | Yes | Yes | Yes | No | Good
WHIMSY (US) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
WHISCA (US) | Yes | Yes | Mostly, except for smoking status | Yes | Yes | Yes | Yes | Yes | No | Good
WISDOM (UK, Australia, New Zealand) | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | No | Fair

a High risk of selection bias and contamination. Invited participants chose whether or not to be part of randomized trial (those who preferred a treatment option where followed in the cohort study). Among those who were randomized to no-HRT and attended 5 -year follow-up, 15% had initiated HRT. Among those randomized to HRT, 18% had changed the type of HRT and 22% had stopped HRT at 5 years.

b Although the trial conducted an ITT analysis, it was only for evaluable patients (199/222) from the larger set of randomized patients.

c There was a statistically significant difference between placebo and CEE in adherence.

d Risk of measurement bias. Some outcome (e.g., breast cancer) were assessed as adverse events; ascertainment of these outcomes is unclear. Although mammograms were performed as part of the study protocol, cases of breast cancer appear to have been self-reported. Some were assessed to be benign; method of determining cancer severity were not described.

e Potential risk of contamination and low adherence to assigned study medications. Study authors note that in women assigned to CEE, continuation rate were lowest and potentially due to endometrial hyperplasia. Some women were also initiated on another hormone regimen (other than the one assigned at randomization); this included up to 18% in some study arms.

Abbreviations: BMD = bone mineral density; DOPS = Danish Osteoporosis Prevention Trail; EMS = Estrogen Memory Study; EPAT = Estrogen in the Prevention of Atherosclerosis; EPHT = Estonian Postmenopausal Hormone Therapy Trial; ERA = Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HERS = Heart and Estrogen/Progestin Replacement Study; PEPI = Postmenopausal Estrogen and Progestin Interventions Trial; UK = United Kingdom; ULTRA = Ultra-Low-Dose Transdermal Estrogen Assessment; US = United States; WAVE = Women's Angiographic Vitamin and Estrogen Trial; WHI = Women's Health Initiative; WHIMS = Women's Health Initiative Memory Study; WHIMSY = Women's Health Initiative Memory Study of Younger Women; WHISCA = Women's Health Initiative Study of Cognitive Aging; WISDOM = Women's International Study of Long Duration Oestrogen After Menopause.