# Appendix E Excluded Studies

Code | Exclusion reason
X1 | Non-English publication
X2 | Ineligible publication type
X3 | Ineligible population
X4 | Ineligible intervention
X5 | Ineligible indication
X6 | Ineligible duration
X7 | Ineligible design
X8 | Superseded by more recent review
X9 | Ineligible sample size
X10 | Irrelevant outcomes
X11 | Intermediate outcomes only
X12 | Ineligible setting
X13 | Does not answer Key Questions
X14 | Excluded for poor quality
X15 | Systematic reviews handsearched and excluded

1 Effects of hormone replacement therapy on endometrial histology in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial. JAMA. 1996 Feb 7;275(5):370-5. PMID: 8569016.Exclusion Code: X10.8569016
2 Hormone therapy has no effect on cognition in younger postmenopausal women. BMJ. 2013;346:f4095. PMID: 23804184.Exclusion Code: X2.23804184
3 Risks and benefits of hormone replacement therapy, revisited. An update on the Women's Health Initiative study, which in 2002 changed the landscape of hormone replacement therapy. Duke Med Health News. 2014 Jan;20(1):5-6.Exclusion Code: X2.
4 Menopausal hormone therapy: is it OK after all? Weighing symptom relief against the risk. Health After 50 Sci Am Consum Health. 2016 Winter;27(14):3-5. PMID: 27062750.Exclusion Code: X2.27062750
5 Postmenopausal hormone replacement therapy: ovarian cancer. Prescrire Int. 2016 Jan;25(167):16. PMID: 26942255.Exclusion Code: X2.26942255
6 Abdelbary AM, El-Dessoukey AA, Massoud AM, . Combined Vaginal Pelvic Floor Electrical Stimulation (PFS) and Local Vaginal Estrogen for Treatment of Overactive Bladder (OAB) in Perimenopausal Females. Randomized Controlled Trial (RCT). Urology. 2015 Sep;86(3):482-6. doi: 10.1016/j.urology.2015.06.007. PMID: 26135813.Exclusion Code: X4.26135813
7 Anderson GL, Barrington WE. Narrowing of racial disparities in breast cancer incidence: insights from menopausal hormone therapy study findings. J Natl Cancer Inst. 2016 Apr;108(4)doi: 10.1093/jnci/djv393. PMID: 26613938.Exclusion Code: X2.26613938
8 Antoine C, Ameye L, Paesmans M, . Update of the evolution of breast cancer incidence in relation to hormone replacement therapy use in Belgium. Maturitas. 2012;72(4):317-23.Exclusion Code: X7.22627077
9 Antoine C, Ameye L, Paesmans M, . Systematic review about breast cancer incidence in relation to hormone replacement therapy use. Climacteric. 2014 Apr;17(2):116-32. doi: 10.3109/13697137.2013.829812 [doi]. PMID: 23909434.Exclusion Code: X7.23909434
10 Antoine C, Ameye L, Paesmans M, . Systematic review about breast cancer incidence in relation to hormone replacement therapy use. Maturitas. 2015;81(1):194.Exclusion Code: X7.
11 Archer DF, Pickar JH, MacAllister DC, . Transdermal estradiol gel for the treatment of symptomatic postmenopausal women. Menopause. 2012 Jun;19(6):622-9. doi: 10.1097/gme.0b013e31823b8867 [doi]. PMID: 22282101.Exclusion Code: X5.22282101
12 Archer DF, Schmelter T, Schaefers M, . A randomized, double-blind, placebo-controlled study of the lowest effective dose of drospirenone with 17beta-estradiol for moderate to severe vasomotor symptoms in postmenopausal women. Menopause. 2014 Mar;21(3):227-35. doi: 10.1097/GME.0b013e31829c1431 [doi]. PMID: 23963307.Exclusion Code: X6.23963307
13 Arem H, Park Y, Felix AS, . Reproductive and hormonal factors and mortality among women with colorectal cancer in the NIH-AARP Diet and Health Study. Br J Cancer. 2015;113(3):562-8.Exclusion Code: X4.26103572
14 Bagcchi S. Menopausal hormone therapy reduces liver cancer risk. Lancet Oncol. 2016 Feb;17(2):e50. doi: 10.1016/S1470-2045(16)00003-6. PMID: 26774795.Exclusion Code: X2.26774795
15 Barakat RR, Bundy BN, Spirtos NM, . Randomized double-blind trial of estrogen replacement therapy versus placebo in stage I or II endometrial cancer: a Gynecologic Oncology Group Study. J Clin Oncol. 2006 Feb 1;24(4):587-92. doi: 10.1200/jco.2005.02.8464. PMID: 16446331.Exclusion Code: X3.16446331
16 Barnes EL, Long MD. Colorectal cancer in women: hormone replacement therapy and chemoprevention. Climacteric. 2012 Jun;15(3):250-5. doi: 10.3109/13697137.2012.659450 [doi]. PMID: 22612611.Exclusion Code: X2.22612611
17 Baumgartner AK, Hausler A, Seifert-Klauss V, . Breast cancer after hormone replacement therapy--does prognosis differ in perimenopausal and postmenopausal women? Breast. 2011 Oct;20(5):448-54. doi: 10.1016/j.breast.2011.04.010. PMID: 21652211.Exclusion Code: X7.21652211
18 Bayer U, Hausmann M. Estrogen treatment affects brain functioning after menopause. Menopause Int. 2011 Dec;17(4):148-52. doi: 10.1258/mi.2011.011105. PMID: 22120942.Exclusion Code: X2.22120942
19 Benkhadra K, Mohammed K, Al Nofal A, . Menopausal Hormone Therapy and Mortality: A Systematic Review and Meta-Analysis. J Clin Endocrinol Metab. 2015 Nov;100(11):4021-8. doi: 10.1210/jc.2015-2238 [doi]. PMID: 26544652.Exclusion Code: X12.26544652
20 Benson VS, Kirichek O, Beral V, . Menopausal hormone therapy and central nervous system tumor risk: large UK prospective study and meta-analysis. Int J Cancer. 2015 May 15;136(10):2369-77. doi: 10.1002/ijc.29274 [doi]. PMID: 25335165.Exclusion Code: X3.25335165
21 Beral V, Gaitskell K, Hermon C, . Menopausal hormone use and ovarian cancer risk: individual participant meta-analysis of 52 epidemiological studies. Lancet. 2015 May 9;385(9980):1835-42. doi: 10.1016/S0140-6736(14)61687-1. PMID: 25684585.Exclusion Code: X7.25684585
22 Beral V, Reeves G, Bull D, . Breast cancer risk in relation to the interval between menopause and starting hormone therapy. J Natl Cancer Inst. 2011 Feb 16;103(4):296-305. doi: 10.1093/jnci/djq527. PMID: 21278356.Exclusion Code: X7.21278356
23 Berent-Spillson A, Briceno E, Pinsky A, . Distinct cognitive effects of estrogen and progesterone in menopausal women. Psychoneuroendocrinology. 2015 Sep;59:25-36. doi: 10.1016/j.psyneuen.2015.04.020. PMID: 26010861.Exclusion Code: X6.26010861
24 Besevic J, Gunter MJ, Fortner RT, . Reproductive factors and epithelial ovarian cancer survival in the EPIC cohort study. Br J Cancer. 2015 Dec 1;113(11):1622-31. doi: 10.1038/bjc.2015.377. PMID: 26554655.Exclusion Code: X3.26554655
25 Birrer N, Chinchilla C, Del Carmen M, . Is Hormone Replacement Therapy Safe in Women With a BRCA Mutation?: A Systematic Review of the Contemporary Literature. American Journal of Clinical Oncology: Cancer Clinical Trials. 2016((Birrer N.) Division of Gynecologic Oncology, Massachusetts General Hospital Cancer Center, Boston, MA).Exclusion Code: X2.
26 Bladbjerg EM, Madsen JS, Kristensen SR, . Effect of long-term hormone replacement therapy on tissue factor pathway inhibitor and thrombin activatable fibrinolysis inhibitor in healthy postmenopausal women: a randomized controlled study. J Thromb Haemost. 2003 Jun;1(6):1208-14. PMID: 12871321.Exclusion Code: X10.12871321
27 Boardman H, Hartley L, Eisinga A, . Cochrane corner: oral hormone therapy and cardiovascular outcomes in post-menopausal women. Heart. 2016 Jan;102(1):9-11. doi: 10.1136/heartjnl-2015-308287. PMID: 26453279.Exclusion Code: X2.26453279
28 Boardman Henry MP, Hartley L, Eisinga A, . Hormone therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015.Exclusion Code: X7.
29 Bonnelykke K, Raaschou-Nielsen O, Tjonneland A, . Postmenopausal hormone therapy and asthma-related hospital admission. J Allergy Clin Immunol. 2015 Mar;135(3):813-6 e5. doi: 10.1016/j.jaci.2014.11.019. PMID: 25579482.Exclusion Code: X2.25579482
30 Boyd NF, Melnichouk O, Martin LJ, . Mammographic density, response to hormones, and breast cancer risk. J Clin Oncol. 2011 Aug 1;29(22):2985-92. doi: 10.1200/JCO.2010.33.7964. PMID: 21709206.Exclusion Code: X4.21709206
31 Braganza MZ, de Gonzalez AB, Schonfeld SJ, . Benign breast and gynecologic conditions, reproductive and hormonal factors, and risk of thyroid cancer. Cancer Prev Res (Phila). 2014 Apr;7(4):418-25. doi: 10.1158/1940-6207.CAPR-13-0367. PMID: 24449056.Exclusion Code: X7.24449056
32 Brinton LA, Felix AS. Menopausal hormone therapy and risk of endometrial cancer. J Steroid Biochem Mol Biol. 2014 Jul;142:83-9. doi: 10.1016/j.jsbmb.2013.05.001. PMID: 23680641.Exclusion Code: X2.23680641
33 Brown E. Hormone therapy linked to lower non-Hodgkin lymphoma risk. Womens Health (Lond Engl). 2014 May;10(3):235-6. PMID: 25093225.Exclusion Code: X2.25093225
34 Brown S. Hormone replacement therapy and breast cancer: causation and epidemiology. Menopause Int. 2012 Mar;18(1):3-4. PMID: 22493829.Exclusion Code: X2.22493829
35 Brown S. Estradiol associated with lower thrombotic risk than conjugated equine estrogens when used as oral HRT. Menopause Int. 2013 Dec;19(4):145. PMID: 24479171.Exclusion Code: X2.24479171
36 Brown S. Hormone therapy in early menopause does not slow progression of atherosclerosis. Post Reprod Health. 2014 Dec;20(4):130-1. PMID: 25621341.Exclusion Code: X2.25621341
37 Buckler A, Voss J. Menopausal hormone therapy for the primary prevention of chronic conditions. Am Fam Physician. 2013 Mar 15;87(6):437-8. doi: d11000 [pii]. PMID: 23547577.Exclusion Code: X2.23547577
38 Caan B, LaCroix AZ, Joffe H, . Effects of estrogen and venlafaxine on menopause-related quality of life in healthy postmenopausal women with hot flashes: a placebo-controlled randomized trial. Menopause. 2015 Jun;22(6):607-15. doi: 10.1097/GME.0000000000000364 [doi]. PMID: 25405571.Exclusion Code: X6.25405571
39 Cahoon EK, Kitahara CM, Ntowe E, . Female Estrogen-Related Factors and Incidence of Basal Cell Carcinoma in a Nationwide US Cohort. J Clin Oncol. 2015 Dec 1;33(34):4058-65. doi: 10.1200/JCO.2015.62.0625. PMID: 26527779.Exclusion Code: X7.26527779
40 Caini S, Gibelli B, Palli D, . Menstrual and reproductive history and use of exogenous sex hormones and risk of thyroid cancer among women: a meta-analysis of prospective studies. Cancer Causes Control. 2015;26(4):511-8.Exclusion Code: X4.25754110
41 Camargo MC, Goto Y, Zabaleta J, . Sex hormones, hormonal interventions, and gastric cancer risk: A meta-analysis. Cancer Epidemiology Biomarkers and Prevention. 2012;21(1):20-38.Exclusion Code: X4.
42 Campbell Jenkins BW, Addison C, Wilson G, . Association of the joint effect of menopause and hormone replacement therapy and cancer in African American women: the Jackson Heart Study. Int J Environ Res Public Health. 2011 Jun;8(6):2491-504. doi: 10.3390/ijerph8062491. PMID: 21776241.Exclusion Code: X4.21776241
43 Cannoletta M, Cagnacci A. Modification of blood pressure in postmenopausal women: Role of hormone replacement therapy. International Journal of Women's Health. 2014;6(1):745-57.Exclusion Code: X2.
44 Canonico M. Hormone therapy and risk of venous thromboembolism among postmenopausal women. Maturitas. 2015 Nov;82(3):304-7. doi: 10.1016/j.maturitas.2015.06.040. PMID: 26276103.Exclusion Code: X2.26276103
45 Casanova G, Bossardi Ramos R, Ziegelmann P, . Effects of low-dose versus placebo or conventional-dose postmenopausal hormone therapy on variables related to cardiovascular risk: a systematic review and meta-analyses of randomized clinical trials. J Clin Endocrinol Metab. 2015 Mar;100(3):1028-37. doi: 10.1210/jc.2014-3301 [doi]. PMID: 25514104.Exclusion Code: X11.25514104
46 Casanova G, Spritzer PM. Effects of micronized progesterone added to non-oral estradiol on lipids and cardiovascular risk factors in early postmenopause: a clinical trial. Lipids Health Dis. 2012;11:133. doi: 10.1186/1476-511X-11-133. PMID: 23046709.Exclusion Code: X4.23046709
47 Castelo-Branco C, Davila J, Perello MF, . Long-term effect of hormone therapy on bone in early menopause: vertebral fractures after 20 years. Climacteric. 2014 Aug;17(4):336-41. doi: 10.3109/13697137.2013.871511 [doi]. PMID: 24313640.Exclusion Code: X9.24313640
48 Chen YH, Hsieh TF, Lee CC, . Estrogen Therapy and Ischemic Stroke in Women with Diabetes Aged Over 55 Years: A Nation-Wide Prospective Population-Based Study in Taiwan. PLoS One. 2015;10(12):e0144910. doi: 10.1371/journal.pone.0144910. PMID: 26658781.Exclusion Code: X7.26658781
49 Chiu CL, Lind JM. Menopausal hormone therapy: examining cardiovascular and clinical impacts of treatment. Future Cardiol. 2013 May;9(3):427-35. doi: 10.2217/fca.13.14 [doi]. PMID: 23668745.Exclusion Code: X2.23668745
50 Chiu CL, Lujic S, Thornton C, . Menopausal hormone therapy is associated with having high blood pressure in postmenopausal women: observational cohort study. PLoS One. 2012;7(7):e40260. doi: 10.1371/journal.pone.0040260. PMID: 22808129.Exclusion Code: X11.22808129
51 Chlebowski RT, Anderson GL. Menopausal hormone therapy and breast cancer mortality: clinical implications. Ther Adv Drug Saf. 2015 Apr;6(2):45-56. doi: 10.1177/2042098614568300. PMID: 25922653.Exclusion Code: X2.25922653
52 Chlebowski RT, Anderson GL, Aragaki AK, . Breast Cancer and Menopausal Hormone Therapy by Race/Ethnicity and Body Mass Index. J Natl Cancer Inst. 2016 Feb;108(2)doi: 10.1093/jnci/djv327. PMID: 26546117.Exclusion Code: X7.26546117
53 Chlebowski RT, Manson JE, Anderson GL, . Estrogen plus progestin and breast cancer incidence and mortality in the Women's Health Initiative Observational Study. J Natl Cancer Inst. 2013 Apr 17;105(8):526-35. doi: 10.1093/jnci/djt043. PMID: 23543779.Exclusion Code: X7.23543779
54 Clarke SC, Kelleher J, Lloyd-Jones H, . A study of hormone replacement therapy in postmenopausal women with ischaemic heart disease: the Papworth HRT atherosclerosis study. BJOG. 2002 Sep;109(9):1056-62. PMID: 12269682.Exclusion Code: X14.12269682
55 Clarkson TB, Melendez GC, Appt SE. Timing hypothesis for postmenopausal hormone therapy: its origin, current status, and future. Menopause. 2013 Mar;20(3):342-53. doi: 10.1097/GME.0b013e3182843aad. PMID: 23435033.Exclusion Code: X2.23435033
56 Close H, Mason JM, Wilson D, . Hormone replacement therapy is associated with gastro-oesophageal reflux disease: A retrospective cohort study. BMC Gastroenterol. 2012;12((Close H., h.j.close@durham.ac.uk; Mason J.M., j.m.mason@durham.ac.uk; Wilson D., d.w.wilson@durham.ac.uk) Durham Clinical Trials Unit, Wolfson Research Institute, University of Durham, University Boulevard, Stockton-on-Tees, TS17 6BH, United Kingdom).Exclusion Code: X6.
57 Cody JD, Jacobs ML, Richardson K, . Oestrogen therapy for urinary incontinence in post-menopausal women. Cochrane Database Syst Rev. 2012;10:CD001405. doi: 10.1002/14651858.CD001405.pub3 [doi]. PMID: 23076892.Exclusion Code: X5.23076892
58 Daugherty SE, Lacey JV, Jr., Pfeiffer RM, . Reproductive factors and menopausal hormone therapy and bladder cancer risk in the NIH-AARP Diet and Health Study. Int J Cancer. 2013 Jul 15;133(2):462-72. doi: 10.1002/ijc.28022 [doi]. PMID: 23319449.Exclusion Code: X7.23319449
59 Davison SL, Bell RJ, Robinson PJ, . Continuous-combined oral estradiol/drospirenone has no detrimental effect on cognitive performance and improves estrogen deficiency symptoms in early postmenopausal women: a randomized placebo-controlled trial. Menopause. 2013 Oct;20(10):1020-6. doi: 10.1097/GME.0b013e318287474f [doi]. PMID: 23591255.Exclusion Code: X6.23591255
60 De Franciscis P, Luisi A, Matteo M, . Hormone replacement therapy and mild cognitive impairment in postmenopause. Giornale Italiano di Ostetricia e Ginecologia. 2013;35(3):457-61.Exclusion Code: X3.
61 de Villiers TJ, Stevenson JC. The WHI: the effect of hormone replacement therapy on fracture prevention. Climacteric. 2012 Jun;15(3):263-6. doi: 10.3109/13697137.2012.659975 [doi]. PMID: 22612613.Exclusion Code: X2.22612613
62 Della Martina M, Xodo S, Vogrig E, . [Hormone replacement therapy and urogenital disease in postmenopausal women]. Minerva Ginecol. 2012 Aug;64(4):337-44. doi: R09123306 [pii]. PMID: 22728578.Exclusion Code: X1.22728578
63 Demetrio FN, Renno J, Jr., Gianfaldoni A, . Effect of estrogen replacement therapy on symptoms of depression and anxiety in non-depressive menopausal women: a randomized double-blind, controlled study. Arch Womens Ment Health. 2011 Dec;14(6):479-86. doi: 10.1007/s00737-011-0241-3 [doi]. PMID: 22016254.Exclusion Code: X6.22016254
64 Depypere H, Everaert K, De Pauw M, . Considerations on hormone replacement therapy in women over 60 years of age. Tijdschrift voor Geneeskunde. 2014;70(19):1089-97.Exclusion Code: X1.
65 Doty RL, Tourbier I, Ng V, . Influences of hormone replacement therapy on olfactory and cognitive function in postmenopausal women. Neurobiol Aging. 2015 Jun;36(6):2053-9. doi: 10.1016/j.neurobiolaging.2015.02.028. PMID: 25850354.Exclusion Code: X6.25850354
66 Dumas JA, Kutz AM, Naylor MR, . Estradiol treatment altered anticholinergic-related brain activation during working memory in postmenopausal women. Neuroimage. 2012 Apr 2;60(2):1394-403. doi: 10.1016/j.neuroimage.2012.01.043. PMID: 22266175.Exclusion Code: X6.22266175
67 Espeland MA, Brinton RD, Hugenschmidt C, . Impact of Type 2 Diabetes and Postmenopausal Hormone Therapy on Incidence of Cognitive Impairment in Older Women. Diabetes Care. 2015 Dec;38(12):2316-24. doi: 10.2337/dc15-1385. PMID: 26486190.Exclusion Code: X7.26486190
68 Espeland MA, Brinton RD, Manson JE, . Postmenopausal hormone therapy, type 2 diabetes mellitus, and brain volumes. Neurology. 2015 Sep 29;85(13):1131-8. doi: 10.1212/WNL.0000000000001816. PMID: 26163429.Exclusion Code: X10.26163429
69 Farhat GN, Parimi N, Chlebowski RT, . Sex hormone levels and risk of breast cancer with estrogen plus progestin. J Natl Cancer Inst. 2013 Oct 2;105(19):1496-503. doi: 10.1093/jnci/djt243. PMID: 24041978.Exclusion Code: X13.24041978
70 Felix AS, Arem H, Trabert B, . Menopausal hormone therapy and mortality among endometrial cancer patients in the NIH-AARP Diet and Health Study. Cancer Causes Control. 2015 Aug;26(8):1055-63. doi: 10.1007/s10552-015-0598-0 [doi]. PMID: 25962764.Exclusion Code: X3.25962764
71 Ferenczy A, Gelfand MM, van de Weijer PH, . Endometrial safety and bleeding patterns during a 2-year study of 1 or 2 mg 17 beta-estradiol combined with sequential 5-20 mg dydrogesterone. Climacteric. 2002 Mar;5(1):26-35. PMID: 11974556.Exclusion Code: X10.11974556
72 Fischer B, Gleason C, Asthana S. Effects of hormone therapy on cognition and mood. Fertil Steril. 2014 Apr;101(4):898-904. doi: 10.1016/j.fertnstert.2014.02.025. PMID: 24680649.Exclusion Code: X2.24680649
73 Flores VA, Taylor HS. The Effect of Menopausal Hormone Therapies on Breast Cancer: Avoiding the Risk. Endocrinol Metab Clin North Am. 2015 Sep;44(3):587-602. doi: 10.1016/j.ecl.2015.05.007. PMID: 26316245.Exclusion Code: X7.26316245
74 Fournier JP, Duijnhoven RG, Renoux C, . Concurrent use of statins and hormone therapy and risk of venous thromboembolism in postmenopausal women: a population-based case-control study. Menopause. 2014 Sep;21(9):1023-6. doi: 10.1097/GME.0000000000000279 [doi]. PMID: 24937027.Exclusion Code: X7.24937027
75 Frechette D, Paquet L, Verma S, . The impact of endocrine therapy on sexual dysfunction in postmenopausal women with early stage breast cancer: encouraging results from a prospective study. Breast Cancer Res Treat. 2013 Aug;141(1):111-7. doi: 10.1007/s10549-013-2659-y [doi]. PMID: 23942873.Exclusion Code: X3.23942873
76 Gallagher JC. Estrogen treatment does not reduce fractures. Menopause. 2014;21(2):111-2.Exclusion Code: X2.24448107
77 Gast GC, Pop VJ, Samsioe GN, . Hormone therapy and coronary heart disease risk by vasomotor menopausal symptoms. Maturitas. 2011 Dec;70(4):373-8. doi: 10.1016/j.maturitas.2011.09.005. PMID: 21978631.Exclusion Code: X6.21978631
78 Gavrilova NP, Seliverstov PV, Tatarova NA, . [Approaches to the treatment of patients with climacteric disorders complicated with menopausal metabolic syndrome with cholestasis]. Eksp Klin Gastroenterol. 2014(8):34-40. PMID: 25911910.Exclusion Code: X1.25911910
79 Genazzani AR, Simoncini T. Pharmacotherapy: Benefits of menopausal hormone therapy--timing is key. Nat Rev Endocrinol. 2013 Jan;9(1):5-6. doi: 10.1038/nrendo.2012.228. PMID: 23183673.Exclusion Code: X2.23183673
80 Giordano S, Hage FG, Xing D, . Estrogen and cardiovascular disease: Is timing everything Am J Med Sci. 2015;350(1):27-35.Exclusion Code: X2.26110752
81 Gorenstein C, Renno J, Jr., Vieira Filho AH, . Estrogen replacement therapy and cognitive functions in healthy postmenopausal women: a randomized trial. Arch Womens Ment Health. 2011 Oct;14(5):367-73. doi: 10.1007/s00737-011-0230-6 [doi]. PMID: 21732218.Exclusion Code: X12.21732218
82 Gu H, Zhao X, Yang Y, . Risk of stroke in healthy postmenopausal women during and after hormone therapy: a meta-analysis. Menopause. 2014 Nov;21(11):1204-10. doi: 10.1097/GME.0000000000000227 [doi]. PMID: 24686450.Exclusion Code: X7.24686450
83 Guallar E, Manson JE, Laine C, . Postmenopausal hormone therapy: the heart of the matter. Ann Intern Med. 2013 Jan 1;158(1):69-70. doi: 10.7326/0003-4819-158-1-201301010-00015. PMID: 23277904.Exclusion Code: X2.23277904
84 Haines CJ, Yim SF, Chung TK, . A prospective, randomized, placebo-controlled study of the dose effect of oral oestradiol on menopausal symptoms, psychological well being, and quality of life in postmenopausal Chinese women. Maturitas. 2003 Mar 28;44(3):207-14. PMID: 12648884.Exclusion Code: X10.12648884
85 Harman SM. Menopausal hormone treatment cardiovascular disease: another look at an unresolved conundrum. Fertil Steril. 2014 Apr;101(4):887-97. doi: 10.1016/j.fertnstert.2014.02.042. PMID: 24680648.Exclusion Code: X2.24680648
86 Harman SM, Vittinghoff E, Brinton EA, . Timing and duration of menopausal hormone treatment may affect cardiovascular outcomes. Am J Med. 2011 Mar;124(3):199-205. doi: 10.1016/j.amjmed.2010.09.021. PMID: 21396500.Exclusion Code: X2.21396500
87 Hautamaki H, Mikkola TS, Sovijarvi AR, . Menopausal hot flushes do not associate with changes in heart rate variability in controlled testing: a randomized trial on hormone therapy. Acta Obstet Gynecol Scand. 2013 Aug;92(8):902-8. doi: 10.1111/aogs.12164 [doi]. PMID: 23656530.Exclusion Code: X6.23656530
88 Hays J, Hunt JR, Hubbell FA, . The Women's Health Initiative recruitment methods and results. Ann Epidemiol. 2003 Oct;13(9 Suppl):S18-77. PMID: 14575939.Exclusion Code: X8.14575939
89 Hein A, Thiel FC, Bayer CM, . Hormone replacement therapy and prognosis in ovarian cancer patients. Eur J Cancer Prev. 2013 Jan;22(1):52-8. doi: 10.1097/CEJ.0b013e328355ec22 [doi]. PMID: 22694828.Exclusion Code: X2.22694828
90 Hemminki E, Hovi SL, Veerus P, . Blinding decreased recruitment in a prevention trial of postmenopausal hormone therapy. J Clin Epidemiol. 2004 Dec;57(12):1237-43. doi: 10.1016/j.jclinepi.2004.04.009. PMID: 15617949.Exclusion Code: X10.15617949
91 Henderson VW. Alzheimer's disease: review of hormone therapy trials and implications for treatment and prevention after menopause. J Steroid Biochem Mol Biol. 2014 Jul;142:99-106. doi: 10.1016/j.jsbmb.2013.05.010. PMID: 23727128.Exclusion Code: X2.23727128
92 Hickey M, Elliott J, Davison SL. Hormone replacement therapy. BMJ. 2012;344:e763. PMID: 22344303.Exclusion Code: X2.22344303
93 Hodis HN, Mack WJ. The timing hypothesis and hormone replacement therapy: a paradigm shift in the primary prevention of coronary heart disease in women. Part 2: comparative risks. J Am Geriatr Soc. 2013 Jun;61(6):1011-8. doi: 10.1111/jgs.12281 [doi]. PMID: 23692449.Exclusion Code: X2.23692449
94 Hodis HN, Mack WJ, Henderson VW, . Vascular Effects of Early versus Late Postmenopausal Treatment with Estradiol. N Engl J Med. 2016 Mar 31;374(13):1221-31. doi: 10.1056/NEJMoa1505241 [doi]. PMID: 27028912.Exclusion Code: X11.27028912
95 Hoibraaten E, Qvigstad E, Arnesen H, . Increased risk of recurrent venous thromboembolism during hormone replacement therapy--results of the randomized, double-blind, placebo-controlled estrogen in venous thromboembolism trial (EVTET). Thromb Haemost. 2000 Dec;84(6):961-7. PMID: 11154141.Exclusion Code: X3.11154141
96 Hou N, Hong S, Wang W, . Hormone replacement therapy and breast cancer: heterogeneous risks by race, weight, and breast density. J Natl Cancer Inst. 2013 Sep 18;105(18):1365-72. doi: 10.1093/jnci/djt207. PMID: 24003037.Exclusion Code: X2.24003037
97 Hulley SG, D; Bush, T; Furberg, C; Herrington, D; Riggs, B; Vittinghoff, E. Randomized Trial of Estrogen Plus Progestin for Secondary Prevention of Coronary Heart Disease in Postmenopausal Women. Obstet Gynecol Surv. 1999;54(1):41-2.Exclusion Code: X2.
98 Jaakkola S, Lyytinen HK, Dyba T, . Endometrial cancer associated with various forms of postmenopausal hormone therapy: a case control study. Int J Cancer. 2011 Apr 1;128(7):1644-51. doi: 10.1002/ijc.25762. PMID: 21280035.Exclusion Code: X7.21280035
99 Jaakkola S, Pukkala E, H KL, . Postmenopausal estradiol-progestagen therapy and risk for uterine cervical cancer. Int J Cancer. 2012 Aug 15;131(4):E537-43. doi: 10.1002/ijc.27321 [doi]. PMID: 22024969.Exclusion Code: X4.22024969
100 Justenhoven C, Obazee O, Winter S, . The postmenopausal hormone replacement therapy-related breast cancer risk is decreased in women carrying the CYP2C19*17 variant. Breast Cancer Res Treat. 2012 Jan;131(1):347-50. doi: 10.1007/s10549-011-1827-1 [doi]. PMID: 22037784.Exclusion Code: X2.22037784
101 Kabat GC, Kim MY, Luo J, . Menstrual and reproductive factors and exogenous hormone use and risk of transitional cell bladder cancer in postmenopausal women. Eur J Cancer Prev. 2013 Sep;22(5):409-16. doi: 10.1097/CEJ.0b013e32835f3ba3 [doi]. PMID: 23442343.Exclusion Code: X7.23442343
102 Kang JH, Grodstein F. Postmenopausal hormone therapy, timing of initiation, APOE and cognitive decline. Neurobiol Aging. 2012 Jul;33(7):1129-37. doi: 10.1016/j.neurobiolaging.2010.10.007. PMID: 21122949.Exclusion Code: X12.21122949
103 Karim R, Dell RM, Greene DF, . Hip fracture in postmenopausal women after cessation of hormone therapy: results from a prospective study in a large health management organization. Menopause. 2011 Nov;18(11):1172-7. doi: 10.1097/gme.0b013e31821b01c7 [doi]. PMID: 21775911.Exclusion Code: X4.21775911
104 Kass-Wolff JH, Fisher JE. Menopause and the hormone controversy: clarification or confusion? Nurse Pract. 2011 Jul;36(7):22-9; quiz 9-30. doi: 10.1097/01.NPR.0000398779.49929.40 [doi]. PMID: 21642886.Exclusion Code: X2.21642886
105 Kaygusuz I, Gumus, II, Yuvaci HU, . Does hormone replacement therapy have beneficial effects on renal functions in menopausal women? Arch Gynecol Obstet. 2012 Jun;285(6):1643-6. doi: 10.1007/s00404-012-2215-8 [doi]. PMID: 22246479.Exclusion Code: X9.22246479
106 Keaney JF, Jr., Solomon CG. Postmenopausal Hormone Therapy and Atherosclerosis--Time Is of the Essence. N Engl J Med. 2016 Mar 31;374(13):1279-80. doi: 10.1056/NEJMe1602846 [doi]. PMID: 27028919.Exclusion Code: X2.27028919
107 Khalili H, Higuchi LM, Ananthakrishnan AN, . Hormone therapy increases risk of ulcerative colitis but not Crohn's disease. Gastroenterology. 2012 Nov;143(5):1199-206. doi: 10.1053/j.gastro.2012.07.096. PMID: 22841783.Exclusion Code: X7.22841783
108 Kim C, Golden SH, Kong S, . Does hormone therapy affect blood pressure changes in the diabetes prevention program? Menopause. 2014;21(5):477-83.Exclusion Code: X9.23942251
109 Knowlton AA. Estrogen and cardiovascular disease: aging and estrogen loss at the heart of the matter? Future Cardiol. 2012 Jan;8(1):9-12. doi: 10.2217/fca.11.84 [doi]. PMID: 22185441.Exclusion Code: X2.22185441
110 Koskela-Niska V, Lyytinen H, Riska A, . Ovarian cancer risk in postmenopausal women using estradiol-progestin therapy - a nationwide study. Climacteric. 2013 Feb;16(1):48-53. doi: 10.3109/13697137.2012.663818 [doi]. PMID: 22640598.Exclusion Code: X6.22640598
111 Koskela-Niska V, Pukkala E, Lyytinen H, . Effect of various forms of postmenopausal hormone therapy on the risk of ovarian cancer--a population-based case control study from Finland. Int J Cancer. 2013 Oct 1;133(7):1680-8. doi: 10.1002/ijc.28167 [doi]. PMID: 23526244.Exclusion Code: X7.23526244
112 Lambrinoudaki I. Progestogens in postmenopausal hormone therapy and the risk of breast cancer. Maturitas. 2014 Apr;77(4):311-7. doi: 10.1016/j.maturitas.2014.01.001. PMID: 24485796.Exclusion Code: X2.24485796
113 Lambrinoudaki I, Perez-Lopez FR. Hormone therapy and the prevention of cardiovascular disease and cognitive decline: where do we stand? Maturitas. 2013 Feb;74(2):107-8. doi: 10.1016/j.maturitas.2012.11.008. PMID: 23265306.Exclusion Code: X2.23265306
114 Lauer MS. Investing in clinical science: make way for (not-so-uncommon) outliers. Ann Intern Med. 2014 May 6;160(9):651-2. doi: 10.7326/M14-0655. PMID: 24798528.Exclusion Code: X2.24798528
115 Lavasani S, Chlebowski RT, Prentice RL, . Estrogen and colorectal cancer incidence and mortality. Cancer. 2015 Sep 15;121(18):3261-71. doi: 10.1002/cncr.29464. PMID: 26036212.Exclusion Code: X7.26036212
116 Lee E, Horn-Ross PL, Rull RP, . Reproductive factors, exogenous hormones, and pancreatic cancer risk in the CTS. Am J Epidemiol. 2013 Nov 1;178(9):1403-13. doi: 10.1093/aje/kwt154. PMID: 24008905.Exclusion Code: X7.24008905
117 L'Hermite M. HRT optimization, using transdermal estradiol plus micronized progesterone, a safer HRT. Climacteric. 2013 Aug;16 Suppl 1:44-53. doi: 10.3109/13697137.2013.808563 [doi]. PMID: 23848491.Exclusion Code: X2.23848491
118 Limsui D, Vierkant RA, Tillmans LS, . Postmenopausal hormone therapy and colorectal cancer risk by molecularly defined subtypes among older women. Gut. 2012 Sep;61(9):1299-305. doi: 10.1136/gutjnl-2011-300719. PMID: 22027477.Exclusion Code: X7.22027477
119 Lindenfeld EA, Langer RD. Bleeding patterns of the hormone replacement therapies in the postmenopausal estrogen and progestin interventions trial. Obstet Gynecol. 2002 Nov;100(5 Pt 1):853-63. PMID: 12423841.Exclusion Code: X10.12423841
120 Lisabeth L, Bushnell C. Stroke risk in women: the role of menopause and hormone therapy. Lancet Neurol. 2012 Jan;11(1):82-91. doi: 10.1016/S1474-4422(11)70269-1. PMID: 22172623.Exclusion Code: X2.22172623
121 Liu R, Baird D, Park Y, . Female reproductive factors, menopausal hormone use, and Parkinson's disease. Mov Disord. 2014 Jun;29(7):889-96. doi: 10.1002/mds.25771 [doi]. PMID: 24352877.Exclusion Code: X7.24352877
122 Luo J, Cochrane BB, Wactawski-Wende J, . Effects of menopausal hormone therapy on ductal carcinoma in situ of the breast. Breast Cancer Res Treat. 2013 Feb;137(3):915-25. doi: 10.1007/s10549-012-2402-0 [doi]. PMID: 23315265.Exclusion Code: X10.23315265
123 Ma Y, Hebert JR, Balasubramanian R, . All-cause, cardiovascular, and cancer mortality rates in postmenopausal white, black, Hispanic, and Asian women with and without diabetes in the United States: the Women's Health Initiative, 1993-2009. Am J Epidemiol. 2013 Nov 15;178(10):1533-41. doi: 10.1093/aje/kwt177. PMID: 24045960.Exclusion Code: X4.24045960
124 Main C, Knight B, Moxham T, . Hormone therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database Syst Rev. 2013;4:CD002229. doi: 10.1002/14651858.CD002229.pub3 [doi]. PMID: 23633307.Exclusion Code: X8.23633307
125 Maki PM. Women and memory. Menopause. 2015 Jan;22(1):4-5. doi: 10.1097/GME.0000000000000386 [doi]. PMID: 25490115.Exclusion Code: X2.25490115
126 Manson J, Branch H. The women's health initiative: the latest findings from long-term follow-up. Womens Health (Lond Engl). 2014 Mar;10(2):125-8. doi: 10.2217/whe.14.6 [doi]. PMID: 24601803.Exclusion Code: X2.24601803
127 Manson JE. The ‘timing hypothesis’ for estrogen therapy in menopausal symptom management. Womens Health (Lond). 2015 Jul;11(4):437-40. doi: 10.2217/WHE.15.24 [doi]. PMID: 26237097.Exclusion Code: X2.26237097
128 Manson JE, Kaunitz AM. Menopause Management--Getting Clinical Care Back on Track. N Engl J Med. 2016 Mar 3;374(9):803-6. doi: 10.1056/NEJMp1514242 [doi]. PMID: 26962899.Exclusion Code: X2.26962899
129 Marjoribanks J, Farquhar C, Roberts H, . Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2012;7:CD004143. doi: 10.1002/14651858.CD004143.pub4 [doi]. PMID: 22786488.Exclusion Code: X7.22786488
130 Marras C, Saunders-Pullman R. The complexities of hormonal influences and risk of Parkinson's disease. Mov Disord. 2014 Jun;29(7):845-8. doi: 10.1002/mds.25891 [doi]. PMID: 24789470.Exclusion Code: X2.24789470
131 Matthews KA, Shumaker SA, Bowen DJ, . Women's health initiative. Why now? What is it? What's new? Am Psychol. 1997 Feb;52(2):101-16. PMID: 9104085.Exclusion Code: X7.9104085
132 McCarrey AC, Resnick SM. Postmenopausal hormone therapy and cognition. Horm Behav. 2015 Aug;74:167-72. doi: 10.1016/j.yhbeh.2015.04.018. PMID: 25935728.Exclusion Code: X2.25935728
133 McGlynn KA, Sahasrabuddhe VV, Campbell PT, . Reproductive factors, exogenous hormone use and risk of hepatocellular carcinoma among US women: Results from the Liver Cancer Pooling Project. Br J Cancer. 2015;112(7):1266-72.Exclusion Code: X4.25742475
134 Mikkola TS, Tuomikoski P, Lyytinen H, . Estradiol-based postmenopausal hormone therapy and risk of cardiovascular and all-cause mortality. Menopause. 2015 Sep;22(9):976-83. doi: 10.1097/GME.0000000000000450 [doi]. PMID: 25803671.Exclusion Code: X7.25803671
135 Moltz L, Holl RW. Low-dose transdermal therapy with estradiol and anti-androgen. Primary prevention of diabetes mellitus type 2 in the menopause. Gynakologische Endokrinologie. 2012;10(4):281-8.Exclusion Code: X1.
136 Morois S, Fournier A, Clavel-Chapelon F, . Menopausal hormone therapy and risks of colorectal adenomas and cancers in the French E3N prospective cohort: true associations or bias? Eur J Epidemiol. 2012 Jun;27(6):439-52. doi: 10.1007/s10654-012-9694-6 [doi]. PMID: 22644109.Exclusion Code: X4.22644109
137 Mosekilde L, Beck-Nielsen H, Sorensen OH, . Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women - results of the Danish Osteoporosis Prevention Study. Maturitas. 2000 Oct 31;36(3):181-93. PMID: 11063900.Exclusion Code: X14.11063900
138 Mulnard RA, Cotman CW, Kawas C, . Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: a randomized controlled trial. Alzheimer's Disease Cooperative Study. JAMA. 2000 Feb 23;283(8):1007-15. PMID: 10697060.Exclusion Code: X3.10697060
139 Mychka VB, Kirillova MY, Kuznetsova IV, . Cardiovascular and metabolic effects of hormone therapy in perimenopausal women. Giornale Italiano di Ostetricia e Ginecologia. 2013;35(1):285-7.Exclusion Code: X12.
140 Nachtigall LE, Nachtigall RH, Nachtigall RD, . Estrogen replacement therapy ii: a prospective study in the relationship to carcinoma and cardiovascular and metabolic problems. Obstet Gynecol. 1979;54(1):74-9.Exclusion Code: X3.221871
141 Nair GV, Herrington DM. The ERA trial: findings and implications for the future. Climacteric. 2000 Dec;3(4):227-32. PMID: 11910581.Exclusion Code: X2.11910581
142 Nelson HD. Menopausal hormone therapy and primary prevention. Ann Intern Med. 2013 Jan 15;158(2):141. doi: 10.7326/0003-4819-158-2-201301150-00022. PMID: 23318326.Exclusion Code: X2.23318326
143 Ni XJ, Xia TS, Zhao YC, . Postmenopausal hormone therapy is associated with in situ breast cancer risk. Asian Pac J Cancer Prev. 2012;13(8):3917-25. PMID: 23098493.Exclusion Code: X7.23098493
144 Nielsen TF, Ravn P, Pitkin J, . Pulsed estrogen therapy improves postmenopausal quality of life: a 2-year placebo-controlled study. Maturitas. 2006 Jan 20;53(2):184-90. doi: 10.1016/j.maturitas.2005.04.003. PMID: 16368471.Exclusion Code: X4.16368471
145 Nordenvall C, Oskarsson V, Sadr-Azodi O, . Postmenopausal hormone replacement therapy and risk of cholecystectomy: a prospective cohort study. Scand J Gastroenterol. 2014 Jan;49(1):109-13. doi: 10.3109/00365521.2013.858180 [doi]. PMID: 24256204.Exclusion Code: X7.24256204
146 Northington GM, de Vries HF, Bogner HR. Self-reported estrogen use and newly incident urinary incontinence among postmenopausal community-dwelling women. Menopause. 2012 Mar;19(3):290-5. doi: 10.1097/gme.0b013e31822bda11 [doi]. PMID: 21997497.Exclusion Code: X9.21997497
147 Notelovitz M, John VA, Good WR. Effectiveness of Alora estradiol matrix transdermal delivery system in improving lumbar bone mineral density in healthy, postmenopausal women. Menopause. 2002 Sep-Oct;9(5):343-53. PMID: 12218723.Exclusion Code: X14.12218723
148 Nyante SJ, Dallal CM, Gierach GL, . Risk factors for specific histopathological types of postmenopausal breast cancer in the NIH-AARP Diet and Health Study. Am J Epidemiol. 2013 Aug 1;178(3):359-71. doi: 10.1093/aje/kws471. PMID: 23899816.Exclusion Code: X5.23899816
149 Obel EB, Munk-Jensen N, Svenstrup B, . A two-year double-blind controlled study of the clinical effect of combined and sequential postmenopausal replacement therapy and steroid metabolism during treatment. Maturitas. 1993 Jan;16(1):13-21. PMID: 8429800.Exclusion Code: X6.8429800
150 O'Brien J, Jackson JW, Grodstein F, . Postmenopausal hormone therapy is not associated with risk of all-cause dementia and Alzheimer's disease. Epidemiol Rev. 2014;36:83-103. doi: 10.1093/epirev/mxt008. PMID: 24042430.Exclusion Code: X7.24042430
151 Oliveira VM, Aldrighi JM, Gebara OC. So, now what? what are the risks of breast cancer and myocardial infarction among women receiving hormonal replacement therapy after menopause? Rev Assoc Med Bras. 2011 Jul-Aug;57(4):355-7. doi: S0104-42302011000400003 [pii]. PMID: 21876911.Exclusion Code: X2.21876911
152 Panay N, Fenton A. Does HRT increase the risk of breast cancer? Don't forget the menopausal woman! Climacteric. 2012 Apr;15(2):103-4. doi: 10.3109/13697137.2012.665224 [doi]. PMID: 22420566.Exclusion Code: X2.22420566
153 Panay N, Hamoda H, Arya R, . The 2013 British Menopause Society & Women's Health Concern recommendations on hormone replacement therapy. Menopause Int. 2013 Jun;19(2):59-68. doi: 10.1177/1754045313489645. PMID: 23761319.Exclusion Code: X2.23761319
154 Paoletti AM, Cagnacci A, Di Carlo C, . Clinical effect of hormonal replacement therapy with estradiol associated with noretisterone or drospirenone. A prospective randomized placebo controlled study. Gynecol Endocrinol. 2015;31(5):384-7.Exclusion Code: X11.25703254
155 Pefanco MA, Kenny AM, Kaplan RF, . The effect of 3-year treatment with 0.25 mg/day of micronized 17beta-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. 2007 Mar;55(3):426-31. doi: 10.1111/j.1532-5415.2007.01085.x. PMID: 17341247.Exclusion Code: X14.17341247
156 Perello MF, Peguero A, Ros C, . Spinal fractures after hormone therapy during menopause: A 20-year follow-up. [Spanish]. Progresos de Obstetricia y Ginecologia; 2013. p. 462-6.Exclusion Code: X1.
157 Pesatori AC, Carugno M, Consonni D, . Hormone use and risk for lung cancer: A pooled analysis from the International Lung Cancer Consortium (ILCCO). Br J Cancer. 2013;109(7):1954-64.Exclusion Code: X7.24002594
158 Pickar JH. Age at menopause, reproductive history and VTE risk. Climacteric. 2013 Dec;16(6):723. PMID: 24383093.Exclusion Code: X2.24383093
159 Pickar JH, Komm BS. Selective estrogen receptor modulators and the combination therapy conjugated estrogens/bazedoxifene: A review of effects on the breast. Post Reprod Health. 2015 Sep;21(3):112-21. doi: 10.1177/2053369115599090 [doi]. PMID: 26289836.Exclusion Code: X4.26289836
160 Pines A. Downside of preventive therapies in menopause. Menopause. 2014 Mar;21(3):207-8. doi: 10.1097/GME.0000000000000135 [doi]. PMID: 24193299.Exclusion Code: X2.24193299
161 Pines A. Primary prevention of stroke in women. Climacteric. 2014;17(3):312-3.Exclusion Code: X2.
162 Pinkerton JV, Abraham L, Bushmakin AG, . Evaluation of the efficacy and safety of bazedoxifene/conjugated estrogens for secondary outcomes including vasomotor symptoms in postmenopausal women by years since menopause in the Selective estrogens, Menopause and Response to Therapy (SMART) trials. J Womens Health (Larchmt). 2014 Jan;23(1):18-28. doi: 10.1089/jwh.2013.4392 [doi]. PMID: 24206058.Exclusion Code: X4.24206058
163 Polac I, Borowiecka M, Wilamowska A, . Coagulation and fibrynolitic parameters in women and the effects of hormone therapy; comparison of transdermal and oral administration. Gynecol Endocrinol. 2013 Feb;29(2):165-8. doi: 10.3109/09513590.2012.730567 [doi]. PMID: 23116237.Exclusion Code: X5.23116237
164 Racketa J, Pinkerton JV, Pan K, . Effects of bazedoxifene/conjugated estrogens on sleep parameters and health-related quality of life in postmenopausal women. Maturitas; 2012. p. S59-S60 Abstract no:137.Exclusion Code: X2.
165 Rahn DD, Carberry C, Sanses TV, . Vaginal estrogen for genitourinary syndrome of menopause: a systematic review. Obstet Gynecol. 2014 Dec;124(6):1147-56. doi: 10.1097/AOG.0000000000000526. PMID: 25415166.Exclusion Code: X4.25415166
166 Rasgon NL, Geist CL, Kenna HA, . Prospective randomized trial to assess effects of continuing hormone therapy on cerebral function in postmenopausal women at risk for dementia. PLoS One. 2014;9(3):e89095. doi: 10.1371/journal.pone.0089095. PMID: 24622517.Exclusion Code: X7.24622517
167 Reid RL, Fortier MP. Menopausal hormone therapy and quality of life: too many pyjamas. J Obstet Gynaecol Can. 2014 Nov;36(11):953-6. PMID: 25574670.Exclusion Code: X2.25574670
168 Roberts H, Hickey M, Lethaby A. Hormone therapy in postmenopausal women and risk of endometrial hyperplasia: a Cochrane review summary. Maturitas. 2014 Jan;77(1):4-6. doi: 10.1016/j.maturitas.2013.10.002. PMID: 24182544.Exclusion Code: X2.24182544
169 Rocca WA, Shuster LT, Brown RD. Could estrogen protect younger menopausal women from stroke? Expert Rev Neurother. 2012 Apr;12(4):363-5. doi: 10.1586/ern.12.20 [doi]. PMID: 22449208.Exclusion Code: X2.22449208
170 Rockman CB, Maldonado TS, Jacobowitz GR, . Hormone replacement therapy is associated with a decreased prevalence of peripheral arterial disease in postmenopausal women. Ann Vasc Surg. 2012 Apr;26(3):411-8. doi: 10.1016/j.avsg.2011.10.012 PMID: 22285341.Exclusion Code: X7.22285341
171 Rosano G, Vitale C. Cardiovascular benefits of HRT may differ by patient age. Evid Based Med. 2014 Apr;19(2):61. doi: 10.1136/eb-2013-101430. PMID: 24113233.Exclusion Code: X2.24113233
172 Rosano G, Vitale C, Spoletini I, . Cardiovascular health in the menopausal woman: impact of the timing of hormone replacement therapy. Climacteric. 2012 Aug;15(4):299-305. doi: 10.3109/13697137.2012.658899 [doi]. PMID: 22424090.Exclusion Code: X2.22424090
173 Rosenberg L, Bethea TN, Viscidi E, . Postmenopausal Female Hormone Use and Estrogen Receptor-Positive and -Negative Breast Cancer in African American Women. J Natl Cancer Inst. 2016 Apr;108(4)doi: 10.1093/jnci/djv361. PMID: 26613937.Exclusion Code: X7.26613937
174 Rossouw J. Design of the Women's Health Initiative clinical trial and observational study. The Women's Health Initiative Study Group. Control Clin Trials. 1998 Feb;19(1):61-109. PMID: 9492970.Exclusion Code: X13.9492970
175 Ruan X. Type, dose of hormones-Breast cancer risk. Eur J Contracept Reprod Health Care; 2014. p. S20.Exclusion Code: X2.
176 Rubinow DR, Girdler SS. Hormones, heart disease, and health: individualized medicine versus throwing the baby out with the bathwater. Depress Anxiety. 2011 Jun;28(6):E1-E15. doi: 10.1002/da.20833 [doi]. PMID: 21648024.Exclusion Code: X2.21648024
177 Sai AJ, Gallagher JC, Fang X. Effect of hormone therapy and calcitriol on serum lipid profile in postmenopausal older women: association with estrogen receptor-alpha genotypes. Menopause. 2011 Oct;18(10):1101-12. doi: 10.1097/gme.0b013e318217d41d. PMID: 21712736.Exclusion Code: X10.21712736
178 Sarri G, Davies M, Lumsden MA. Diagnosis and management of menopause: summary of NICE guidance. BMJ. 2015;351:h5746. PMID: 26563259.Exclusion Code: X2.26563259
179 Scarabin PY. Hormone therapy and venous thromboembolism among postmenopausal women. Front Horm Res. 2014;43:21-32. doi: 10.1159/000360554. PMID: 24943295.Exclusion Code: X2.24943295
180 Schaer TM. Menopausal hormone therapy and primary prevention. Ann Intern Med. 2013 Jan 15;158(2):140-1. doi: 10.7326/0003-4819-158-2-201301150-00021. PMID: 23318325.Exclusion Code: X2.23318325
181 Schierbeck LL, Rejnmark L, Tofteng CL, . Effect of hormone replacement therapy on cardiovascular events in recently postmenopausal women: randomised trial. BMJ. 2012;345:e6409. PMID: 23048011.Exclusion Code: X14.23048011
182 Schonfeld SJ, Ron E, Kitahara CM, . Hormonal and reproductive factors and risk of postmenopausal thyroid cancer in the NIH-AARP Diet and Health Study. Cancer Epidemiol. 2011 Dec;35(6):e85-90. doi: 10.1016/j.canep.2011.05.009. PMID: 21852218.Exclusion Code: X7.21852218
183 Scott E, Zhang QG, Wang R, . Estrogen neuroprotection and the critical period hypothesis. Front Neuroendocrinol. 2012 Jan;33(1):85-104. doi: 10.1016/j.yfrne.2011.10.001. PMID: 22079780.Exclusion Code: X2.22079780
184 Scott RG. Hormone therapy. Am J Nurs. 2011 Nov;111(11):12. doi: 10.1097/01.NAJ.0000407278.86759.6b. PMID: 22030905.Exclusion Code: X2.22030905
185 Shao H, Breitner JC, Whitmer RA, . Hormone therapy and Alzheimer disease dementia: new findings from the Cache County Study. Neurology. 2012 Oct 30;79(18):1846-52. doi: 10.1212/WNL.0b013e318271f823 PMID: 23100399.Exclusion Code: X9.23100399
186 Shapiro S. Risk of breast cancer among users of estrogen plus progestogen and unopposed estrogen: is the likelihood of bias symmetrical? Climacteric. 2015 Jun;18(3):333-5. doi: 10.3109/13697137.2015.1007623 [doi]. PMID: 25651904.Exclusion Code: X2.25651904
187 Shapiro S, Stevenson JC, Mueck AO, . Misrepresentation of the risk of ovarian cancer among women using menopausal hormones. Spurious findings in a meta-analysis. Maturitas. 2015 Jun;81(2):323-6. doi: 10.1016/j.maturitas.2015.03.018. PMID: 25891501.Exclusion Code: X2.25891501
188 Shufelt CL, Johnson BD, Berga SL, . Timing of hormone therapy, type of menopause, and coronary disease in women: data from the National Heart, Lung, and Blood Institute-sponsored Women's Ischemia Syndrome Evaluation. Menopause. 2011 Sep;18(9):943-50. doi: 10.1097/gme.0b013e3182113672. PMID: 21532511.Exclusion Code: X7.21532511
189 Shufelt CL, Merz CN, Prentice RL, . Hormone therapy dose, formulation, route of delivery, and risk of cardiovascular events in women: findings from the Women's Health Initiative Observational Study. Menopause. 2014 Mar;21(3):260-6. doi: 10.1097/GME.0b013e31829a64f9 [doi]. PMID: 24045672.Exclusion Code: X7.24045672
190 Shulman LP. The adverse impact of hormone therapy discontinuation on bone health: initiating a more balanced and comprehensive assessment of the impact and role of postmenopausal hormone therapy. Menopause. 2011 Nov;18(11):1152-3. doi: 10.1097/gme.0b013e31823639d4. PMID: 22033486.Exclusion Code: X2.22033486
191 Sjögren LL, Mørch LS, Løkkegaard E. Hormone replacement therapy and the risk of endometrial cancer: A systematic review. Maturitas 2016;91((Sjögren L.L., leasjogren@live.dk; Løkkegaard E.) Department of Obstetrics and Gynecology, Nordsjællands Hospital, University of Copenhagen, Denmark):25-35.Exclusion Code: X3.27451318
192 Skouby SO, Pan K, Thompson JR, . Effects of conjugated estrogens/bazedoxifene on lipid and coagulation variables: a randomized placebo- and active-controlled trial. Menopause. 2015 Jun;22(6):640-9. doi: 10.1097/GME.0000000000000362 [doi]. PMID: 25405570.Exclusion Code: X4.25405570
193 Spas'onova LH, Dmytruk SM, Medvedieva IM, . [Characteristics of proatherogenic disorder development in women with different reproductive status]. Lik Sprava. 2013 Jan-Feb(1):59-67. PMID: 23951911.Exclusion Code: X1.23951911
194 Speroff L. The heart and estrogen/progestin replacement study (HERS). Maturitas. 1998 Nov 30;31(1):9-14. PMID: 10091199.Exclusion Code: X2.10091199
195 Stanczyk FZ, Bhavnani BR. Use of medroxyprogesterone acetate for hormone therapy in postmenopausal women: is it safe? J Steroid Biochem Mol Biol. 2014 Jul;142:30-8. doi: 10.1016/j.jsbmb.2013.11.011. PMID: 24291402.Exclusion Code: X2.24291402
196 Stanczyk FZ, Winer SA. Effect of hormone therapy on breast epithelial cell proliferation. Menopause. 2013 May;20(5):483-5. doi: 10.1097/GME.0b013e31828ebfb6. PMID: 23615638.Exclusion Code: X2.23615638
197 Stegeman B, Kubinova R, Malyutina S, . Exogenous hormone use and all-cause mortality: Results from the HAPIEE study. Eur J Epidemiol. 2013;28(1):S193.Exclusion Code: X4.
198 Stendell-Hollis NR, Thompson PA, Thomson CA, . Investigating the association of lactation history and postmenopausal breast cancer risk in the Women's Health Initiative. Nutr Cancer. 2013;65(7):969-81. doi: 10.1080/01635581.2013.815787 [doi]. PMID: 24127779.Exclusion Code: X10.24127779
199 Stevenson JC, Panay N, Pexman-Fieth C. Oral estradiol and dydrogesterone combination therapy in postmenopausal women: review of efficacy and safety. Maturitas. 2013 Sep;76(1):10-21. doi: 10.1016/j.maturitas.2013.05.018. PMID: 23835005.Exclusion Code: X2.23835005
200 Stuenkel CA. Timing of menopausal hormone therapy and myocardial infarction. Menopause. 2015 Jun;22(6):584-6. doi: 10.1097/GME.0000000000000468 [doi]. PMID: 25871003.Exclusion Code: X2.25871003
201 Stute P. [Hormone therapy during peri- and postmenopause]. MMW Fortschr Med. 2014 Apr 30;156(8):37-9. PMID: 24851443.Exclusion Code: X1.24851443
202 Sullivan SD, Lehman A, Thomas F, . Effects of self-reported age at nonsurgical menopause on time to first fracture and bone mineral density in the Women's Health Initiative Observational Study. Menopause. 2015 Oct;22(10):1035-44. doi: 10.1097/GME.0000000000000451 [doi]. PMID: 25803670.Exclusion Code: X4.25803670
203 Sumino H, Murakami M. [Investigation of atherosclerosis in postmenopausal women: alteration of atherosclerosis-associated factors and vascular atherosclerosis by oral and transdermal estrogen replacement]. Rinsho Byori. 2013 Mar;61(3):256-62. PMID: 23785796.Exclusion Code: X1.23785796
204 Sweetland S, Beral V, Balkwill A, . Venous thromboembolism risk in relation to use of different types of postmenopausal hormone therapy in a large prospective study. J Thromb Haemost. 2012 Nov;10(11):2277-86. doi: 10.1111/j.1538-7836.2012.04919.x [doi]. PMID: 22963114.Exclusion Code: X7.22963114
205 Tanday S. Hormone therapy increases ovarian cancer risk. Lancet Oncol. 2015 Mar;16(3):e112. doi: 10.1016/S1470-2045(15)70038-0. PMID: 25704437.Exclusion Code: X2.25704437
206 Tang B, Lv J, Li Y, . Relationship between female hormonal and menstrual factors and pancreatic cancer: a meta-analysis of observational studies. Medicine (Baltimore). 2015 Feb;94(7):e177. doi: 10.1097/MD.0000000000000177. PMID: 25700305.Exclusion Code: X3.25700305
207 Teras LR, Patel AV, Hildebrand JS, . Postmenopausal unopposed estrogen and estrogen plus progestin use and risk of non-Hodgkin lymphoma in the American Cancer Society Cancer Prevention Study-II Cohort. Leuk Lymphoma. 2013 Apr;54(4):720-5. doi: 10.3109/10428194.2012.722216 [doi]. PMID: 22916741.Exclusion Code: X7.22916741
208 Trabert B, Wentzensen N, Yang HP, . Ovarian cancer and menopausal hormone therapy in the NIH-AARP diet and health study. Br J Cancer. 2012 Sep 25;107(7):1181-7. doi: 10.1038/bjc.2012.397. PMID: 22929888.Exclusion Code: X7.22929888
209 Tsilidis KK, Allen NE, Key TJ, . Menopausal hormone therapy and risk of ovarian cancer in the European prospective investigation into cancer and nutrition. Cancer Causes Control. 2011 Aug;22(8):1075-84. doi: 10.1007/s10552-011-9782-z [doi]. PMID: 21637986.Exclusion Code: X7.21637986
210 Tuomikoski P, Lyytinen H, Korhonen P, . Coronary heart disease mortality and hormone therapy before and after the Women's Health Initiative. Obstet Gynecol. 2014 Nov;124(5):947-53. doi: 10.1097/AOG.0000000000000461. PMID: 25437723.Exclusion Code: X7.25437723
211 Tuomikoski P, Mikkola TS. Postmenopausal hormone therapy and coronary heart disease in early postmenopausal women. Ann Med. 2014 Feb;46(1):1-7. doi: 10.3109/07853890.2013.854982 [doi]. PMID: 24266727.Exclusion Code: X2.24266727
212 Utian WH, Woods NF. Impact of hormone therapy on quality of life after menopause. Menopause. 2013 Oct;20(10):1098-105. doi: 10.1097/GME.0b013e318298debe [doi]. PMID: 23799357.Exclusion Code: X2.23799357
213 Valdiviezo C, Lawson S, Ouyang P. An update on menopausal hormone replacement therapy in women and cardiovascular disease. Curr Opin Endocrinol Diabetes Obes. 2013 Apr;20(2):148-55. doi: 10.1097/MED.0b013e32835ed58b [doi]. PMID: 23422240.Exclusion Code: X2.23422240
214 Veerus P, Fischer K, Hakama M, . Results from a blind and a non-blind randomised trial run in parallel: experience from the Estonian Postmenopausal Hormone Therapy (EPHT) Trial. BMC Med Res Methodol. 2012;12:44. doi: 10.1186/1471-2288-12-44. PMID: 22475112.Exclusion Code: X10.22475112
215 Veerus P, Fischer K, Hovi SL, . Symptom reporting and quality of life in the Estonian Postmenopausal Hormone Therapy Trial. BMC Womens Health. 2008;8:5. doi: 10.1186/1472-6874-8-5. PMID: 18366766.Exclusion Code: X10.18366766
216 Veerus P, Hovi SL, Sevon T, . The effect of hormone therapy on women's quality of life in the first year of the Estonian Postmenopausal Hormone Therapy trial. BMC Res Notes. 2012;5:176. doi: 10.1186/1756-0500-5-176. PMID: 22472039.Exclusion Code: X10.22472039
217 Viscoli CM, Brass LM, Kernan WN, . A clinical trial of estrogen-replacement therapy after ischemic stroke. N Engl J Med. 2001 Oct 25;345(17):1243-9. doi: 10.1056/NEJMoa010534. PMID: 11680444.Exclusion Code: X3.11680444
218 Vittinghoff E, Shlipak MG, Varosy PD, . Risk factors and secondary prevention in women with heart disease: the Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2003 Jan 21;138(2):81-9. PMID: 12529088.Exclusion Code: X3.12529088
219 Vorobjov S, Hovi SL, Veerus P, . Treatment adherence in the Estonian postmenopausal hormone therapy (EPHT) trial [ISRCTN35338757]. Maturitas. 2005 Nov-Dec;52(3-4):286-95. doi: 10.1016/j.maturitas.2005.05.001. PMID: 16055284.Exclusion Code: X10.16055284
220 Waetjen LE, Johnson WO, Xing G, . Serum estradiol levels are not associated with urinary incontinence in midlife women transitioning through menopause. Menopause. 2011 Dec;18(12):1283-90. doi: 10.1097/gme.0b013e31821f5d25 [doi]. PMID: 21785372.Exclusion Code: X4.21785372
221 Walker T. Rise in mortality risk seen in hysterectomized women aged 50 to 59 not using estrogen therapy. Formulary. 2013;48(8):254-5.Exclusion Code: X2.
222 Wein AJ. Re: Menopausal hormone therapy for the primary prevention of chronic conditions: a systematic review to update the U.S. Preventive Services Task Force recommendations. J Urol. 2013 Dec;190(6):2168-9. doi: 10.1016/j.juro.2013.08.106. PMID: 24209543.Exclusion Code: X2.24209543
223 Wein AJ. Re: Menopausal hormone therapy for the primary prevention of chronic conditions: a systematic review to update the U.S. Preventive Services Task Force recommendations. J Urol. 2013 Oct;190(4):1329. doi: 10.1016/j.juro.2013.06.108. PMID: 24029335.Exclusion Code: X2.24029335
224 Weinstein MM. Hormone therapy and urinary incontinence. Menopause. 2012 Mar;19(3):255-6. doi: 10.1097/gme.0b013e31824e9bb0. PMID: 22367730.Exclusion Code: X2.22367730
225 Weiping L, Chenxing L, Enfeng Z. Comment on ‘Effect of conjugated estrogen versus conjugated estrogen associated with medroxyprogesterone acetate in postmenopausal women on internal carotid artery pulsatility index: a randomized pilot study’. J Obstet Gynaecol Res. 2012 Mar;38(3):611-2. doi: 10.1111/j.1447-0756.2011.01751.x [doi]. PMID: 22353571.Exclusion Code: X2.22353571
226 Welton AJ, Vickers MR, Kim J, . Health related quality of life after combined hormone replacement therapy: randomised controlled trial. BMJ. 2008;337:a1190. doi: 10.1136/bmj.a1190. PMID: 18719013.Exclusion Code: X6.18719013
227 Wild RA, Wu C, Curb JD, . Coronary heart disease events in the Women's Health Initiative hormone trials: effect modification by metabolic syndrome: a nested case-control study within the Women's Health Initiative randomized clinical trials. Menopause. 2013 Mar;20(3):254-60. doi: 10.1097/GME.0b013e31826f80e0. PMID: 23435021.Exclusion Code: X2.23435021
228 Wilson LF, Page AN, Dunn NA, . Population attributable risk of modifiable risk factors associated with invasive breast cancer in women aged 45-69 years in Queensland, Australia. Maturitas. 2013 Dec;76(4):370-6. doi: 10.1016/j.maturitas.2013.09.002. PMID: 24113278.Exclusion Code: X9.24113278
229 Windler E, Stute P, Ortmann O, . Is postmenopausal hormone replacement therapy suitable after a cardio- or cerebrovascular event? Arch Gynecol Obstet. 2015 Jan;291(1):213-7. doi: 10.1007/s00404-014-3485-0 [doi]. PMID: 25322975.Exclusion Code: X2.25322975
230 Xu Y, Lin J, Wang S, . Combined estrogen replacement therapy on metabolic control in postmenopausal women with diabetes mellitus. Kaohsiung J Med Sci. 2014 Jul;30(7):350-61. doi: 10.1016/j.kjms.2014.03.002. PMID: 24924841.Exclusion Code: X11.24924841
231 Zhu Y, Yue D, Yuan B, . Reproductive factors are associated with oesophageal cancer risk: results from a meta-analysis of observational studies. Eur J Cancer Prev. 2016 Feb 16doi: 10.1097/CEJ.0000000000000234. PMID: 26886236.26886236
232 Ziaei S. The effects of HRT on cognitive function in postmenopausal women Tarbiat Modares University. Tehran, Iran: 2016. Exclusion Code: X12.
233 Ziller M, Herwig J, Ziller V, . Effects of a low-dose oral estrogen only treatment on bone mineral density and quantitative ultrasonometry in postmenopausal women. Gynecol Endocrinol. 2012 Dec;28(12):1002-5. doi: 10.3109/09513590.2012.705369 [doi]. PMID: 22835159.Exclusion Code: X3.22835159