# Appendix D Literature Flow Diagram

a We conducted searches of PubMed/MEDLINE, the Cochrane Library, EMBASE, International Pharmaceutical Abstracts, ClinicalTrials.gov, Drugs@FDA.gov, the Health Services Research Projects in Process (HSRProj), and the World Health Organization International Clinical Trials Registry Platform (WHO ICTRP).

Abbreviations: KQs = Key Questions; N = number.

Appendix D is the preferred reporting of systematic review and meta-analysis (PRISMA) tree that summarizes the search and selection of articles. There were 2,241 new references identified through database searching (after duplicates removed), resulting in a total of 6,765 references when added to those from the previous review. The titles and abstracts of the new references were screened for potential inclusion. Of these, 1,989 were excluded and 252 were deemed appropriate for full-text review to determine eligibility. After full-text review, 235 were excluded: 8 for non-English language, 92 for publication type, 14 for ineligible population, 22 for ineligible intervention, 4 for ineligible indication, 13 for ineligible duration, 43 for ineligible design, 6 for ineligible sample size, 2 were superseded by a more recent review, 14 had irrelevant outcomes, 5 for intermediate outcomes, 5 for ineligible setting, 2 for not answering the KQs, and 5 for poor quality. Nine additional trials of fair or good quality were synthesized with the previous review, resulting in total of 18 trials. These trials were represented in 17 new publications, bringing the total number of included articles from both reviews to 68.