# Appendix B Inclusion and Exclusion Criteria

| Include | Exclude
Population | Generally healthy perimenopausal and postmenopausal women who are eligible for menopausal hormone therapy; women with and without menopausal symptoms will be included if the focus of the analysis is on the prevention of chronic conditions | Animals; men; premenopausal women; postmenopausal women with contraindications for hormone therapy use, such as history of breast cancer, coronary heart disease, previous venous thromboembolic event or stroke, active liver disease, or women who are at high risk of these complications; populations that are not applicable to U.S. primary care
Interventions | Systemic therapy with estrogen-only formulations or estrogen plus progestin for the prevention of chronic conditions; U.S. Food and Drug Administration–approved medications that are available for use in the United States | Localized (nonsystemic) treatments, such as rings or gels, contraceptives, and other hormones or treatments of menopausal symptoms (such as over-the-counter preparations that are not approved by the U.S. Food and Drug Administration)
Comparators | Placebo, no treatment | Active comparator
Outcomes | KQ 1/2: Benefits and harms Cancer (breast, cervical, colorectal, endometrial, nonsmall cell lung, and ovarian) Coronary heart disease Cognitive functioning and dementia Diabetes Gallbladder disease Fractures Stroke Urinary incontinence Venus thromboembolism Quality of life (if related to chronic conditions of interest) Functional capacity All-cause mortality Disease-specific mortality (if related to chronic conditions of interest) KQ 3: Any of the outcomes listed above by subgroups of interest | Any outcomes that are not health outcomes of chronic conditions associated with hormone therapy (e.g., intermediate outcomes, such as bone density and cholesterol level)
Timing: Duration of intervention | ≥1 year of treatment | <1 year of treatment
Setting | Primary care or primary care–like settings | Inpatient facilities, nursing homes, and specialist settings (such as endocrinology)
Geography | U.S. adult population or comparable populations (i.e., those categorized as “Very High” on the Human Development Index, as defined by the United Nations Development Programme) | Settings not comparable or applicable to U.S. adult population
Study design | All outcomes: Randomized controlled trials Controlled clinical trials Systematic reviews Large cohort studies (>10,000 women) for outcomes with no evidence from trials or systematic reviews | All other study designs
Publication language | English | Non-English language
Publication type | Published or unpublished original research | Nonsystematic review article, letter, or editorial; results reported elsewhere; no original data
Start date of search | January 2011 onward | Before January 2011