# Appendix A Search Strategies

## August 1, 2016

#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Hormone Replacement Therapy”[Mesh] OR “Estrogen Replacement Therapy”[Mesh] OR “Estrogens”[Mesh] OR “Estradiol Congeners”[Mesh]) | 157162 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Perimenopause”[Mesh] OR “Climacteric”[Mesh] OR “Menopause”[Mesh] | 52591 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 AND #16) | 18650 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 AND #16) Filters: Publication date from 2015/06/01 | 223 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 AND #16) Filters: Publication date from 2015/06/01; Humans | 216 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 AND #16) Filters: Publication date from 2015/06/01; Humans; English | 204 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#30 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#21 NOT #23) | 19 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#32 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#21 NOT #23) Filters: Humans | 12 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)

PubMed (English)= 204 = 189 NEW

PubMed (non-English) = 12

Cochrane

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric)

Reviews =3 =3 NEW

Other reviews = 0 = 0 NEW

Trials =26 = 22 NEW

Embase

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) =29 = 19 NEW

ClinicalTrials.gov

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) = 2

WHO ICTRP

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) = 2 NEW

TOTAL NON-DUPLICATE DATABASE = 237

Drugs@FDA.gov

Will do targeted searches for “harms” as indicated

NON ENGLISH

PubMed (non-English) = 12

Embase = 0 = NEW

Total = 12

IPA

IPA (held as separate file) = 0 New

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric)

## Sept. 28, 2015

PubMed

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Hormone Replacement Therapy”[Mesh] OR “Estrogen Replacement Therapy”[Mesh] OR “Estrogens”[Mesh] OR “Estradiol Congeners”[Mesh] | 153213 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Perimenopause”[Mesh] OR “Climacteric”[Mesh] OR “Menopause”[Mesh] | 50740 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) | 18187 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Filters: Humans | 17486 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4) AND (“2011/06/01”[Date - Entrez]: “3000”[Date - Entrez]) Filters: Humans | 1558 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4) AND (“2011/06/01”[Date - Entrez]: “3000”[Date - Entrez]) Filters: Humans; English | 1449 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #6) NON ENGLISH | 109 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)

PubMed (English) = 1449 = (2 appeared in the original report and have been removed)

PubMed (English) = 1447

Cochrane

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric)

Reviews = 9 = 4 NEW

Other reviews = 5 = 1 NEW

Trials = 62 = 33 NEW

Embase

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) = 459 = 327 NEW

ClinicalTrials.gov

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) = 12

WHO ICTRP

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) = 7 = 4 NEW

TOTAL NON-DUPLICATE DATABASE = 1828

Drugs@FDA.gov

Will do targeted searches for “harms” as indicated

NON ENGLISH

PubMed (non-English) = 109 = NEW

Embase = 16 = 13 NEW

Total - 122

IPA

IPA (held as separate file) =

‘hormone replacement therapy’ AND (menopause OR perimenopause OR climacteric) = 6 = 4 NEW