# References

1 Mazhar D, Waxman J. Prostate cancer. Postgraduate medical journal. 2002;78(924):590–5.12415080
2 American Joint Committee on Cancer. Genitourinary Sites: Prostate AJCC Cancer Staging Manual. 7th ed. New York: Springer; 2010.
3 Edge S, Byrd D, Compton C, AJCC Cancer Staging Manuel (7th ed). New York, NY: Spring; 2010.
4 National Cancer Institute. SEER Cancer Statistics Factsheets: Prostate Cancer. http://seer.cancer.gov/statfacts/html/prost.html Accessed: Accessed July 24, 2017.
5 Siegel RL, Miller KD, Jemal A. Cancer Statistics, 2017. CA-Cancer J Clin. 2017;67(1):7–30. 10.3322/caac.21387 28055103
6 Stern MC, Fejerman L, Das R, Variability in Cancer Risk and Outcomes Within US Latinos by National Origin and Genetic Ancestry. Current epidemiology reports. 2016;3:181–90. 10.1007/s40471-016-0083-7 27547694
7 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2011 Incidence and Mortality Web-based Report. http://www.cdc.gov/uscs. Accessed: Accessed March 26, 2015.
8 Imperato-McGinley J, Zhu YS. Androgens and male physiology the syndrome of 5alpha-reductase-2 deficiency. Molecular and cellular endocrinology. 2002;198(1–2):51–9.12573814
9 Bell KJ, Del Mar C, Wright G, Prevalence of incidental prostate cancer: A systematic review of autopsy studies. International journal of cancer Journal international du cancer. 2015;137(7):1749–57. 10.1002/ijc.29538 25821151
10 Kirschner-Hermanns R, Jakse G. Quality of life following radical prostatectomy. Critical reviews in oncology/hematology. 2002;43(2):141–51.12191736
11 Bruner DW, Moore D, Parlanti A, Relative risk of prostate cancer for men with affected relatives: systematic review and meta-analysis. International journal of cancer Journal international du cancer. 2003;107(5):797–803. 10.1002/ijc.11466 14566830
12 Lichtenstein P, Holm NV, Verkasalo PK, Environmental and heritable factors in the causation of cancer--analyses of cohorts of twins from Sweden, Denmark, and Finland. The New England journal of medicine. 2000;343(2):78–85. 10.1056/nejm200007133430201 10891514
13 Sinha R, Park Y, Graubard BI, Meat and meat-related compounds and risk of prostate cancer in a large prospective cohort study in the United States. American journal of epidemiology. 2009;170(9):1165–77. 10.1093/aje/kwp280 19808637
14 Allen NE, Key TJ, Appleby PN, Animal foods, protein, calcium and prostate cancer risk: the European Prospective Investigation into Cancer and Nutrition. British journal of cancer. 2008;98(9):1574–81. 10.1038/sj.bjc.6604331 18382426
15 Cohen JH, Kristal AR, Stanford JL. Fruit and vegetable intakes and prostate cancer risk. Journal of the National Cancer Institute. 2000;92(1):61–8.10620635
16 Islami F, Moreira DM, Boffetta P, A Systematic Review and Meta-analysis of Tobacco Use and Prostate Cancer Mortality and Incidence in Prospective Cohort Studies. European urology. 2014;66(6):1054–64. 10.1016/j.eururo.2014.08.059 25242554
17 Carter HB, Albertsen PC, Barry MJ, Early detection of prostate cancer: AUA Guideline. J Urol. 2013;190(2):419–26. 10.1016/j.juro.2013.04.119 23659877
18 Fleshner K, Carlsson SV, Roobol MJ. The effect of the USPSTF PSA screening recommendation on prostate cancer incidence patterns in the USA. Nat Rev Urol. 2017;14(1):26–37. 10.1038/nrurol.2016.251 27995937
19 Parker PM, Rice KR, Sterbis JR, Prostate cancer in men less than the age of 50: a comparison of race and outcomes. Urology. 2011;78(1):110–5. 10.1016/j.urology.2010.12.046 21397300
20 Hoffman RM, Gilliland FD, Eley JW, Racial and ethnic differences in advanced-stage prostate cancer: the Prostate Cancer Outcomes Study. Journal of the National Cancer Institute. 2001;93(5):388–95.11238701
21 Powell IJ, Banerjee M, Sakr W, Should African-American men be tested for prostate carcinoma at an earlier age than white men? Cancer. 1999;85(2):472–7.10023717
22 Cross CK, Shultz D, Malkowicz SB, Impact of race on prostate-specific antigen outcome after radical prostatectomy for clinically localized adenocarcinoma of the prostate. J Clin Oncol. 2002;20(12):2863–8.12065563
23 Barocas DA, Grubb R, Black A, Association between race and follow-up diagnostic care after a positive prostate cancer screening test in the prostate, lung, colorectal, and ovarian cancer screening trial. Cancer [serial on the Internet]. 2013 [cited Search 2 Database 20160304; 119(12): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/484/CN-00964484/frame.html http://onlinelibrary.wiley.com/store/10.1002/cncr.28042/asset/cncr28042.pdf?v=1&t=ilel7j4n&s=c16f5e4f9eb423babb11d926b64b51d4f7744b47.
24 Oesterling JE, Jacobsen SJ, Chute CG, Serum prostate-specific antigen in a community-based population of healthy men. Establishment of age-specific reference ranges. Jama. 1993;270(7):860–4.7688054
25 Vickers AJ, Savage C, O’Brien MF, Systematic review of pretreatment prostate-specific antigen velocity and doubling time as predictors for prostate cancer. J Clin Oncol. 2009;27(3):398–403. 10.1200/jco.2008.18.1685 19064972
26 Hoffman R. Screening for prostate cancer. In: Rind D, editor. UpToDate 2015.
27 Moul JW, Sesterhenn IA, Connelly RR, Prostate-specific antigen values at the time of prostate cancer diagnosis in African-American men. Jama. 1995;274(16):1277–81.7563532
28 Morgan TO, Jacobsen SJ, McCarthy WF, Age-specific reference ranges for prostate-specific antigen in black men. The New England journal of medicine. 1996;335(5):304–10. 10.1056/nejm199608013350502 8663870
29 Klein E. Initial approach to low- and very low-risk clinically localized prostate cancer In: Ross M, editor. UpToDate 2015.
30 American Cancer Society. Hormone (androgen deprivation) therapy for prostate cancer. http://www.cancer.org/cancer/prostatecancer/detailedguide/prostate-cancer-treating-hormone-therapy. Accessed: Accessed February 11, 2015.
31 Dahabreh IJ, Chung M, Balk EM, Active surveillance in men with localized prostate cancer: a systematic review. Annals of internal medicine. 2012;156(8):582–90. 10.7326/0003-4819-156-8-201204170-00397 22351515
32 Tosoian JJ, Carter HB, Lepor A, Active surveillance for prostate cancer: current evidence and contemporary state of practice. Nat Rev Urol. 2016;13(4):205–15. 10.1038/nrurol.2016.45 26954332
33 Walter LC, Fung KZ, Kirby KA, Five-year downstream outcomes following prostate-specific antigen screening in older men. JAMA internal medicine. 2013;173(10):866–73. 10.1001/jamainternmed.2013.323 23588999
34 Cooperberg MR, Broering JM, Carroll PR. Time trends and local variation in primary treatment of localized prostate cancer. J Clin Oncol. 2010;28(7):1117–23. 10.1200/jco.2009.26.0133 20124165
35 Filson CP, Shelton JB, Tan HJ, Expectant management of veterans with early-stage prostate cancer. Cancer. 2016;122(4):626–33. 10.1002/cncr.29785 26540451
36 Filson CP, Schroeck FR, Ye Z, Variation in use of active surveillance among men undergoing expectant treatment for early stage prostate cancer. J Urol. 2014;192(1):75–80. 10.1016/j.juro.2014.01.105 24518783
37 Womble PR, Montie JE, Ye Z, Contemporary use of initial active surveillance among men in Michigan with low-risk prostate cancer. European urology. 2015;67(1):44–50. 10.1016/j.eururo.2014.08.024 25159890
38 Ritch CR, Graves AJ, Keegan KA, Increasing use of observation among men at low risk for prostate cancer mortality. J Urol. 2015;193(3):801–6. 10.1016/j.juro.2014.08.102 25196658
39 Weiner AB, Patel SG, Etzioni R, National trends in the management of low and intermediate risk prostate cancer in the United States. Journal of Urology. 2015;193(1):95–102. http://dx.doi.org/10.1016/j.juro.2014.07.111 25106900
40 Cooperberg MR, Carroll PR. Trends in Management for Patients With Localized Prostate Cancer, 1990–2013. Jama. 2015;314(1):80–2. 10.1001/jama.2015.6036 26151271
41 American Academy of Family Physicians. Prostate Cancer Screening. http://www.aafp.org/patient-care/clinical-recommendations/all/prostate-cancer.html. Accessed: Accessed September 12, 2016.
42 Lim LS, Sherin K. Screening for prostate cancer in U.S. men ACPM position statement on preventive practice. American journal of preventive medicine. 2008;34(2):164–70. 10.1016/j.amepre.2007.10.003 18201648
43 Bell N, Connor Gorber S, Shane A, Recommendations on screening for prostate cancer with the prostate-specific antigen test. CMAJ: Canadian Medical Association journal = journal de l’Association medicale canadienne. 2014;186(16):1225–34. 10.1503/cmaj.140703
44 Mottet N, Bellmunt J, Briers E, EAU Guidelines on Prostate Cancer. http://uroweb.org/guideline/prostate-cancer/. Accessed: February 27, 2017.
45 American Cancer Society. American Cancer Society recommendations for prostate cancer early detection. http://www.cancer.org/cancer/prostatecancer/moreinformation/prostatecancerearlydetection/prostate-cancer-early-detection-acs-recommendations. Accessed: Accessed September 12, 2016.
46 Carroll PR, Parsons JK, Andriole G, NCCN Guidelines Insights: Prostate Cancer Early Detection, Version 2.2016. J Natl Compr Canc Netw. 2016;14(5):509–19.27160230
47 Moyer VA, Force USPST. Screening for prostate cancer: U.S. Preventive Services Task Force recommendation statement. Annals of internal medicine. 2012;157(2):120–34. http://dx.doi.org/10.7326/0003-4819-157-2-201207170-00459 22801674
48 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual, AHRQ Publication No. 08-05118-EF. http://www.uspreventiveservicestaskforce.org/Home/GetFile/6/7/procedure-manual_2015/pdf. Accessed: May 24, 2016.
49 Lin K, Croswell JM, Koenig H, Prostate-Specific Antigen-Based Screening for Prostate Cancer: An Evidence Update for the U.S. Preventive Services Task Force. 12-05160-EF-1. Rockville, MD: Agency for Healthcare Resaerch and Quality October 2011.
50 Chou R, Dana T, Bougatsos C, Treatments for Localized Prostate Cancer: Systematic Review to Update the 2002 U.S. Preventive Services Task Force Recommendation. 12-05161-EF-1. Rockville, MD: Agency for Healthcare Research and Quality October 2011.
51 Thompson IM, Ankerst DP, Chi C, Assessing prostate cancer risk: results from the Prostate Cancer Prevention Trial. Journal of the National Cancer Institute. 2006;98(8):529–34. 10.1093/jnci/djj131 16622122
52 United Nations Development Programme. Human Develoment Data (1980–2015). http://hdr.undp.org/en/data. Accessed: August 16, 2016.
53 Andriole GL, Crawford ED, Grubb RL, 3rd, Mortality results from a randomized prostate-cancer screening trial. The New England journal of medicine. 2009;360(13):1310–9. 10.1056/NEJMoa0810696 19297565
54 Schroder FH, Hugosson J, Roobol MJ, Screening and prostate-cancer mortality in a randomized European study. The New England journal of medicine. 2009;360(13):1320–8. 10.1056/NEJMoa0810084 19297566
55 National Cancer Institute. SEER Training Module: Summary Staging. https://training.seer.cancer.gov/staging/systems/summary/. Accessed: September 12, 2016.
56 D’Amico AV, Whittington R, Malkowicz SB, Predicting prostate specific antigen outcome preoperatively in the prostate specific antigen era. J Urol. 2001;166(6):2185–8.11696732
57 Moons KG, de Groot JA, Bouwmeester W, Critical appraisal and data extraction for systematic reviews of prediction modelling studies: the CHARMS checklist. PLoS medicine. 2014;11(10):e1001744. 10.1371/journal.pmed.1001744 25314315
58 Parekh DJ, Punnen S, Sjoberg DD, A multi-institutional prospective trial in the USA confirms that the 4Kscore accurately identifies men with high-grade prostate cancer. European urology. 2015;68(3):464–70. 10.1016/j.eururo.2014.10.021 25454615
59 Nordstrom T, Vickers A, Assel M, Comparison Between the Four-kallikrein Panel and Prostate Health Index for Predicting Prostate Cancer. European urology. 2015;68(1):139–46. http://dx.doi.org/10.1016/j.eururo.2014.08.010 25151013
60 Salami SS, Vira MA, Turkbey B, Multiparametric magnetic resonance imaging outperforms the Prostate Cancer Prevention Trial risk calculator in predicting clinically significant prostate cancer. Cancer. 2014;120(18):2876–82. http://dx.doi.org/10.1002/cncr.28790 24917122
61 Wells GA, Shea B, O’Connell D . The Newcastle-Ottowa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: August 16, 2016.
62 National Institute for Health and Care Excellence. The Guidelines Manual. London: National Institute for Health and Care Excellence; 2006.
63 Collins GS, Reitsma JB, Altman DG, Transparent Reporting of a multivariable prediction model for Individual Prognosis or Diagnosis (TRIPOD): the TRIPOD statement. Annals of internal medicine. 2015;162(1):55–63. 10.7326/m14-0697 25560714
64 Harris PA, Taylor R, Thielke R, Research electronic data capture (REDCap)--a metadata-driven methodology and workflow process for providing translational research informatics support. Journal of biomedical informatics. 2009;42(2):377–81. 10.1016/j.jbi.2008.08.010 18929686
65 Carter JL, Coletti RJ, Harris RP. Quantifying and monitoring overdiagnosis in cancer screening: a systematic review of methods. Bmj. 2015;350:g7773. 10.1136/bmj.g7773 25569206
66 Miller AB, Wall C, Baines CJ, Twenty five year follow-up for breast cancer incidence and mortality of the Canadian National Breast Screening Study: randomised screening trial. Bmj. 2014;348:g366. 10.1136/bmj.g366 24519768
67 Zackrisson S, Andersson I, Janzon L, Rate of over-diagnosis of breast cancer 15 years after end of Malmo mammographic screening trial: follow-up study. Bmj. 2006;332(7543):689–92. 10.1136/bmj.38764.572569.7C 16517548
68 Patz EF, Jr., Pinsky P, Gatsonis C, Overdiagnosis in low-dose computed tomography screening for lung cancer. JAMA internal medicine. 2014;174(2):269–74. 10.1001/jamainternmed.2013.12738 24322569
69 Vickers AJ, Elkin EB. Decision curve analysis: a novel method for evaluating prediction models. Med Decis Making. 2006;26(6):565–74. 10.1177/0272989x06295361 17099194
70 Fransson P, Damber JE, Tomic R, Quality of life and symptoms in a randomized trial of radiotherapy versus deferred treatment of localized prostate carcinoma. Cancer. 2001;92(12):3111–9.11753990
71 Fransson P, Damber JE, Widmark A. Health-related quality of life 10 years after external beam radiotherapy or watchful waiting in patients with localized prostate cancer. Scand J Urol Nephrol. 2009;43(2):119–26. 10.1080/00365590802519396 18985545
72 Berkman ND, Lohr KN, Ansari MT, Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015;68(11):1312–24. 10.1016/j.jclinepi.2014.11.023 25721570
73 Atkins D, Eccles M, Flottorp S, Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. 10.1186/1472-6963-4-38 15615589
74 Wilt TJ, Jones KM, Barry MJ, Follow-up of Prostatectomy versus Observation for Early Prostate Cancer. The New England journal of medicine. 2017;377(2):132–42. 10.1056/NEJMoa1615869 28700844
75 Barocas DA, Alvarez J, Resnick MJ, Association Between Radiation Therapy, Surgery, or Observation for Localized Prostate Cancer and Patient-Reported Outcomes After 3 Years. Jama. 2017;317(11):1126–40. 10.1001/jama.2017.1704 28324093
76 Chen RC, Basak R, Meyer AM, Association Between Choice of Radical Prostatectomy, External Beam Radiotherapy, Brachytherapy, or Active Surveillance and Patient-Reported Quality of Life Among Men With Localized Prostate Cancer. Jama. 2017;317(11):1141–50. 10.1001/jama.2017.1652 28324092
77 Gomez-Gomez E, Carrasco-Valiente J, Blanca-Pedregosa A, European Randomized Study of Screening for Prostate Cancer Risk Calculator: External Validation, Variability, and Clinical Significance. Urology. 2017;102:85–91. 10.1016/j.urology.2016.11.004 27840252
78 Maruf M, Fascelli M, George AK, The prostate cancer prevention trial risk calculator 2.0 performs equally for standard biopsy and MRI/US fusion-guided biopsy. Prostate Cancer and Prostatic Diseases. 2017;20(2):179–85. 10.1038/pcan.2016.46 28220802
79 Park JY, Yoon S, Park MS, Development and external validation of the Korean prostate cancer risk calculator for high-grade prostate cancer: Comparison with two western risk calculators in an asian cohort. PLoS ONE. 2017;12(1). 10.1371/journal.pone.0168917
80 Andriole GL, Crawford ED, Grubb RL, 3rd, Prostate cancer screening in the randomized Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial: mortality results after 13 years of follow-up. Journal of the National Cancer Institute. 2012;104(2):125–32. 10.1093/jnci/djr500 22228146
81 Arnsrud Godtman R, Holmberg E, Lilja H, Opportunistic Testing Versus Organized Prostate-specific Antigen Screening: Outcome After 18 Years in the Göteborg Randomized Population-based Prostate Cancer Screening Trial. European urology. 2015;68(3):354–60.25556937
82 Bokhorst LP, Bangma CH, van Leenders GJ, Prostate-specific antigen-based prostate cancer screening: reduction of prostate cancer mortality after correction for nonattendance and contamination in the Rotterdam section of the European Randomized Study of Screening for Prostate Cancer. European urology. 2014;65(2):329–36. http://dx.doi.org/10.1016/j.eururo.2013.08.005 23954085
83 Buzzoni C, Auvinen A, Roobol MJ, Metastatic prostate cancer incidence and prostate-specific antigen testing: New insights from the European Randomized Study of Screening for Prostate Cancer. European urology. 2015;68(5):885–90.25791513
84 Ciatto S, Zappa M, Villers A, Contamination by opportunistic screening in the European Randomized Study of Prostate Cancer Screening. BJU international. 2003;92 Suppl 2:97–100.
85 Hugosson J, Carlsson S, Aus G, Mortality results from the Goteborg randomised population-based prostate-cancer screening trial. The Lancet Oncology. 2010;11(8):725–32. 10.1016/s1470-2045(10)70146-7 20598634
86 Kilpeläinen TP, Pogodin-Hannolainen D, Kemppainen K, Estimate of opportunistic prostate-specific antigen testing in the Finnish Randomized Study of Screening for Prostate Cancer. The Journal of Urology. 2017. http://dx.doi.org/10.1016/j.juro.2017.01.048
87 Kilpelainen TP, Tammela TL, Malila N, Prostate cancer mortality in the Finnish randomized screening trial. Journal of the National Cancer Institute. 2013;105(10):719–25. 10.1093/jnci/djt038 23479454
88 Liss MA, Chen H, Hemal S, Impact of family history on prostate cancer mortality in white men undergoing prostate specific antigen based screening. Journal of Urology. 2015;193(1):75–9. http://dx.doi.org/10.1016/j.juro.2014.07.085 25066872
89 Lujan M, Paez A, Angulo JC, Prostate cancer incidence and mortality in the Spanish section of the European Randomized Study of Screening for Prostate Cancer (ERSPC). Prostate Cancer Prostatic Dis. 2014;17(2):187–91. http://dx.doi.org/10.1038/pcan.2014.7 24614694
90 Pinsky P, Prorok P, Yu K, Extended Mortality Results for Prostate Cancer Screening in the PLCO Trial with Median 15 Years Follow-up. Cancer. 2017;123(4):592–9.27911486
91 Prorok PC, Andriole GL, Bresalier RS, Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):273s–309s.11189684
92 Roobol MJ, Kranse R, Bangma CH, Screening for prostate cancer: results of the Rotterdam section of the European randomized study of screening for prostate cancer. European urology. 2013;64(4):530–9. http://dx.doi.org/10.1016/j.eururo.2013.05.030 23759326
93 Saarimaki L, Tammela TL, Maattanen L, Family history in the Finnish Prostate Cancer Screening Trial. International Journal of Cancer. 2015;136(9):2172–7. http://dx.doi.org/10.1002/ijc.29243 25274038
94 Schroder FH, Hugosson J, Carlsson S, Screening for prostate cancer decreases the risk of developing metastatic disease: findings from the European Randomized Study of Screening for Prostate Cancer (ERSPC). European urology. 2012;62(5):745–52. http://dx.doi.org/10.1016/j.eururo.2012.05.068 22704366
95 Schroder FH, Hugosson J, Roobol MJ, Prostate-cancer mortality at 11 years of follow-up. The New England journal of medicine. 2012;366(11):981–90. 10.1056/NEJMoa1113135 22417251
96 Schroder FH, Hugosson J, Roobol MJ, Screening and prostate cancer mortality: results of the European Randomised Study of Screening for Prostate Cancer (ERSPC) at 13 years of follow-up. Lancet (London, England). 2014;384(9959):2027–35. 10.1016/s0140-6736(14)60525-0
97 Wolters T, Roobol MJ, Steyerberg EW, The effect of study arm on prostate cancer treatment in the large screening trial ERSPC. International journal of cancer Journal international du cancer. 2010;126(10):2387–93. 10.1002/ijc.24870 19739124
98 ERSPC. Study Book: European Randomized Study of Screening for Prostate Cancer (ERSPC). http://www.erspc.org/wp-content/uploads/Study-protocol-ERSPC.pdf Accessed: April 11, 2016.
99 Pinsky PF, Blacka A, Kramer BS, Assessing contamination and compliance in the prostate component of the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. Clinical trials (London, England). 2010;7(4):303–11. 10.1177/1740774510374091
100 Sandblom G, Varenhorst E, Lofman O, Clinical consequences of screening for prostate cancer: 15 years follow-up of a randomised controlled trial in Sweden. European urology. 2004;46(6):717–23; discussion 24. 10.1016/j.eururo.2004.08.011 15548438
101 Kilpelainen TP, Tammela TL, Roobol M, False-positive screening results in the European randomized study of screening for prostate cancer. Eur J Cancer. 2011;47(18):2698–705. 10.1016/j.ejca.2011.06.055 21788129
102 Rosario DJ, Lane JA, Metcalfe C, Short term outcomes of prostate biopsy in men tested for cancer by prostate specific antigen: prospective evaluation within ProtecT study. Bmj. 2012;344:d7894. 10.1136/bmj.d7894 22232535
103 Pinsky PF, Parnes HL, Andriole G. Mortality and complications after prostate biopsy in the Prostate, Lung, Colorectal and Ovarian Cancer Screening (PLCO) trial. BJU international. 2014;113(2):254–9. 10.1111/bju.12368 24053621
104 Carlsson SV, Holmberg E, Moss SM, No excess mortality after prostate biopsy: results from the European Randomized Study of Screening for Prostate Cancer. BJU international. 2011;107(12):1912–7. 10.1111/j.1464-410X.2010.09712.x 20950305
105 Vasarainen H, Malmi H, Määttänen L, Effects of prostate cancer screening on health-related quality of life: results of the Finnish arm of the European randomized screening trial (ERSPC). Acta oncologica (Stockholm, Sweden) [serial on the Internet]. 2013 [cited Search 2 Database 20160304; 52(8): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/782/CN-00913782/frame.html http://www.tandfonline.com/doi/pdf/10.3109/0284186X.2013.802837.
106 Pinsky PF, Prorok PC, Yu K, Extended mortality results for prostate cancer screening in the PLCO trial with median follow-up of 15 years. Cancer. 2016. 10.1002/cncr.30474
107 Croswell JM, Kramer BS, Kreimer AR, Cumulative incidence of false-positive results in repeated, multimodal cancer screening. Annals of family medicine. 2009;7(3):212–22. 10.1370/afm.942 19433838
108 Raaijmakers R, Kirkels WJ, Roobol MJ, Complication rates and risk factors of 5802 transrectal ultrasound-guided sextant biopsies of the prostate within a population-based screening program. Urology. 2002;60(5):826–30.12429309
109 Bokhorst LP, Zhu X, Bul M, Positive predictive value of prostate biopsy indicated by prostate-specific-antigen-based prostate cancer screening: trends over time in a European randomized trial. BJU international. 2012;110(11):1654–60. http://dx.doi.org/10.1111/j.1464-410X.2012.11481.x 23043563
110 Fowler FJ, Jr., Barry MJ, Walker-Corkery B, The impact of a suspicious prostate biopsy on patients’ psychological, socio-behavioral, and medical care outcomes. J Gen Intern Med. 2006;21(7):715–21. 10.1111/j.1525-1497.2006.00464.x 16808772
111 McNaughton-Collins M, Fowler FJ, Jr., Caubet JF, Psychological effects of a suspicious prostate cancer screening test followed by a benign biopsy result. Am J Med. 2004;117(10):719–25. 10.1016/j.amjmed.2004.06.036 15541320
112 Katz DA, Jarrard DF, McHorney CA, Health perceptions in patients who undergo screening and workup for prostate cancer. Urology. 2007;69(2):215–20. 10.1016/j.urology.2006.09.059 17320653
113 Brindle LA, Oliver SE, Dedman D, Measuring the psychosocial impact of population-based prostate-specific antigen testing for prostate cancer in the UK. BJU international. 2006;98(4):777–82. 10.1111/j.1464-410X.2006.06401.x 16978272
114 Abdollah F, Sun M, Schmitges J, Competing-risks mortality after radiotherapy vs. observation for localized prostate cancer: a population-based study. International Journal of Radiation Oncology, Biology, Physics. 2012;84(1):95–103. http://dx.doi.org/10.1016/j.ijrobp.2011.11.034
115 Albertsen PC, Hanley JA, Penson DF, 13-year outcomes following treatment for clinically localized prostate cancer in a population based cohort. J Urol. 2007;177(3):932–6. 10.1016/j.juro.2006.10.051 17296379
116 Bill-Axelson A, Holmberg L, Filen F, Radical prostatectomy versus watchful waiting in localized prostate cancer: the Scandinavian prostate cancer group-4 randomized trial. Journal of the National Cancer Institute. 2008;100(16):1144–54. 10.1093/jnci/djn255 18695132
117 Bill-Axelson A, Holmberg L, Garmo H, Radical prostatectomy or watchful waiting in early prostate cancer. The New England journal of medicine. 2014;370(10):932–42. 10.1056/NEJMoa1311593 24597866
118 Bill-Axelson A, Holmberg L, Ruutu M, Radical prostatectomy versus watchful waiting in early prostate cancer. The New England journal of medicine. 2011;364(18):1708–17. 10.1056/NEJMoa1011967 21542742
119 Bill-Axelson A, Holmberg L, Ruutu M, Radical prostatectomy versus watchful waiting in early prostate cancer. The New England journal of medicine. 2005;352(19):1977–84. 10.1056/NEJMoa043739 15888698
120 Godtman RA, Holmberg E, Khatami A, Outcome following active surveillance of men with screen-detected prostate cancer. Results from the Goteborg randomised population-based prostate cancer screening trial. European urology. 2013;63(1):101–7. http://dx.doi.org/10.1016/j.eururo.2012.08.066 22980443
121 Hamdy FC, Donovan JL, Lane JA, 10-Year Outcomes after Monitoring, Surgery, or Radiotherapy for Localized Prostate Cancer. The New England journal of medicine. 2016;375(15):1415–24. 10.1056/NEJMoa1606220 27626136
122 Holmberg L, Bill-Axelson A, Garmo H, Prognostic markers under watchful waiting and radical prostatectomy. Hematol Oncol Clin North Am. 2006;20(4):845–55. 10.1016/j.hoc.2006.03.007 16861118
123 Holmberg L, Bill-Axelson A, Helgesen F, A randomized trial comparing radical prostatectomy with watchful waiting in early prostate cancer. The New England journal of medicine. 2002;347(11):781–9. 10.1056/NEJMoa012794 12226148
124 Holmberg L, Bill-Axelson A, Steineck G, Results from the Scandinavian Prostate Cancer Group Trial Number 4: a randomized controlled trial of radical prostatectomy versus watchful waiting. Journal of the National Cancer Institute Monographs. 2012;2012(45):230–3. http://dx.doi.org/10.1093/jncimonographs/lgs025 23271778
125 Ladjevardi S, Sandblom G, Berglund A, Tumour grade, treatment, and relative survival in a population-based cohort of men with potentially curable prostate cancer. European urology. 2010;57(4):631–8. 10.1016/j.eururo.2009.03.007 19299069
126 Lane JA, Donovan JL, Davis M, Active monitoring, radical prostatectomy, or radiotherapy for localised prostate cancer: study design and diagnostic and baseline results of the ProtecT randomised phase 3 trial. The Lancet Oncology. 2014;15(10):1109–18. 10.1016/S1470-2045(14)70361-4 25163905
127 Lu-Yao GL, Albertsen PC, Moore DF, Fifteen-year survival outcomes following primary androgen-deprivation therapy for localized prostate cancer. JAMA internal medicine. 2014;174(9):1460–7. http://dx.doi.org/10.1001/jamainternmed.2014.3028 25023796
128 Lu-Yao GL, Albertsen PC, Moore DF, Survival following primary androgen deprivation therapy among men with localized prostate cancer. Jama. 2008;300(2):173–81. 10.1001/jama.300.2.173 18612114
129 Schymura MJ, Kahn AR, German RR, Factors associated with initial treatment and survival for clinically localized prostate cancer: results from the CDC-NPCR Patterns of Care Study (PoC1). BMC Cancer. 2010;10:152. 10.1186/1471-2407-10-152 20403178
130 Stattin P, Holmberg E, Johansson JE, Outcomes in localized prostate cancer: National Prostate Cancer Register of Sweden follow-up study. Journal of the National Cancer Institute. 2010;102(13):950–8. 10.1093/jnci/djq154 20562373
131 Sun M, Sammon JD, Becker A, Radical prostatectomy vs radiotherapy vs observation among older patients with clinically localized prostate cancer: a comparative effectiveness evaluation. BJU international. 2014;113(2):200–8. http://dx.doi.org/10.1111/bju.12321 23937636
132 Wilt TJ. The Prostate Cancer Intervention Versus Observation Trial: VA/NCI/AHRQ Cooperative Studies Program #407 (PIVOT): design and baseline results of a randomized controlled trial comparing radical prostatectomy with watchful waiting for men with clinically localized prostate cancer. Journal of the National Cancer Institute Monographs. 2012;2012(45):184–90. http://dx.doi.org/10.1093/jncimonographs/lgs041 23271771
133 Wilt TJ, Brawer MK, Jones KM, Radical Prostatectomy versus Observation for Localized Prostate Cancer. New England Journal of Medicine. 2012;367(3):203–13. doi:10.1056/NEJMoa1113162 22808955
134 Wong YN, Mitra N, Hudes G, Survival associated with treatment vs observation of localized prostate cancer in elderly men. Jama. 2006;296(22):2683–93. 10.1001/jama.296.22.2683 17164454
135 Zhou EH, Ellis RJ, Cherullo E, Radiotherapy and survival in prostate cancer patients: a population-based study. Int J Radiat Oncol Biol Phys. 2009;73(1):15–23. 10.1016/j.ijrobp.2008.04.001 18538495
136 Hamdy F, Donovan J, Lane J, 10-Year Outcomes after Monitoring, Surgery, or Radiotherapy for Localized Prostate Cancer. New England Journal of Medicine. 2016;375(15):1415–24.27626136
137 Alibhai SM, Leach M, Tomlinson G, 30-day mortality and major complications after radical prostatectomy: influence of age and comorbidity. Journal of the National Cancer Institute. 2005;97(20):1525–32. 10.1093/jnci/dji313 16234566
138 Augustin H, Hammerer P, Graefen M, Intraoperative and perioperative morbidity of contemporary radical retropubic prostatectomy in a consecutive series of 1243 patients: results of a single center between 1999 and 2002. European urology. 2003;43(2):113–8.12565767
139 Bacon CG, Giovannucci E, Testa M, The impact of cancer treatment on quality of life outcomes for patients with localized prostate cancer. J Urol. 2001;166(5):1804–10.11586228
140 Bjorklund J, Folkvaljon Y, Cole A, Postoperative mortality 90 days after robot-assisted laparoscopic prostatectomy and retropubic radical prostatectomy: a nationwide population-based study. BJU international. 2016. 10.1111/bju.13404
141 Blana A, Rogenhofer S, Ganzer R, Eight years’ experience with high-intensity focused ultrasonography for treatment of localized prostate cancer. Urology. 2008;72(6):1329–33; discussion 33–4. 10.1016/j.urology.2008.06.062 18829078
142 Blana A, Walter B, Rogenhofer S, High-intensity focused ultrasound for the treatment of localized prostate cancer: 5-year experience. Urology. 2004;63(2):297–300. 10.1016/j.urology.2003.09.020 14972475
143 Crouzet S, Chapelon JY, Rouviere O, Whole-gland ablation of localized prostate cancer with high-intensity focused ultrasound: oncologic outcomes and morbidity in 1002 patients. European urology. 2014;65(5):907–14. http://dx.doi.org/10.1016/j.eururo.2013.04.039 23669165
144 Donovan JL, Hamdy FC, Lane JA, Patient-Reported Outcomes after Monitoring, Surgery, or Radiotherapy for Prostate Cancer. The New England journal of medicine. 2016;375(15):1425–37. 10.1056/NEJMoa1606221 27626365
145 Hoffman RM, Hunt WC, Gilliland FD, Patient satisfaction with treatment decisions for clinically localized prostate carcinoma. Results from the Prostate Cancer Outcomes Study. Cancer. 2003;97(7):1653–62. 10.1002/cncr.11233 12655522
146 Inoue Y, Goto K, Hayashi T, Transrectal high-intensity focused ultrasound for treatment of localized prostate cancer. International Journal of Urology. 2011;18(5):358–62. http://dx.doi.org/10.1111/j.1442-2042.2011.02739.x 21449970
147 Johansson E, Bill-Axelson A, Holmberg L, Time, symptom burden, androgen deprivation, and self-assessed quality of life after radical prostatectomy or watchful waiting: the Randomized Scandinavian Prostate Cancer Group Study Number 4 (SPCG-4) clinical trial. European urology. 2009;55(2):422–30. 10.1016/j.eururo.2008.08.054 18783877
148 Johansson E, Steineck G, Holmberg L, Long-term quality-of-life outcomes after radical prostatectomy or watchful waiting: the Scandinavian Prostate Cancer Group-4 randomised trial. The Lancet Oncology. 2011;12(9):891–9. 10.1016/s1470-2045(11)70162-0 21821474
149 Litwin MS. Health-related quality of life after treatment for localized prostate cancer. Cancer. 1995;75(S7):2000–3. 10.1002/1097-0142(19950401)75:7+<2000::AIDCNCR2820751641>3.0.CO;2-4
150 Litwin MS, Hays RD, Fink A, Quality-of-life outcomes in men treated for localized prostate cancer. Jama. 1995;273(2):129–35.7799493
151 Litwin MS, Lubeck DP, Spitalny GM, Mental health in men treated for early stage prostate carcinoma: a posttreatment, longitudinal quality of life analysis from the Cancer of the Prostate Strategic Urologic Research Endeavor. Cancer. 2002;95(1):54–60. 10.1002/cncr.10651 12115317
152 Lubeck DP, Litwin MS, Henning JM, Changes in health-related quality of life in the first year after treatment for prostate cancer: results from CaPSURE. Urology. 1999;53(1):180–6.9886609
153 Pfeiffer D, Berger J, Gross AJ. Single application of high-intensity focused ultrasound as a first-line therapy for clinically localized prostate cancer: 5-year outcomes. BJU international. 2012;110(11):1702–7. http://dx.doi.org/10.1111/j.1464-410X.2012.11375.x 22928703
154 Potosky AL, Reeve BB, Clegg LX, Quality of life following localized prostate cancer treated initially with androgen deprivation therapy or no therapy. Journal of the National Cancer Institute. 2002;94(6):430–7.11904315
155 Rabbani F, Yunis LH, Pinochet R, Comprehensive standardized report of complications of retropubic and laparoscopic radical prostatectomy. European urology. 2010;57(3):371–86. 10.1016/j.eururo.2009.11.034 19945779
156 Schapira MM, Lawrence WF, Katz DA, Effect of treatment on quality of life among men with clinically localized prostate cancer. Med Care. 2001;39(3):243–53.11242319
157 Shah C, Jones PM, Wallace M, Differences in disease presentation, treatment outcomes, and toxicities in African American patients treated with radiation therapy for prostate cancer. Am J Clin Oncol. 2012;35(6):566–71. http://dx.doi.org/10.1097/COC.0b013e3182208262 21694572
158 Siegel T, Moul JW, Spevak M, The development of erectile dysfunction in men treated for prostate cancer. J Urol. 2001;165(2):430–5. 10.1097/00005392-200102000-00019 11176390
159 Smith DP, King MT, Egger S, Quality of life three years after diagnosis of localised prostate cancer: population based cohort study. Bmj. 2009;339:b4817. 10.1136/bmj.b4817 19945997
160 Smith DS, Carvalhal GF, Schneider K, Quality-of-life outcomes for men with prostate carcinoma detected by screening. Cancer. 2000;88(6):1454–63.10717630
161 Thong MS, Mols F, Kil PJ, Prostate cancer survivors who would be eligible for active surveillance but were either treated with radiotherapy or managed expectantly: comparisons on long-term quality of life and symptom burden. BJU international. 2010;105(5):652–8. 10.1111/j.1464-410X.2009.08815.x 19747357
162 Thuroff S, Chaussy C, Vallancien G, High-intensity focused ultrasound and localized prostate cancer: efficacy results from the European multicentric study. J Endourol. 2003;17(8):673–7. 10.1089/089277903322518699 14622488
163 Uchida T, Tomonaga T, Kim H, Improved outcomes with advancements in high intensity focused ultrasound devices for the treatment of localized prostate cancer. Journal of Urology. 2015;193(1):103–10. http://dx.doi.org/10.1016/j.juro.2014.07.096 25079940
164 Walz J, Montorsi F, Jeldres C, The effect of surgical volume, age and comorbidities on 30-day mortality after radical prostatectomy: a population-based analysis of 9208 consecutive cases. BJU international. 2008;101(7):826–32. 10.1111/j.1464-410X.2007.07373.x 18321316
165 Yao SL, Lu-Yao G. Population-based study of relationships between hospital volume of prostatectomies, patient outcomes, and length of hospital stay. Journal of the National Cancer Institute. 1999;91(22):1950–6.10564679
166 Donovan J, Hamdy F, Lane J, Patient-Reported Outcomes after Monitoring, Surgery, or Radiotherapy for Prostate Cancer. New England Journal of Medicine. 2016;375(15):1425–37.27626365
167 Foley RW, Maweni RM, Gorman L, The ERSPC Risk Calculators Significantly Outperform The PCPT 2.0 In The Prediction Of Prostate Cancer; A Multi-Institutional Study. BJU international. 2016. 10.1111/bju.13437
168 Poyet C, Nieboer D, Bhindi B, Prostate cancer risk prediction using the novel versions of the European Randomised Study for Screening of Prostate Cancer (ERSPC) and Prostate Cancer Prevention Trial (PCPT) risk calculators: independent validation and comparison in a contemporary European cohort. BJU international. 2016;117(3):401–8. 10.1111/bju.13314 26332503
169 Lundon DJ, Kelly BD, Foley R, Prostate cancer risk assessment tools in an unscreened population. World journal of urology. 2015;33(6):827–32. http://dx.doi.org/10.1007/s00345-014-1365-7 25091862
170 Ankerst DP, Hoefler J, Bock S, Prostate Cancer Prevention Trial risk calculator 2.0 for the prediction of low- vs high-grade prostate cancer. Urology. 2014;83(6):1362–7. http://dx.doi.org/10.1016/j.urology.2014.02.035 24862395
171 Ankerst DP, Boeck A, Freedland SJ, Evaluating the Prostate Cancer Prevention Trial High Grade prostate cancer risk calculator in 10 international biopsy cohorts: Results from the prostate biopsy collaborative group. World journal of urology. 2014;32(1):185–91.22527674
172 Roobol MJ, van Vugt HA, Loeb S, Prediction of Prostate Cancer Risk: The Role of Prostate Volume and Digital Rectal Examination in the ERSPC Risk Calculators. European urology. 2012;61(3):577–83. 10.1016/j.eururo.2011.11.012 22104592
173 Nam RK, Kattan MW, Chin JL, Prospective multi-institutional study evaluating the performance of prostate cancer risk calculators. Journal of Clinical Oncology. 2011;29(22):2959–64. http://dx.doi.org/10.1200/JCO.2010.32.6371 21690464
174 Ngo TC, Turnbull BB, Lavori PW, The prostate cancer risk calculator from the Prostate Cancer Prevention Trial underestimates the risk of high grade cancer in contemporary referral patients. Journal of Urology. 2011;185(2):483–7. http://dx.doi.org/10.1016/j.juro.2010.09.101 21167519
175 Trottier G, Roobol MJ, Lawrentschuk N, Comparison of risk calculators from the Prostate Cancer Prevention Trial and the European Randomized Study of Screening for Prostate Cancer in a contemporary Canadian cohort. BJU international. 2011;108(8 Pt 2):E237–44. http://dx.doi.org/10.1111/j.1464-410X.2011.10207.x 21507190
176 Nguyen CT, Yu C, Moussa A, Performance of prostate cancer prevention trial risk calculator in a contemporary cohort screened for prostate cancer and diagnosed by extended prostate biopsy. J Urol. 2010;183(2):529–33. 10.1016/j.juro.2009.10.007 20006887
177 Hernandez DJ, Han M, Humphreys EB, Predicting the outcome of prostate biopsy: comparison of a novel logistic regression-based model, the prostate cancer risk calculator, and prostate-specific antigen level alone. BJU international. 2009;103(5):609–14. 10.1111/j.1464-410X.2008.08127.x 19007374
178 Sandblom G, Varenhorst E, Rosell J, Randomised prostate cancer screening trial: 20 year follow-up. BMJ. 2011;342:d1539. 10.1136/bmj.d1539 21454449
179 Kjellman A, Akre O, Norming U, 15-year followup of a population based prostate cancer screening study. J Urol. 2009;181(4):1615–21; discussion 21. 10.1016/j.juro.2008.11.115 19233435
180 Djulbegovic M, Beyth RJ, Neuberger MM, Screening for prostate cancer: systematic review and meta-analysis of randomised controlled trials. BMJ. 2010;341:c4543. 10.1136/bmj.c4543 20843937
181 Ilic D, O’Connor D, Green S, Screening for prostate cancer: an updated Cochrane systematic review. BJU international. 2011;107(6):882–91. 10.1111/j.1464-410X.2010.10032.x 21392207
182 Cuzick J, Thorat MA, Andriole G, Prevention and early detection of prostate cancer. The Lancet Oncology. 2014;15(11):e484–92. 10.1016/s1470-2045(14)70211-6 25281467
183 Shoag JE, Mittal S, Hu JC. Reevaluating PSA Testing Rates in the PLCO Trial. The New England journal of medicine. 2016;374(18):1795–6. 10.1056/NEJMc1515131 27144870
184 Otto SJ, van der Cruijsen IW, Liem MK, Effective PSA contamination in the Rotterdam section of the European Randomized Study of Screening for Prostate Cancer. International journal of cancer Journal international du cancer. 2003;105(3):394–9. 10.1002/ijc.11074 12704675
185 Wolters T, Roobol MJ, Van Leeuwen PJ, A critical analysis of the tumor volume threshold for clinically insignificant prostate cancer using a data set of a randomized screening trial. Journal of Urology. 2011;185(1):121–5.21074212
186 Powell IJ, Vigneau FD, Bock CH, Reducing prostate cancer racial disparity: evidence for aggressive early prostate cancer PSA testing of African American men. Cancer Epidemiol Biomarkers Prev. 2014;23(8):1505–11. http://dx.doi.org/10.1158/1055-9965.EPI-13-1328 24802741
187 van Leeuwen PJ, Connolly D, Tammela TL, Balancing the harms and benefits of early detection of prostate cancer. Cancer. 2010;116(20):4857–65. 10.1002/cncr.25474 20839233
188 Gulati R, Feuer EJ, Etzioni R. Conditions for Valid Empirical Estimates of Cancer Overdiagnosis in Randomized Trials and Population Studies. American journal of epidemiology. 2016;184(2):140–7. 10.1093/aje/kwv342 27358266
189 Lu-Yao GL, Albertsen PC, Moore DF, Fifteen-year Outcomes Following Conservative Management Among Men Aged 65 Years or Older with Localized Prostate Cancer. European urology. 2015;68(5):805–11. 10.1016/j.eururo.2015.03.021 25800944
190 Litwin MS, Hays RD, Fink A, The UCLA Prostate Cancer Index: development, reliability, and validity of a health-related quality of life measure. Med Care. 1998;36(7):1002–12.9674618
191 Yao A, Iwamoto H, Masago T, The role of staging MRI in predicting apical margin positivity for robot-assisted laparoscopic radical prostatectomy. Urologia Internationalis. 2014;93(2):182–8. http://dx.doi.org/10.1159/000358175 24863097
192 National Cancer Institute, Surveillance Epidemiology and End Results Program (SEER). Prostate Cancer Outcomes Study - Landmark Studies. http://seer.cancer.gov/archive/studies/endresults/study24.html. Accessed: September 13, 2016.
193 Yaxley JW, Coughlin GD, Chambers SK, Robot-assisted laparoscopic prostatectomy versus open radical retropubic prostatectomy: early outcomes from a randomised controlled phase 3 study. Lancet (London, England). 2016;388(10049):1057–66. 10.1016/s0140-6736(16)30592-x
194 Nguyen PL, Alibhai SM, Basaria S, Adverse effects of androgen deprivation therapy and strategies to mitigate them. European urology. 2015;67(5):825–36. 10.1016/j.eururo.2014.07.010 25097095
195 Roobol MJ, Schroder FH, Hugosson J, Importance of prostate volume in the European Randomised Study of Screening for Prostate Cancer (ERSPC) risk calculators: results from the prostate biopsy collaborative group. World journal of urology. 2012;30(2):149–55. http://dx.doi.org/10.1007/s00345-011-0804-y 22203238
196 Louie KS, Seigneurin A, Cathcart P, Do prostate cancer risk models improve the predictive accuracy of PSA screening? A meta-analysis. Annals of Oncology. 2015;26(5):848–64.25403590
197 Welch HG, Albertsen PC. Prostate cancer diagnosis and treatment after the introduction of prostate-specific antigen screening: 1986–2005. Journal of the National Cancer Institute. 2009;101(19):1325–9. 10.1093/jnci/djp278 19720969
198 Zappa M, Ciatto S, Bonardi R, Overdiagnosis of prostate carcinoma by screening: an estimate based on the results of the Florence Screening Pilot Study. Ann Oncol. 1998;9(12):1297–300.9932159
199 Draisma G, Boer R, Otto SJ, Lead times and overdetection due to prostate-specific antigen screening: estimates from the European Randomized Study of Screening for Prostate Cancer. Journal of the National Cancer Institute. 2003;95(12):868–78.12813170
200 Draisma G, Etzioni R, Tsodikov A, Lead time and overdiagnosis in prostate-specific antigen screening: importance of methods and context. Journal of the National Cancer Institute. 2009;101(6):374–83. 10.1093/jnci/djp001 19276453
201 Etzioni R, Penson DF, Legler JM, Overdiagnosis due to prostate-specific antigen screening: lessons from U.S. prostate cancer incidence trends. Journal of the National Cancer Institute. 2002;94(13):981–90.12096083
202 Roth JA, Gulati R, Gore JL, Improving the value of PSA prostate cancer screening with “smarter” strategies and increased use of active surveillance. Journal of Clinical Oncology. 2015;33(15).
203 Carlsson S, Assel M, Sjoberg D, Influence of blood prostate specific antigen levels at age 60 on benefits and harms of prostate cancer screening: population based cohort study. BMJ. 2014;348:g2296. 10.1136/bmj.g2296 24682399
204 Siddiqui MM, Rais-Bahrami S, Turkbey B, Comparison of MR/ultrasound fusion-guided biopsy with ultrasound-guided biopsy for the diagnosis of prostate cancer. Jama. 2015;313(4):390–7. 10.1001/jama.2014.17942 25626035
205 Ahmed HU, El-Shater Bosaily A, Brown LC, Diagnostic accuracy of multi-parametric MRI and TRUS biopsy in prostate cancer (PROMIS): a paired validating confirmatory study. Lancet (London, England). 2017. 10.1016/s0140-6736(16)32401-1
206 Panebianco V, Barchetti F, Sciarra A, Multiparametric magnetic resonance imaging vs. standard care in men being evaluated for prostate cancer: a randomized study. Urol Oncol. 2015;33(1):17.e1–7. 10.1016/j.urolonc.2014.09.013
207 Pokorny MR, De Rooij M, Duncan E, Prospective Study of Diagnostic Accuracy Comparing Prostate Cancer Detection by Transrectal Ultrasound-Guided Biopsy Versus Magnetic Resonance (MR) Imaging with Subsequent MR-guided Biopsy in Men Without Previous Prostate Biopsies. European urology. 2014;66(1):22–9. 10.1016/j.eururo.2014.03.002 24666839
208 Tonttila PP, Lantto J, Paakko E, Prebiopsy Multiparametric Magnetic Resonance Imaging for Prostate Cancer Diagnosis in Biopsy-naive Men with Suspected Prostate Cancer Based on Elevated Prostate-specific Antigen Values: Results from a Randomized Prospective Blinded Controlled Trial. European urology. 2016;69(3):419–25. 10.1016/j.eururo.2015.05.024 26033153
209 Radtke JP, Kuru TH, Boxler S, Comparative analysis of transperineal template saturation prostate biopsy versus magnetic resonance imaging targeted biopsy with magnetic resonance imaging-ultrasound fusion guidance. J Urol. 2015;193(1):87–94. 10.1016/j.juro.2014.07.098 25079939
210 Schoots IG, Petrides N, Giganti F, Magnetic resonance imaging in active surveillance of prostate cancer: a systematic review. European urology. 2015;67(4):627–36. 10.1016/j.eururo.2014.10.050 25511988
211 Ilic D, Jammal W, Chiarelli P, Assessing the effectiveness of decision aids for decision making in prostate cancer testing: a systematic review. Psycho-Oncol. 2015;24(10):1303–15. 10.1002/pon.3815
212 Stacey D, Legare F, Col NF, Decision aids for people facing health treatment or screening decisions. Cochrane Database of Systematic Reviews. 2014(1):335. 10.1002/14651858.CD001431.pub4
213 Berry DL, Halpenny B, Hong F, The Personal Patient Profile-Prostate decision support for men with localized prostate cancer: a multi-center randomized trial. Urol Oncol. 2013;31(7):1012–21. 10.1016/j.urolonc.2011.10.004 22153756
214 Wang EH, Gross CP, Tilburt JC, Shared decision making and use of decision AIDS for localized prostate cancer: perceptions from radiation oncologists and urologists. JAMA internal medicine. 2015;175(5):792–9. 10.1001/jamainternmed.2015.63 25751604
215 Tosoian JJ, Mamawala M, Epstein JI, Intermediate and Longer-Term Outcomes From a Prospective Active-Surveillance Program for Favorable-Risk Prostate Cancer. J Clin Oncol. 2015;33(30):3379–85. 10.1200/jco.2015.62.5764 26324359
216 Klotz L, Vesprini D, Sethukavalan P, Long-term follow-up of a large active surveillance cohort of patients with prostate cancer. J Clin Oncol. 2015;33(3):272–7. 10.1200/jco.2014.55.1192 25512465
217 Qaseem A, Barry MJ, Denberg TD, Screening for prostate cancer: a guidance statement from the Clinical Guidelines Committee of the American College of Physicians. Annals of internal medicine. 2013;158(10):761–9. 10.7326/0003-4819-158-10-201305210-00633 23567643
218 Carroll PR, Parsons JK, Andriole G, Prostate cancer early detection, version 1.2014. Featured updates to the NCCN Guidelines. J Natl Compr Cancer Netw. 2014;12(9):1211–9; quiz 9.
219 Shea BJ, Hamel C, Wells GA, AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. 2009;62(10):1013–20. 10.1016/j.jclinepi.2008.10.009 19230606
220 Labrie F, Candas B, Cusan L, Screening decreases prostate cancer mortality: 11-year follow-up of the 1988 Quebec prospective randomized controlled trial. The Prostate. 2004;59(3):311–8. 10.1002/pros.20017 15042607
221 Wang W, Wang M, Wang L, Diagnostic ability of %p2PSA and prostate health index for aggressive prostate cancer: a meta-analysis. Sci. 2014;4:5012. http://dx.doi.org/10.1038/srep05012
222 Foley RW, Gorman L, Sharifi N, Improving multivariable prostate cancer risk assessment using the Prostate Health Index. BJU international. 2016;117(3):409–17. 10.1111/bju.13143 25847734
223 Mohler JL, Armstrong AJ, Bahnson RR, Prostate Cancer, Version 1.2016. J Natl Compr Canc Netw. 2016;14(1):19–30.26733552
224 Bostrom PJ, Bjartell AS, Catto JW, Genomic Predictors of Outcome in Prostate Cancer. European urology. 2015;68(6):1033–44. 10.1016/j.eururo.2015.04.008 25913390
225 Moore CM, Ridout A, Emberton M. The role of MRI in active surveillance of prostate cancer. Current Opinion in Urology. 2013;23(3):261–7. http://dx.doi.org/10.1097/MOU.0b013e32835f899f 23478498
226 PRostate Evaluation for Clinically Important Disease: Sampling Using Image-guidance or Not? (PRECISION). [database on the Internet]. National Library of Medicine. Available from: https://clinicaltrials.gov/ct2/show/NCT02380027.