# Acknowledgments

The authors acknowledge the following individuals for their comments on the research plan or earlier drafts of this report: Otis Brawley, MD, Chief Medical and Scientific Officer, American Cancer Society; Peter Carroll, MD, MPH, Chair of Urology, University of California, San Francisco; Phillip Dahm, MD, MHSc, Professor of Urology, University of Minnesota; David Penson, MD, MPH, Chair of Urologic Surgery, Vanderbilt-Ingram Cancer Center; Ian Thompson, MD, Distinguished Chair in Genitourinary Oncology, University of Texas Health Science Center at San Antonio; Andrew Vickers, DPhil, Attending Research Methodologist, Memorial Sloan Kettering Cancer Center (external expert reviewers); Rina Das, PhD, Program Officer, National Institute on Minority Health and Health Disparities; Barry Kramer, MD, MPH, Director, Division of Cancer Prevention, National Cancer Institute (NCI); Eliseo Perez-Stable, MD, Director, National Institute on Minority Health and Health Disparities; Paul Pinsky, PhD, Acting Chief, Early Detection Research Branch, Division of Cancer Prevention, NCI; Philip Prorok, PhD, Chief of Biometry, Division of Cancer Prevention, NCI; Mary Roary, PhD, Program Director, National Institute of Nursing Research; and two anonymous reviewers from the Centers for Disease Control and Prevention; Michael LeFevre, MD, MSPH, Vice Chair of Family and Community Medicine, University of Missouri; Jennifer S. Lin, MD, MCR, Director, Kaiser Permanente EPC; Russell P. Harris, MD, MPH, Adjunct Professor of Epidemiology, University of North Carolina–Chapel Hill; and David Meyers, MD, Chief Medical Officer, AHRQ.