# Chapter 4 Discussion

## Summary of Evidence

The results of this synthesis are summarized in Table 29. We systematically reviewed the literature to assess the benefits and harms of PSA screening for prostate cancer. Recognizing that long-term impacts of screening are affected by treatment outcomes, we also systematically reviewed the literature on the benefits and harms of treatment for early-stage or screen-detected prostate cancer. We further synthesized evidence on whether screening or treatment benefits and harms may be greater or lesser among patient subgroups. Finally, we summarized the literature on the utility of prostate cancer risk calculators in distinguishing men with and without clinically significant prostate cancers prior to biopsy.

Table 29 Summary of Evidence: Main Findings

Intervention or Population | Outcome | No. of Studies (k), No. of Observations (n) | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence | Applicability
KQ1
PSA-based screening vs. no screening among asymptomatic men | Prostate cancer mortality | k=2 RCTs (PLCO and ERSPC) n=239,081 (ages 55 to 74 years in PLCO, ages 55 to 69 in ERSPC core age group) | [underlined: PLCO] RR=1.04 (95% CI, 0.87 to 1.24) at median 14.8 years followup [underlined: ERSPC] RR=0.79 (95% CI, 0.69 to 0.91) at median 13 years followup (core age group) RR=0.83 (95% CI, 0.73 to 0.94) (ages 50 to 74 years) NNI to prevent 1 prostate cancer death=781 (95% CI, 490 to 1929) NND=27 (95% CI, 17 to 66) | Inconsistent; Reasonably precise | Undetected | Fair | PLCO trial limited by contamination in control group. ERSPC PSA thresholds for biopsy were generally lower than in U.S. Among ERSPC enrollees diagnosed with prostate cancer, men randomized to screening were more likely to be treated with RP compared to controls. | Moderate | Applicability of ERSPC results to U.S. practice is uncertain because of the lower thresholds for biopsy and high rate of biopsy after positive screens at the 2 ERSPC sites demonstrating prostate cancer specific-mortality or all-cause mortality reduction.
PSA-based screening vs. no screening among asymptomatic men | All-cause mortality | k=2 RCTs (PLCO and ERSPC) n=239,081 (ages 55 to 74 years in PLCO, ages 55 to 69 in ERSPC core age group) | [underlined: PLCO] RR=0.98 (95% CI, 0.95 to 1.00; p=0.11) at median 14.8 years followup [underlined: ERSPC] RR=1.00 (95% CI, 0.98 to 1.02; p=0.82) (core age group) at median 13 years followup | Reasonably consistent; Imprecise | Undetected | Fair | Trials were underpowered to detect the small differences in all-cause mortality that might be expected with prostate cancer screening. | Low-to-moderate
PSA-based screening vs. no screening among asymptomatic men | Cumulative incidence of metastatic prostate cancer | k=1 RCT (ERSPC, 4 sites) n=76,813 men ages 55 to 69 years | RR of metastatic cancer in screening arm vs. control= 0.70 (95% CI, 0.60 to 0.82) ARR=3.1 cases of metastatic cancer per 1,000 men randomized | Reasonably precise | Undetected | Fair | Data derived from only 4 of 7 ERSPC trial sites, including the only 2 sites that demonstrated prostate cancer mortality reductions. | Low-to-moderate | PSA thresholds for biopsy were lower (2.5 to 3.0 ng/mL) than in U.S. practice; uncertain whether similar reductions in metastatic disease incidence would be achieved with a higher PSA threshold for biopsy.
KQ2
PSA-based screening among asymptomatic men | False-positive PSA tests (positive PSA test but no cancer diagnosis within 1 year of screening) | k=2 RCT (PLCO, ERSPC, 5 sites; PLCO) n=130,040 men | [underlined: PLCO]: 10.4% of men with ≥1 PSA screen had ≥1 false-positive screens. The cumulative risk of receiving ≥1 false positives was 5.4% with 1 screening test, 7.9% with 2, 10.4% with 3, and 12.9% with 4 tests. ERSPC 17.8% of screened men had ≥1 false-positive screening tests. 44.9% of screened men in Sweden had ≥1 false-positive screens (biennial screening with 2.5 ng/mL positive threshold) | Reasonably precise | Undetected | Fair | ERSPC sites had variable screening intervals, thresholds for positive tests | Moderate | PLCO results should be general izable to U.S. practice.
PSA-based screening among asymptomatic men | Biopsy postpositive PSA test | K=3 (2 RCTs, 1 cohort); n=133,969 | [underlined: PLCO] 12.6% of men randomized to screening had a prostate biopsy (67.7% were negative for cancer) 4.6% men screened had a moderately-invasive procedure (mostly biopsies) as a result of a false-positive The cumulative risk of receiving ≥1 moderately-invasive procedures as a result of a false-positive increased with each PSA test to 5.5% of screened men with 4 tests. [underlined: ERSPC] 27.7 biopsies per 100 men randomized to screening (75.8% were negative for cancer) [underlined: VA cohort] 2.8% of screened men underwent biopsy due to positive screens. 51.2% had repeat PSA rather than biopsy | Inconsistent; Reasonably precise | Undetected | Fair | PLCO diagnostic followup was coordinated by community physicians, so biopsy rate after positive screening was lower in PLCO than in ERSPC (44.8% vs. 85.6%). | Moderate | Rate of biopsy after positive PSA in U.S. may be lower than both the PLCO and ERSPC, as many men may undergo monitoring (e.g., repeat PSA measurement) instead of biopsy for initial PSA elevation on screening.
PSA-based screening among asymptomatic men | Overdiagnosis of screen-detected prostate cancer | k=2 RCTs (PLCO and ERSPC) n=239,081 (ages 55 to 74 years in PLCO, ages 55 to 69 in ERSPC core age group) | [underlined: PLCO] 20.7% of screen-detected cancer overdiagnosed [underlined: ERSPC]y50.4% of screen-detected cancer overdiagnosed | Inconsistent; Reasonably precise | Undetected | Fair | 13 year median followup may be too short to observe full catchup incidence in control arms. Use of PSA screening in control arms would bias estimates toward null. | Low | ERSPC screening protocols used a lower PSA cutoff for biopsy referral than is typical in U.S. practice, which may have increased overdiagnosis.
Men receiving prostate biopsy after a positive PSA test | Biopsy-related symptoms | k=2 (1 RCT, ERSPC, and 1 cohort, U.K. cohort) n=6,823 | [underlined: ERSPC] Hematuria 3 days: 22.6% Hematospermia: 50.4% Rectal bleeding: 1.3% Pain after biopsy: 7.5% Fever: 3.5% Nausea/sickness: 0.3% [underlined: UK Cohort] Symptoms rated as “major/moderate” within 35 days of biopsy: Pain: 7.3% (95% CI, 5.7 to 9.1%) Fever: 5.5% (95% CI, 4.2 to 7.1%) Hematuria: 6.2% (95% CI: 4.7 to 7.9%) Hemejaculate: 26.6% (23.3 to 30.2%) | Reasonably precise | Undetected | Good | Men ages 50-69 years and participating in the U.K. ProtecT trial screening phase (ProBE cohort). | Moderate | Likely to be general izable to asymptomatic men receiving biopsy in the U.S. for abnormal PSA screening.
Men receiving prostate biopsy after a positive PSA test | Biopsy-related medical complications | k=2 (1 RCT, 1 cohort) n=13,149 | [underlined: PLCO] 20.2 complications per 1000 biopsies (7.8 infectious vs. 13.0 non-infectious) [underlined: VA cohort] 5.6% with infectious or urinary complications within 7 days | Reasonably consistent; reasonably precise | Undetected | Fair | Minor complications not requiring medical may not have been ascertained in either study | Moderate | Likely to be general izable to U.S. practice
Men receiving prostate biopsy after a positive PSA test | Biopsy-related health care utilization | k=2(2 cohorts) n=9,460 | [underlined: U.K. cohort study]: 1.3% hospitalized within 35 days (95% CI, 0.8 to 2.1%), 0.6% for sepsis 10.4% sought outpatient care for biopsy-related symptoms (95% CI, 8.7 to 12.3%) [underlined: VA cohort]: 1.6% hospitalized | Reasonably consistent; reasonably precise | Undetected | 1 good, 1 fair | Small number of studies based in either U.K. or U.S. VA settings | Moderate | Study samples generally similar to men undergoing biopsy after screening in U.S.
Men receiving prostate biopsy after a positive PSA test | Biopsy-related mortality | k=2 (1 RCT, 1 cohort) n=5,943 | [underlined: PLCO] Mortality vs. men with negative screens (120 days post-biopsy): RR=0.49 (95% CI, 0.2 to 1.1). [underlined: U.K. cohort]: 0% died (95% CI, 0.0% to 0.4%) | Reasonably consistent; imprecise | Undetected | Fair | Sample sizes do not allow adequate power to detect meaningful increase in mortality after biopsy | Low | Study samples generally similar to men undergoing biopsy after screening in U.S.
PSA-based screening among asymptomatic men and men receiving a prostate biopsy after a positive PSA test | Psychological harms of PSA screening | k=3 cohorts (U.S., U.K.); n=1,179 | Men with abnormal PSA screens have increased prostate-cancer specific worry up to 1 years after screening but no increase in state-anxiety or depression | Consistent, somewhat imprecise | Undetected | Fair | Small study samples | Moderate | Results should apply to U.S. practice
PSA-based screening among asymptomatic men and men receiving a prostate biopsy after a positive PSA test | Adverse effects of screening on health-related quality of life | k=1 RCT (Finnish ERSPC; men randomized to screening [n, range: 215-386 for each screening event]); 1 U.S. cohort (n=210) | Compared to measures invitation to participate in RCT, median scores were similar after later screening events for all domains of the SF-36. No evidence of adverse impact of abnormal screening on mental or physical health status in U.S. cohort. | Imprecise, consistent | Undetected | Fair | Small sample sizes limited power. | Moderate | Finnish RCT population may not generalize to U.S. practice
KQ3
RP vs. CM among men with early-stage or screen-detected cancer | Prostate cancer mortality | k=7 (3 RCTs, 4 cohorts); n=17,375 | [underlined: ProtecT] HR=0.63 (95% CI, 0.21 to 1.93) at 10 years median followup [underlined: PIVOT] HR=0.63 (95% CI, 0.39 to 1.02; p=0.06) at 12.7 years median followup [underlined: SPCG-4] RR=0.56 (95% CI, 0.41 to 0.77; p=0.001) at 13.4 years median followup [underlined: Cohorts] RP was associated with statistically significantly reduced prostate cancer mortality (median HR, 0.36 [range, 0.25 to 0.59]) compared to CM | Reasonably consistent, imprecise | Undetected | Fair | Only the ProtecT trial randomized exclusively men with screen-detected prostate cancer. Low event rate in this trial led to imprecise estimates with regard to prostate cancer mortality. Active surveillance protocol consisted chiefly of PSA monitoring. | Low | Active surveillance protocols in many U.S. settings include routine rebiopsy, physical exam, and selected use of imaging. ProtecT results may not generalize to U.S. practice or to men with low-risk cancers who are managed with surveillance.
RP vs. CM among men with early-stage or screen-detected cancer | All-cause mortality | k=11 (3RCTs, 8 cohorts); n=103,516 | [underlined: ProtecT] HR=0.93 (95% CI, 0.65 to 1.35) at 10 years median followup [underlined: PIVOT] HR=0.84 (95% CI, 0.70 to 1.01; p=0.06) at 12.7 years median followup [underlined: SPCG-4] RR=0.71 (95% CI, 0.59 to 0.86; p<0.001) at 13.4 years median followup [underlined: Cohorts] RP was associated with statistically significantly decreased risk for all-cause mortality in 5 of 7 studies (median adjusted HR, 0.44 [range, 0.32 to 0.50]) and no significant difference in all-cause mortality in 2 cohort studies. | Reasonably consistent, imprecise | Undetected | Fair | ProtecT not adequately powered to detect differences in all-cause mortality | Low
RP vs. CM among men with early-stage or screen-detected cancer | Progression to metastatic disease | k=3 (3 RCTs, 0 cohorts); n=3,069 | [underlined: ProtecT] Absolute incidence with RP 2.4 (95% CI, 1.4 to 4.2) per 1,000 person-years vs. 6.3 (95% CI, 4.5 to 8.8) with CM at 10 years median followup [underlined: PIVOT] HR=0.64 (95% CI, 0.42 to 0.97) at 12.7 years median followup [underlined: SPCG-4] RR=0.57 (95% CI, 0.44 to 0.75; p<0.001) at 13.4 years median followup | Reasonably consistent, Reasonably precise | Undetected | Good | See above regarding active surveillance protocol in ProtecT trial. PIVOT and SPCG-4 included men with clinically detected rather than screen-detected prostate cancer. | Moderate
RT vs. CM among men with early-stage or screen-detected cancer | Prostate cancer mortality | k=5 (1 RCT, 4 cohorts); n=15,024 | [underlined: ProtecT] HR=0.51 (95% CI, 0.15 to 1.69) at 10 years median followup [underlined: Cohorts] RT was not associated with a statistically significant reduction in 2 studies, while brachytherapy was associated with statistically significantly reduced prostate cancer-specific mortality in the third (HR, 0.45 [95% CI, 0.23 to 0.87]). | Inconsistent, imprecise | Undetected | Fair | Single trial with limited power and few cohort studies assessing this outcome | Low
RT vs. CM among men with early-stage or screen-detected cancer | All-cause mortality | k=8 (1 RCT, 7 cohorts); n=101,165 | [underlined: ProtecT] HR=0.94 (95% CI, 0.65 to 1.36) [underlined: Cohorts] RT was associated with a statistically significant reduction in all-cause mortality in 4 studies (median HR, 0.62 [range, 0.40 to 0.81]), but no statistically significant difference in 3. | Inconsistent, imprecise | Undetected | Fair | [underlined: ProtecT] was not adequately powered to detect meaningful differences in all-cause mortality | Low
RT vs. CM among men with early-stage or screen-detected cancer | Progression to metastatic disease | k=1 (1 RCT) n=1,643 | [underlined: ProtecT] Absolute incidence with RT 3.0 (95% CI, 1.9 to 4.9) per 1000 pyvs. 6.3 (95% CI, 4.5 to 8.8) with CM at 10 years median followup | Consistency NA reasonably precise | Undetected | Fair | Only 1 study assessed morbidity, therefore the results may not be general izable | Low-to-moderate
ADT vs. CM among men with early-stage or screen-detected cancer | Prostate cancer mortality | k=2(2 cohorts); n=70,033 | In an instrumental variable analysis, ADT was not associated with any difference in prostate cancer-specific mortality (adjusted HR, 1.01 [95% CI, 0.90 to 1.14]). Results from other cohorts mixed. | Inconsistent, imprecise | Undetected | Fair | Few studies, all with cohort design. Potential confounding by indication in cohort studies of treatment efficacy. | Low | Potential bias in study estimates may limit applicability to U.S. clinical populations.
ADT vs. CM among men with early-stage or screen-detected cancer | All-cause mortality | k=3(3 cohorts); n=74,333 | In an instrumental variable analysis, ADT was not associated with any difference in all-cause mortality (adjusted HR, 1.04 [95% CI, 0.99 to 1.09]). Results from other cohorts were mixed. | Inconsistent, imprecise | Undetected | Fair | As above | Low | Potential bias in study estimates may limit applicability to U.S. clinical populations.
ADT vs. CM among men with early-stage or screen-detected cancer | Morbidity | k=0 | NA | NA | NA | NA | Lack of evidence | Insufficient | Unknown
Cryotherapy vs. CM among men with early-stage or screen-detected cancer | Prostate cancer mortality, all-cause mortality, or morbidity | k=0 | NA | NA | NA | NA | Lack of evidence | Insufficient | Unknown
HIFU vs. CM among men with early-stage or screen-detected cancer | Prostate cancer mortality, all-cause mortality, or morbidity | k=0 | NA | NA | NA | NA | Lack of evidence | Insufficient | Unknown
KQ4
RP vs. CM among men with early-stage or screen-detected cancer | Urinary incontinence | k=9 (3 RCTs, 6 cohorts) n=7,529 | Pooled RR in the RCTs=2.3 (95% CI, 1.8 to 2.8; I^2^=0.0%) Pooled RR in the cohorts= 2.8 (95% CI, 1.8 to 4.2; I^2^=63.0%) | Reasonably consistent; Reasonably precise | Undetected | 5 good; 4 fair | Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. Approximately half of men in ProtecT who were randomized to CM received RP by the end of the trial. | Moderate | Likely to be general izable to U.S. practice
RP vs. CM among men with early-stage or screen-detected cancer | Erectile dysfunction | k=10(3RCTs, 7 cohorts) n=8,012 | Pooled RR in 2 of the RCTs=1.8 (95% CI, 1.6 to 2.0; I^2^=0.0%) Pooled RR in the cohorts= 1.5 (95% CI, 1.3 to 1.9; I^2^=59.2%) | Reasonably consistent; Reasonably precise | Undetected | 5 good; 5 fair | Excluded ProtecT trial from meta-analysis because it introduced large heterogeneity (I^2^=97.4%). Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Moderate | Likely to be general izable to U.S. practice
RP vs. CM among men with early-stage or screen-detected cancer | Bowel function | k=8 (3 RCTs, 5 cohorts) n=7,458 | RCTs found high fecal incontinence in men undergoing CM (2.6% to 5.7%) vs. RP (0.6% to 1.9%); results from cohort studies were inconsistent | Inconsistent; Imprecise | Undetected | 5 good; 3 fair | Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. Approximately half of men in ProtecT who were randomized to CM received RP by the end of the trial. | Low | Likely to be general izable to U.S. practice
RP vs. CM among men with early-stage or screen-detected cancer | Surgical complications | k=8 (2 RCTs, 6 uncontrolled observational); n=150,001 | 30-day perioperative mortality ranged from 0.0% to 0.52% (4 studies). Common complications included thromboembolic/cardiovascular events (0.4% to 9.0%) and reintervention (1.7% to 5.3%) | Perioperative mortality: reasonably consistent; Reasonably precise Complications Reasonably consistent; Imprecise | Undetected | 2 good; 6 fair | Trials did not present data on mortality or complications among men randomized to CM; uncontrolled observational studies included large sample sizes of men receiving RP but no comparison group | Moderate | Likely to be general izable to U.S. practice
RT vs. CM among men with early-stage or screen-detected cancer | Urinary incontinence | k=8 (2 RCTs, 6 cohorts) n=3,748 | RR (range): 0.4 to 8.31. Estimates not pooled due to high variability in outcome across studies | Inconsistent; Imprecise | Undetected | 3 good; 5 fair | Wide variation in risk of urinary incontinence; larger RCT favored RT and smaller RCT favored CM, while cohorts showed no significant differences. Approximately half of men in ProtecT who were randomized to CM received RT by the end of the trial. Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Low | Likely to be general izable to U.S. practice
RT vs. CM among men with early-stage or screen-detected cancer | Erectile dysfunction | k=9 (1 RCT, 8 cohorts) n=4,165 | Only one RCT (RR=0.9 [95% CI, 0.8 to 1.1]). Pooled RR in the cohorts= 1.3 (95% CI, 1.2 to 1.4; I^2^=0.0%) | Reasonably consistent (cohorts); Relatively precise | Undetected | 3 good; 6 fair | Approximately half of men in ProtecT who were randomized to CM received RT by the end of the trial. Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Moderate | Likely to be general izable to U.S. practice
RT vs. CM among men with early-stage or screen-detected cancer | Bowel function | k=7(2 RCTs, 5 cohorts); n=3,677 | Trials and cohorts found that fecal incontinence or rectal urgency was more common among men receiving RT (3.2% to 16.7%) than CM (0.2% to 4.8%) | Relatively consistent; Relatively precise | Undetected | 3 good; 4 fair | Approximately half of men in ProtecT who were randomized to CM received RT by the end of the trial. Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Moderate | Likely to be general izable to U.S. practice
ADT vs. CM among men with early-stage or screen-detected cancer | Urinary incontinence | k=2(2 cohorts); n=670 | Studies found no significant difference in men receiving ADT vs. CM | Relatively consistent; Imprecise | Undetected | Fair | Small number of studies with small sample size. Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Low | Likely to be general izable to U.S. practice
ADT vs. CM among men with early-stage or screen-detected cancer | Erectile dysfunction | k=3(3 cohorts); n=1,331 | RR (range): 1.6 to 2.9 | Relatively consistent; Relatively precise | Undetected | Fair | Small number of studies with small sample size. Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Moderate | Likely to be general izable to U.S. practice
ADT vs. CM among men with early-stage or screen-detected cancer | Bowel function | k=2(2 cohorts); n=670 | More men receiving ADT reported bowel problems, but no assessment of statistical significance | Relatively consistent; Imprecise | Undetected | Fair | Small number of studies with small sample size. Studies used varying outcome definitions and inconsistent timing or cross-sectional data collection. | Low | Likely to be general izable to U.S. practice
Cryotherapy vs. CM among men with early-stage or screen-detected cancer | Urinary incontinence, erectile dysfunction, bowel function | k=0 | No studies reported this outcomes | NA | NA | NA | Lack of evidence | Insufficient | Unknown
HIFU vs. CM among men with early-stage or screen-detected cancer | Urinary incontinence | k=7(7 uncontrolled observational) n=2,239 | Range of grade 2 urinary incontinence (leaking with mild activity, such as walking or standing up) or worse: 0.0% to 7.3% after 23 months to 6.4 years post-treatment | Relatively consistent; imprecise | Undetected | Fair | No studies comparing HIFU with CM; only 1 study had a sample size exceeding 1,000 men | Low | Likely to be general izable to U.S. practice
HIFU vs. CM among men with early-stage or screen-detected cancer | Erectile dysfunction | k=5(5 uncontrolled observational) n=1,046 | Among potent men pre-treatment (k=3), 37.3% to 52.7% had erectile dysfunction after 6 months to 4.8 years post-treatment | Relatively consistent; imprecise | Undetected | Fair | Not all studies reported pre-treatment potency so unable to ascertain impact of ADT treatment | Low | Likely to be general izable to U.S. practice
HIFU vs. CM among men with early-stage or screen-detected cancer | Bowel function | k=0 | No studies reported this outcomes | NA | NA | NA | Lack of evidence | Insufficient | Unknown
KQ5
Use of pre-biopsy risk calculator in combination with PSA vs. PSA alone to predict high-grade prostate cancer (i.e., Gleason >7 and/or stage T2b) | Discrimination | k=14 (evaluating calculators in 21 total cohorts) n=48,234 biopsies in North America, Europe, or South Korea All articles evaluated either the PCPT calculator (k= 14) or the ERSPC calculator (k=7) | Median AUC with PCPT calculator=0.72 (range, 0.51 to 0.88 across 21 cohorts) Median AUC with ERSPC calculator=0.74 (range, 0.69 to 0.78 across 7 cohorts) Median AUC with PSA alone=0.68 (range, 0.59 to 0.82 across 16 cohorts) | Inconsistent; reasonably precise | Undetected | Fair | Many biopsy cohorts consisted largely of symptomatic men rather than men undergoing biopsy after abnormal screening PSA. ERSPC calculator derived with ultrasound-derived prostate volume measure. | Low | Since most biopsy cohorts included many symptomatic men, results may not generalize to men referred for biopsy after abnormal PSA screening. It is unclear whether risk information from calculators can be accurately communicated to patients in actual practice and whether such information would modify decisions or long-term outcomes.
Use of pre-biopsy risk calculator in combination with PSA vs. PSA alone to predict high-grade prostate cancer (i.e., Gleason >7 and/or stage T2b) | Calibration Clinical utility | k=14 (evaluating calculators in 21 total cohorts) n=48,234 biopsies in North America, Europe, or South Korea All articles evaluated either the PCPT calculator (k= 14) or the ERSPC calculator (k=7) | Mixed for each calculator with acceptable calibration in some cohorts but under-or overestimation in others Decision curve analyses (k=14 for PCPT, k=4 for ERSPC) were mixed with net clinical harm found with calculator use in 2 cohorts for PCPT and 1 cohort for ERSPC calculator | Inconsistent; reasonably precise | Undetected | Fair | Many biopsy cohorts consisted largely of symptomatic men rather than men undergoing biopsy after abnormal screening PSA. ERSPC calculator derived with ultrasound-derived prostate volume measure. | Low

* Results for subgroups are not included, as there was limited data available across all KQs. For information about screening and treatment impacts on subgroups, please refer to the Results section of the report or Tables 7, 8, 16, 18 and 20.

Abbreviations: ADT=androgen deprivation therapy; ARR=absolute risk reduction; CM=conservative management; ERSPC=European Randomized Study of Screening for Prostate Cancer; HIFU=high-intensity focused ultrasound; HR=hazard ratio; NND=number needed to diagnose; NNI=number needed to invite; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; ProBE=Prostate Biopsy Effects study; RP=radical prostatectomy; RR=relative risk; RT=radiation therapy

### PSA-Based Screening

Of randomized trials of PSA screening, only the PLCO and ERSPC trials were of sufficient quality to inform key questions regarding screening effectiveness. Direct evidence from the two trials demonstrates that PSA screening substantially increases the detection of prostate cancer, particularly of early-stage, localized disease. Evidence from four ERSPC sites also suggests that screening can reduce the long-term incidence of metastatic disease. While the PLCO (at a median of 14.8 years of followup) found no association between randomization to annual screening and reduced prostate cancer mortality, the overall ERSPC results (at a median of 13.0 years of followup) suggest a 21 percent relative reduction in prostate cancer mortality with screening. Prostate cancer mortality was statistically significantly reduced at the Swedish and Netherlands ERSPC sites (each with comparatively high rates of biopsy), although point estimates favored screening at all sites except Switzerland. All-cause mortality was not reduced in either trial, and the number needed to diagnose (and potentially treat) to prevent one prostate cancer death in the ERSPC trial was 27 (95% CI, 17 to 66). Evidence is lacking on the differential benefit of screening among African-American men or men with a family history of prostate cancer.

Our review documented several harms stemming from prostate cancer screening. PSA screening is non-specific, and over one quarter of men randomized to screening in the PLCO had at least one positive screening PSA during up to six annual screening rounds. Most men with positive screening results who undergo biopsy will not have prostate cancer. The harms of biopsy include the pain, bleeding, and infectious complications. Perhaps the most serious harm of prostate cancer screening is overdiagnosis, because overdiagnosis burdens men with the harms of diagnosis and treatment without any benefit in terms of life expectancy or quality of life. We estimated that during the 13.0 years of median followup in the PLCO and ERSPC trials, approximately one-third to one-half of screen-detected cancers were overdiagnosed. Our estimates are largely consistent with estimates based on ecological or modeling studies based on U.S. and European data.^197^–^201^ We recognize that an ideal estimate of overdiagnosis would account for cancer incidence across a patient’s lifespan. However, followup duration in the trials does not allow such long-term projection, and post-trial use of PSA screening among participants in both screening and control arms will affect long-term incidence rates in both trial arms, obscuring future attempts to estimate overdiagnosis rates from the PLCO and ERSPC trials. Our results nevertheless suggest that, over a median time horizon of 13.0 years in each trial, a substantial fraction of cancers diagnosed by PSA screening are overdiagnosed.

### Prostate Cancer Treatments

Because prostate cancer screening markedly increases the rate of diagnosis of prostate cancer (especially of early-stage disease), a full picture of the benefits and harms of screening must incorporate the downstream impacts of early-stage prostate cancer treatments, particularly evidence regarding the comparative effectiveness and harms of active, potentially more harmful treatment modalities (e.g., surgery, radiation) versus conservative approaches, such as active surveillance. Evidence shows that the harms of active treatments for prostate cancer are common and long-lasting. A majority of men undergoing radical prostatectomy will have long-term erectile or sexual difficulties and one-third will have urinary difficulties, while one in seven men receiving radiation therapy experience erectile problems in addition to common bowel symptoms. Nevertheless, except for men treated with ADT, men with localized prostate cancers who underwent active and conservative treatments rated their overall quality of life and global health status similarly during extended followup, despite long-term differences in sexual and urinary function.

While earlier randomized trials comparing radical prostatectomy and watchful waiting included many men who were not diagnosed via PSA testing, the recent ProtecT trial compared prostatectomy, radiation therapy, and active surveillance (AS) among men with early-stage prostate cancer detected by screening PSA. Overall, survival at median followup of ten years was over 98.8 percent in each treatment arm, and no statistically significant differences in prostate cancer or all-cause mortality were detected. While power for these outcomes was low because of higher overall and prostate cancer-specific survival compared to earlier trials, nearly half of men assigned to AS were stable without receiving active treatment at 10 year followup, although a small absolute increase in the incidence of metastatic disease was observed in the AS arm as compared to the active treatment arms (approximately 6% with AS vs. 2 to 3% with active treatment). In contemporary case-series of men with low-risk prostate cancer, AS has been associated with cancer-specific survival rates exceeding 99 percent at 10 years of followup.^32^ Nevertheless, the low event rate in ProtecT, the short median followup, and the small numbers of men with extended followup in AS case series leads to uncertainty regarding long-term differences in prostate cancer mortality among men with screen-detected cancer managed with active treatments versus AS.

To integrate synthesized data on screening and treatment benefits and harms, we compared the absolute number of men experiencing various outcomes of screening under alternative assumptions regarding the impact of PSA screening on prostate cancer mortality (Table 28). Estimates for the three scenarios were derived from trial data for: 1) participants in the PLCO trial;^70^ 2) the ERSPC core-age group;^76^ and 3) participants in the Goteborg (Sweden) site,^82^ where the largest mortality reductions were observed among ERSPC sites. Under conditions of the ERSPC core-age group, we estimated that if 1,000 men were invited to undergo multiple PSA screening rounds, 1.3 men would avert prostate cancer death and 2.9 men would avert metastatic cancer during a median followup of 13 years. During this period, 243 men would have positive screening tests, and 220 men would undergo prostate biopsy, resulting in 34.8 additional men being diagnosed with prostate cancer (3.5% of total). If these 34.8 men were treated as men were treated in the ERSPC screening arm, 23.9 would receive radical treatments without benefit, and 6.9 and 1.8 men would develop erectile dysfunction or urinary incontinence, respectively, as a consequence of radical treatments. If 1,000 men were invited to be screened under conditions of the Goteborg site, 3.4 prostate cancer deaths and 3.5 metastatic cases would be averted but with proportionally greater harms related to screening and treatment, while no benefit would derive from screening under conditions of the PLCO. If many of the men diagnosed with localized prostate cancer received active surveillance rather than radical treatment, ProtecT trial data suggest that the number of men developing erectile dysfunction or incontinence could be reduced but with potential increases in the number of men with prostate cancer metastases.^121^

Table 28 Estimates of Benefits and Harms of PSA Screening per 1,000 Men Invited to Screening

Trial | PLCO | ERSPC (Core-Age Group) | Gotebörg, Sweden | Notes
Screening population and strategy | Men aged 55-74 y; screened annually for 6 years; PSA threshold for biopsy recommendation 4.0 ng/mL | Men aged 55-69 y; screened every 4 years (biennially in Sweden); PSA threshold for biopsy referral most commonly 3.0 ng/mL | Men aged 50-64 y; invited biennially up to age 70 y; PSA threshold for biopsy referral 3.0-3.5 ng/mL before 2005 and 2.5 ng/mL from 2005-2008 | Data for PLCO and Goteborg derived from reports with 13.0^80^ and 14.0^85^ y of median followup as more recent reports (with 14.8^90^ and 18.0^81^ y of median followup, respectively) lack some required data.
Median followup, y | 13.0 | 13.0 | 14.0
Outcome | Number of Men Affected | | | Source/Assumption
Men invited to screening | 1,000 | 1,000 | 1,000
≥1 positive screens | 282 | 243 | 248 | PLCO,^80^ ERSPC,^96^ and Goteborg^85^ trial reports; ERSPC study investigators (personal communication)
≥1 biopsy | 130 | 220 | 231 | PLCO,^80^ ERSPC,^96^ and Goteborg^85^ trial reports; ERSPC study investigators (personal communication)
Additional men hospitalized for biopsy complications | 1.7 | 2.9 | 3.0 | ProbE cohort study (1.3% hospitalized due to biopsy complications)^102^
Additional prostate cancers diagnosed due to screening^*^ | 11.3 | 34.8 | 42.0 | Absolute cumulative incidence differences and numbers needed to invite in trial reports
Additional men with erectile dysfunction due to treatment | 1.8 | 6.9 | 8.3 | Men with cancer allocated to primary treatments as in trial screening arms. For treatment harms, number needed to harm from pooled meta-analyses (KQ4)
Additional men with urinary incontinence after prostatectomy | 0.6 | 1.8 | 2.5 | Men with cancer allocated to primary treatments as in trial screening arms. For treatment harms, number needed to harm from pooled meta-analyses (KQ4)
Men treated with prostatectomy or radiation without benefits during followup period | NC | 23.9 | 25.8 | Number computed by subtracting number of men with prostate cancer death or metastasis averted from number of men actively treated
Metastatic cases averted | NR | 2.9 | 3.5 | ERSPC core-age group absolute risk reduction in metastatic disease cumulative incidence (and number needed to diagnose)
Prostate cancer deaths averted | 0 | 1.3 | 3.4 | Absolute risk reduction in prostate cancer deaths (and numbers needed to diagnose)

* Based on trial data, 99.5, 68.3, and 72.1 would be diagnosed with prostate cancer among 1,000 men not invited to screening in the PLCO, ERSPC (core-age group), and Goteborg, Sweden settings, respectively.

Abbreviations: PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; ERSPC=European Randomized Study of Screening for Prostate Cancer; NR=Not reported; NC=Not calculable; ProbE=Prostate Biopsy Effect cohort study; EPC=Evidence-based Practice Center; KQ4=Key Question 4

### Mitigating the Harms of Prostate Cancer Screening

Our review synthesized evidence on the potential for risk calculators to identify men with clinically significant prostate cancer, defined has higher-grade cancer or clinically aggressive cancer that is more likely to progress to locally advanced or metastatic disease. While we identified multiple external validation studies of two risk calculators, results were mixed regarding risk calculator discrimination, calibration, and clinical utility. The literature also does not address the practical challenges of implementing the calculators for screening or followup decisions in clinical practice, including the difficulty of communicating the numerical risk information to patients and caregivers. Additionally, no randomized trials have evaluated the impact of risk calculator use versus non-use on clinical decision-making, biopsy accuracy, or long-term incidence of advanced prostate cancer.

Greater use of AS for men with low-risk cancers may mitigate the harms stemming from PSA screening. As discussed in an accompanying review, recent modeling studies suggest that greater use of AS for low-risk cancer may tilt the balance of benefits and harms in PSA screening in favor screening.^202^ Longer term followup of men managed with AS is needed to understand whether differences in prostate cancer mortality emerge between actively and conservatively treated men with screen-detected cancer. Observational studies further suggest that screening may be deferred or screening intervals lengthened in men with lower PSAs on baseline screening.^187,203^

Efforts are ongoing to reduce the harms of PSA screening by improving the specificity of the screening process, reducing biopsies among cancer-free men, and decreasing overdiagnosis and overtreatment. Several strategies have been developed with the goal of improving the detection of men with aggressive cancer, including serum or urine tests, multivariable risk models, and multiparametric magnetic resonance imaging (mpMRI). In Appendix F, we focus on tests that are currently available in the U.S., and in the case of laboratory tests, that are Food and Drug Administration approved or included in National Comprehensive Cancer Network (NCCN) guidelines.^46^ For selected men with mild elevations of screening PSA, NCCN guidelines suggest consideration of one of several biomarker tests to assist in decision-making about whether to proceed to biopsy or whether to repeat biopsy if initial biopsy is negative. Although several tests have been shown to predict the presence of any prostate cancer or higher-grade prostate on biopsy, none of the biomarker tests or testing strategies described in Appendix F have been evaluated in completed randomized controlled trials, and few rigorous comparative effectiveness studies examining clinical outcomes have been reported. Research has also evaluated the use of multi-parametric magnetic resonance imaging (mpMRI) to improve biopsy accuracy, to evaluate men with negative biopsies, and to monitor men receiving active surveillance. Some studies suggest that mpMRI-targeted biopsy can increase the detection of higher-risk cancers,^204^–^207^ although other studies have yielded null or mixed results.^208,209^ Few studies have been conducted evaluating the role of mpMRI in active surveillance.^210^ Further research is needed to elucidate whether the use of adjunctive tests would improve the balance of benefits and harms of PSA-based prostate cancer screening in community settings.

### Shared Decisionmaking

Compared with traditional health education materials, decision aids are designed to personalize the selection of a care pathway by eliciting patient preferences and values through a structured discussion about the benefits, limitations, and uncertainties associated with medical interventions.^211,212^ In a 2015 systematic review of 13 randomized trials, decision aids about prostate cancer screening were associated with improved patient knowledge, reduced decisional conflict and uncertainty, and improved decisional satisfaction.^211^ With regard to screening behavior, a 2014 Cochrane review found a 13 percent pooled reduction in PSA screening with use of a decision aid (9 trials; RR, 0.87 [95% CI, 0.77 to 0.98]).^212^ In a single RCT evaluating a decision aid among men making treatment decisions for early-stage prostate cancer, a multimedia decision aid reduced decisional conflict but did not significantly modify treatment decisions.^213^ However, in the context of treatment, the adoption and use of decision aids may also be hindered by concerns among urologists and radiation oncologists that decision aids may not accurately estimate or communicate risk information to patients.^214^

## Limitations of the Evidence

### Length of Followup

Because the lead time for prostate cancer may be very long, it is conceivable that current trial reports (with 14.8 and 13.0 years of median followup in the PLCO and ERSPC, respectively) may underestimate prostate cancer mortality benefits. However, post-trial screening among men randomized to screening and control arms may obscure any potential mortality benefits of within-trial screening exposure.^81,183^ Meanwhile, in the ERSPC, there was no change in the relative risk of prostate cancer mortality in the screening vs. control arms when followup was extended from 11 to 13 years. Several modeling studies, summarized in separate reports that were submitted to the USPSTF, have assessed the lifetime impacts of prostate cancer screening. The 10 year median length of followup in the ProtecT trial may also be insufficient to delineate whether higher rates of metastatic disease in the AS arm will affect long-term prostate cancer mortality.

### Screening Trial Limitations

The two screening trials each had significant limitations. The principal limitation of the PLCO was the high-rate of use of PSA screening among men randomized to the control group. The large amount of screening conducted among control arm subjects would be expected to bias all PLCO study results toward the null. Meanwhile the ERSPC trial was limited by unexplained differences in treatments received by men diagnosed with prostate cancer in screening and control arms even after adjustment for clinical stage; subjects diagnosed with intermediate- or high-risk prostate cancer in the screening arm were more likely to be treated with radical prostatectomy and less likely to be treated with hormonal therapy than men diagnosed with similar cancers in the control arm. As these analyses are stratified by tumor risk, the treatment differences are not attributable to a screening effect. Thus, the apparent benefit of screening in the ERSPC trial may be at least partly explained by post-randomization treatment differences. Across ERSPC sites, there was also substantial variation in methods of recruitment, screening intervals, use of ancillary testing, and PSA thresholds for biopsy referral.

### Impact of Screening on High-Risk Populations

Some screening guidelines advocate an approach that accounts for risk factors for prostate cancer mortality (e.g., family history, African American descent). However, we found little direct evidence about whether tailoring screening approaches based on race/ethnicity or family history will reduce prostate cancer mortality risk in higher-risk men or alter the balance of screening benefits and harms. In observational studies, men with a low baseline PSA had a very low-risk of prostate cancer metastasis and death, implying that among men who initiate PSA screening, recommendations for ongoing testing could potentially be individualized based on baseline PSA.^187,203^

### Generalizability of Treatment Studies

The evidence on the comparative effectiveness of treatments for early-stage or screen-detected prostate cancer has grown considerably since the previous review,^50^ but is limited to four randomized trials and multiple cohort studies. Only one of the randomized trials exclusively enrolled men with screen-detected cancer (ProtecT), and prostate cancer-specific and all-cause mortality were extremely low in this study.^121^ Other treatment RCTs have enrolled many or mostly men with clinically detected prostate cancer.^117,133^ Thus, it remains uncertain whether treatment trial results are generalizable to U.S. populations of men with early-stage prostate cancer diagnosed by PSA screening. Meanwhile, when evaluating treatment effectiveness, cohort studies are subject to potential confounding by indication, as patients pursuing active treatments in cohort studies may be healthier in unmeasured ways that may exaggerate the benefits of active prostate cancer treatments.

Evidence on treatment harms predominately pertains to more traditional treatment techniques, such as retropubic radical prostatectomy and external beam radiotherapy; evidence is limited regarding more recently developed techniques, such as nerve-sparing or robotic prostatectomy, brachytherapy, and conformal radiotherapy. Evidence was limited regarding the effectiveness of cryotherapy or HIFU.

## Limitations of the Review

In addition to limitations discussed above, this review may be limited by language or publication biases. We also found limited evidence on some potential harms of ADT among men with early-stage prostate cancer and no long-term evidence on the carcinogenic potential of radiation therapy. Aside from uncontrolled studies of treatment harms, we found few or no studies on comparative effectiveness of new or novel treatment modalities, such as alternative surgical approaches to prostatectomy (e.g., nerve-sparing or robotic surgery), cryotherapy, or HIFU. Due to the limited use and variable definitions of active surveillance during the time periods of most included studies, we grouped active surveillance and watchful waiting in our analyses, although outcomes may differ between these two conservative approaches to prostate cancer treatment.

## Future Research Needs

Additional long term randomized trials of screening would be useful to confirm the effectiveness of prostate cancer screening and to more precisely quantify the impact of screening on prostate cancer mortality. An extension of the ProtecT trial, the CAP trial (Cluster randomized trial of PSA testing for Prostate Cancer) randomized U.K. practices to screening or usual care without screening and is expected to report results in 2017 or 2018.^126^ However, the low rate of prostate cancer death within the ProtecT trial suggests that statistical power may be low for mortality outcomes in the CAP trial. Randomized trials or comparative cohort studies would also be useful in evaluating alternate PSA screening protocols, adjunctive testing, or the differential impact among men at higher risk of prostate cancer, such as African-American men or men with a family history of prostate cancer.

There is a continuing need for evidence on comparative effectiveness of new or novel treatment approaches and their harms. To date, the ProtecT trial provides the only randomized evidence regarding the comparative effectiveness of active surveillance versus active treatments,^121^ yet the AS protocol in ProtecT consisted principally of serial PSA testing. It is conceivable that alternative AS protocols may be associated with lower risk of disease progression and metastasis than was observed with AS in ProtecT. Long-term prostate cancer survival has been very high in several case series of men with low-risk cancers treated initially with AS,^32,215,216^ but relatively few men in these series have been followed for more than 10 years, leading to uncertainty in long-term survival estimates. Ongoing followup of men in these series will be helpful in obtaining more precise estimates of the long-term prognosis of men managed with AS.

Research is also needed to assess the clinical impact of prostate cancer risk calculators when implemented in real practice prior to biopsy decisions. Ideally, such studies would use a randomized design to assess the long-term impact of communicating risk information derived from calculators on patient decisions and clinical outcomes (e.g., accurate detection of high-risk cancers). Research is also needed on outcomes from the use of risk calculators that incorporate newer modalities for pre-biopsy risk assessment, such as multiparametric MRI or tests based on novel biomarkers.

## Conclusion

PSA screening likely reduces the risk of prostate cancer mortality but screening benefits may require a high-rate of biopsy among screen-positive men. In the overall ERSPC trial during a 13.0 years median followup, approximately 27 men needed to be diagnosed with prostate cancer to prevent one prostate cancer death. In current practice, most men with screen-detected prostate cancer undergo active treatments, which are associated with risk of long-term urinary, sexual and bowel complications. Active surveillance of low-risk, screen-detected prostate cancer may mitigate treatment harms, although active surveillance in the ProtecT trial was associated with a higher risk of progression to metastatic disease compared to active treatments during 10 years of followup. Longer term followup is needed to delineate whether the higher rate of metastatic disease among men randomized to active surveillance will increase prostate cancer mortality compared to men randomized to active treatment.