# Chapter 3 Results

## Literature Search

Our literature search yielded 4,148 unique citations. From these, we provisionally accepted 302 articles for review based on titles and abstracts (Appendix A Figure 1). After screening the full-text articles, 2 trials (23 publications)^53,54,80^–^100^ were judged to have met the inclusion criteria for KQ1; 2 trials and 5 cohort studies (14 publications)^33,53,90,96,101^–^113^ were included for KQ2; 3 trials and 10 cohort studies (23 publications)^74,75,114^–^136^ were included for KQ3; 4 trials, 14 cohort studies and 14 uncontrolled observational studies (38 publications)^70,71,74^–^76,121,126,132,133,136^–^166^ were included for KQ 4, and; 13 studies (14 publications)^77^–^79,167^–^177^ were included for KQ5. The remaining articles were excluded (Appendix B).

## KQ1 Is There Direct Evidence That PSA-Based Screening for Prostate Cancer Reduces Short- or Long-Term Prostate Cancer Morbidity and Mortality and All-Cause Mortality?

We identified 2 fair-quality randomized controlled trials (RCTs) investigating the benefits of PSA-based screening for prostate cancer for the prevention of prostate cancer-specific morbidity and mortality and all-cause mortality (Tables 3 and 5–7). In the 2012, the USPSTF considered evidence from the Prostate, Lung, Colorectal, and Ovarian (PLCO)^53^ Cancer Screening Trial and the European Randomized Study of Screening for Prostate Cancer (ERSPC)^54^ trial, as well as separately published reports from the Goteborg center of the ERSPC trial.^85^ In 2012, the USPSTF also reviewed updated evidence from three trials previously rated as poor-quality,^178,179^ as well as results from a 2010 systematic review and meta-analysis^180^ and a 2011 updated Cochrane meta-analysis.^181^ The current review summarizes updated results with extended followup from the PLCO trial,^80,106^ the overall ERSPC trial,^96^ and separate updated reports from four ERSPC sites (Sweden,^81^ Finland,^87^ Netherlands,^92^ and Spain^89^). Subjects included in the site-specific ERSPC reports were also included in the overall trial results, so we interpret site-specific outcomes as ancillary, subgroup analyses of the main trial. We also summarize trial evidence on the potential differential impact of screening on subgroups of men with elevated prostate cancer risk (Table 8). As previously mentioned, the USPSTF previously reviewed three poor-quality randomized controlled trials in their prior assessment of the effectiveness of PSA-based screening for prostate cancer; due to their poor quality, we excluded these trials and briefly summarize the findings of these studies in Appendix D.

Table 3 Study Characteristics of Randomized, Controlled Trials of PSA-Based Prostate Cancer Screening

Study Reference Quality Rating | Location Study population (age and N) | PSA Screening Protocol | | | Enrollment Method | Compliance With Screening | Contamination in Control Arm | Followup
Study Reference Quality Rating | Location Study population (age and N) | PSA Threshold (ng/mL) | Screening Interval | Additional Screening Tests (If Any) | Enrollment Method | Compliance With Screening | Contamination in Control Arm | Followup
PLCO Pinsky, 2016^106^ Andriole, 2009^53^ Fair | United States Multi-center randomized trial (N=76,683)^‡^ Age (range): 55 to 74 years | 4.0 | Annual for up to 6 screening rounds | Annual DRE for first 4 years of the study | Volunteer | 85% (average compliance per screening round)^53^ | 46% overall had routine PSA testing during the screening phase (40% in year 1 and 52% by year 6)^53^ | 14.8 years (median)
ERSPC^*^ Schroder, 2014^96^ Ciatto, 2003^84^ Fair [underlined: ERSPC Site-Specific Reports] Sweden (Göteborg): Arnsrud Godtman, 2015^81^ Spain: Lujan, 2014^89^ Netherlands (Rotterdam): Roobol, 2013^92^ Bokhorst, 2014^82^ Finland: Kilpelainen, 2013^87^ Kilpelainen, in press^86^ | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, France)^†^ Men identified from population-based registries (N=162,388; core age group)^§^ Age (median): 60.2 years | Netherlands: 1993-1997: 4.0 1997 and on: 3.0 Belgium: 1991-1994: 10.0 1995 to 1997: 4.0 Sweden: 1995-1998: 3.0 1999 and on: 2.5 Finland: 4.0 Spain: 3.0 Switzerland: 3.0 Italy: 4.0 | Netherlands: 4 years Belgium: 4-7 years Sweden: 2 years Finland: 4 years Spain: 4 years Switzerland: 4 years Italy: 4 years | Netherlands: From 1991 to 1997, PSA combined PSA with DRE and TRUS Belgium: From 1991 to 1997, PSA combined with DRE and TRUS. Finland: PSA of 3.0 to 3.9 prompted DRE, and after 1999, calculation of free PSA: total PSA ratio led to biopsy, if either was positive Italy: PSA of 2.5 to 3.9 prompted DRE and TRUS | Mixed (some sites population, some volunteer) | 83% (percent of men in screening arm who were screened at least once) | No report on contamination overall.^84^ Site-specific estimates for Spain, Finland, and Netherlands given below. PSA use in prior year among control arms subjects in Italy: 28.9% (1997), 36.6% (2001) | 13.0 years (median)
| Sweden (Göteborg) N=20,000 Age (median): 56.0 years | 1995-1998: 3.0 1999 and on: 2.5 | 2 years | None | Population | NR | NR | 18.0 years
| Spain Men identified from population registry lists (N=4,276) Age (range): 45 to 70 years | 3.0 | 4 years | None | Volunteer | NR | Ever use of PSA in control arm: 6.7% | 15.2 years (median)
| Netherlands (Rotterdam) Men selected from a population-based registry (N=42,376) Age (range): 54 to 74 years | 1993-1997: 4.0 1997 and on: 3.0 | 4 years | PSA of 3.0-3.9 prompted DRE; after 1999, calculation of free PSA: total PSA ratio led to biopsy, if either was positive | Volunteer | 94.5% at first screening; 85%-88% at repeat screenings | Use of screening PSA during screening phase of trial: 19.4%^82^ | 12.8 years (median)
| Finland Men identified from the Finnish Population Registry (N=80,144) Age (median): 58.7 years | 4.0 | 4 years | 1996-1999: PSA of 3.0-3.9 received DRE | Population | 74.6% | Baseline contamination among screening arms subjects (range): 6.7% (1996) to 13.8% (1999)^84^ Contamination in control arm at 12.0 years of followup: 62.7%^86^ | 12.0 years (median)

* Main ERPSC trial includes most patients that are included in site-specific ERSPC reports

† Core age group only; excluded France due to incomplete followup

‡ Population sample sizes in the PLCO differ between the 13-year followup publication (Andriole, 2012; n=76,685) and the 11.5-year and 14.8-year followup (Andriole, 2009 and Pinsky, 2016; n=76,683)

§ Population sample sizes in the ERSPC differ between the 9-year followup publication (Schroder, 2009; n=162,387) and the 11-year and 13-year followup (Schroder, 2012 and Schroder, 2014; n=162,388)

Abbreviations: DRE=digital rectal exam; ERSPC=European Randomized Study of Screening for Prostate Cancer; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; TRUS=transrectal ultrasound

Table 5 The Effect of PSA-Based Screening on Prostate Cancer Incidence

Study Reference Quality Rating | Location | N | Followup | Prostate Cancer Incidence | Stage or Risk Distribution at Diagnosis
PLCO Andriole, 2012^80^ Fair | United States | 76,683^‡^ | 13.0 years (median) | IG: 11.1% (4250/38,340 men) 108.4 per 10,000 PY CG: 9.9% (3815/38,345 men) 97.1 per 10,000 PY RR=1.12 (95% CI, 1.07 to 1.17) | Stage 1: IG: 0.5% (19/4250 men) CG: 0.5% (17/3815 men) Stage 2: IG: 95.4% (4056/4250 men) CG: 94.0% (3584/3815 men) Stage 3: IG: 1.4% (58/4250 men) CG: 1.7% (65/3815 men) Stage 4: IG: 2.3% (96/4250 men) CG: 2.9% (111/3815 men)
ERSPC^*^ Schroder, 2014^96^ Buzzoni, 2015^83^ Fair [underlined: ERSPC Site-Specific Reports] Sweden (Göteborg): Arnsrud Godtman, 2015^81^ Spain: Lujan, 2014^89^ Netherlands (Rotterdam): Roobol, 2013^92^ Finland: Kilpelainen, 2013^87^ | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, and France)^†^ | 162,388 (core age group)^§^ | 13.0 years (median) | IG: 10.2% (7408/72,891 men) 95.5 per 10,000 PY CG: 6.8% (6107/89,352 men) 62.3 per 10,000 PY RR=1.57 (95% CI, 1.51 to 1.62) | Low Risk: IG: 60% (4442/7408 men) CG: 42% (2543/6107 men) RR=2.14 (95% CI, 2.03 to 2.25) Intermediate Risk: IG: 22% (1625/7408 men) CG: 28% (1711/6107 men) RR=1.24 (95% CI, 1.16 to 1.34) High Risk: IG: 7% (519/7408 men) CG: 11% (667/6107 men) RR=1.00 (95% CI, 0.89 to 1.13) Metastatic: IG: 3% (252/7408 men) CG: 10% (586/6107 men) RR=0.60 (95% CI, 0.52 to 0.70)
| Sweden (Göteborg) | 20,000 | 18.0 years | IG: 14.0% (1396/10,000 men) CG: 9.6% (962/10,000 men) | Low Risk: IG: 50.0% (697/1396) CG: 26.3% (253/962) Intermediate Risk: IG: 33.6% (469/1396) CG: 37.4% (360/962) High Risk: IG: 9.7% (136/1396) CG: 17.6% (169/962) Advanced: IG: 2.7% (67/1396) CG: 12.2% (117/962)
| Spain | 4,276 | 15.2 years (median) | IG: 6.7% (161/2415 men) 47.8 per 10,000 PY CG: 4.3% (80/1861 men) 30.5 per 10,000 PY RR=1.57 (95% CI, 1.20 to 2.05) | NR
| Netherlands (Rotterdam) | 42,376 | 12.8 years (median) | IG: 12.7% (2674/20,985 men) CG: 6.8% (1430/20,917 men) | Low Risk: IG: 68.3% (1444/2113 men) CG: 42.3% (605/1430 men) Intermediate Risk: IG: 25.1% (531/2113 men) CG: 27.9% (399/1430 men) High Risk: IG: 5.5% (116/2113 men) CG: 13.0% (183/1430 men) Metastatic: IG: 0.8% (16/2113 men) CG: 12.8% (183/1430 men)
| Finland | 80,144 | 12.0 years (median) | IG: 9.0% (2883/31,866 men) 88.0 per 10,000 PY CG: 6.9% (3337/48,278 men) 66.0 per 10,000 PY HR= 1.34 (95% CI 1.27 to 1.40; p<0.001) | Low risk: IG: 61.5% (1774/2883 men) CG: 46.9% (1565/3337 men) HR=1.75 (95% CI 1.64 to 1.87; p<0.001) Moderate risk: IG: 25.0% (719/2883 men) CG: 32.2% (1076/3337 men) HR=1.03 (95% CI 0.94 to 1.14; p=0.48) High risk: IG: 13.2% (380/2883 men) CG: 20.5% (684/3337 men) HR=0.86 (95% CI 0.76 to 0.97; p=0.02) Advanced: HR=0.73 (95% CI, 0.64 to 0.82; p<0.001)

* Main ERPSC trial includes most patients that are included in site-specific ERSPC reports

† Results for core age group only; excluded France due to incomplete followup

‡ Population sample sizes in the PLCO differ between the 13-year followup publication (Andriole, 2012; n=76,685) and the 11.5-year and 14.8-year followup (Andriole, 2009 and Pinsky, 2016; n=76,683)

§ Population sample sizes in the ERSPC differ between the 9-year followup publication (Schroder, 2009; n=162,387) and the 11-year and 13-year followup (Schroder, 2012 and Schroder, 2014; n=162,388)

Abbreviations: CI=confidence interval; CG=control group; ERSPC=European Randomized Study of Screening for Prostate Cancer; HR=hazard ratio; IG=intervention group assigned to screening; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; RR=relative risk

Table 6 The Effect of PSA-Based Screening on Prostate Cancer-Specific and All-Cause Mortality

Study Reference Quality Rating | Location | N | Followup | Prostate-Cancer Specific Mortality | All-Cause Mortality^‡^
PLCO Pinsky, 2016^106^ Fair | United States | 76,683 | 14.8 years (median) | IG: 0.67% (255/38,340 men) 4.8 per 10,000 PY CG: 0.64% (244/38,345 men) 4.6 per 10,000 PY RR=1.04 (95% CI, 0.87 to 1.24; p=0.67) HR=1.03 (95% CI, 0.87 to 1.23; p=0.72) | IG: 24.0% (9212/38,340 men) 172.8 per 10,000 PY CG: 24.5% (9375/38,345 men) 176.9 per 10,000 PY RR=0.98 (95% CI, 0.95 to 1.00; p=0.11) HR=0.97 (95% CI, 0.95 to 1.00; p=0.06)
ERSPC^*^ Schroder, 2014^96^ Fair [underlined: ERSPC Site-Specific Reports] Sweden (Göteborg): Arnsrud Godtman, 2015^81^ Hugosson, 2010^85^ Spain: Lujan, 2014^89^ Netherlands (Rotterdam): Roobol, 2013^92^ Finland: Kilpelainen, 2013^87^ | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, and France)^†^ | 162,388 (core age group) | 13.0 years (median) | IG: 0.5% (355/72,891 men) 4.3 per 10,000 PY CG: 0.6% (545/89,353 men) 5.4 per 10,000 PY RR=0.79 (95% CI, 0.69 to 0.91; p=0.001) | IG: 21.1% (15,369/72,891 men) 186.0 per 10,000 PY CG: 21.4% (19,108/89,353 men) 189.0 per 10,000 PY RR=1.00 (95% CI, 0.98 to 1.02; p=0.82)
| Sweden (Göteborg) | 20,000 | 18.0 years (median) | IG: 0.79% (79/10,000 men) CG: 1.22% (122/10,000 men) RR=0.58 (95% CI, 0.46 to 0.72) Absolute risk reduction=0.72% (95% CI, 0.50 to 0.94) | [underlined: 14-year followup] IG: 19.8% (1,981/10,000) CG: 19.8% (1,982/10,000)
| Spain | 4,276 | 15.2 years (median) | IG: 0.21% (5/2415 men) 1.4 per 10,000 PY CG: 0.27% (5/1861 men) 1.9 per 10,000 PY RR=0.76 (95% CI, 0.22 to 2.62) | IG: 12.5% (303/2415 men) 86.0 per 10,000 PY CG: 13.5% (251/1861 men) 93.8 per 10,000 PY RR=0.92 (95% CI, 0.78 to 1.08)
| Netherlands (Rotterdam) | 42,376 | 12.8 years (median) | IG: 0.43% (91/20,985 men) CG: 0.90% (188/20,917 men) RR=0.80 (95% CI, 0.65 to 0.99; p=0.042) | IG: 2.8% (578/20,985 men) CG: 2.3% (483/20,917 men)
| Finland | 80,144 | 12.0 years (median) | IG: 0.5% (149/31,866 men) CG: 0.6% (266/48,278 men) HR=0.85 (95% CI, 0.69 to 1.04; p=0.10) | IG: 20.8% (6618/31,866 men) CG: 20.9% (10,079/48,278 men) HR=0.99 (95% CI, 0.96 to 1.02; p=0.69)

* Main ERPSC trial includes most patients that are included in site-specific ERSPC reports

† Results for core age group only; excluded France due to incomplete followup

‡ The PLCO trial excluded lung and colorectal cancers from their analysis of all-cause mortality

Abbreviations: ARR=absolute risk reduction; CI=confidence interval; CG=control group; ERSPC=European Randomized Study of Screening for Prostate Cancer; HR=hazard ratio; IG=intervention group assigned to screening; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; RR=relative risk

Table 7 The Effect of PSA-Based Screening on Prostate Cancer-Specific Mortality, by Subgroup and Risk Factor

Study Reference Quality Rating | Location | Age | Gleason Score | Family History | Comorbid Conditions
PLCO Andriole, 2012^80^ Liss, 2015^88^ Fair | United States | [underlined: 13.0-years followup] 55 to 64 years: IG: 2.35 per 10,000 PY CG: 1.97 per 10,000 PY RR=1.19 (95% CI, 0.83 to 1.72) 65 to 74 years: IG: 6.17 per 10,00 PY CG: 6.02 per 10,000 PY RR=1.02 (95% CI, 0.77 to 1.37) p (interaction)=0.81 | NR | [underlined: 11.6-years followup] Among men with positive FH: IG: 0.36% (18/2,350) CG: 0.77% (9/2,483) HR=0.49 (95% CI, 0.22 to 1.00; p=0.08) Negative FH: 0.37% (216/58,767) Positive FH: 0.56% (27/4,833) HR=1.47 (95% CI, 0.98 to 2.21; p=0.06) | [underlined: 13.0-years followup] No comorbidity IG: 3.47 per 10,000 PY CG: 3.48 per 10,000 PY RR=1.00 (95% CI, 0.76 to 1.31) At least one comorbidity (CCI≥1) IG: 3.78 per 10,000 PY CG:3.41 per 10,000 PY RR=1.11 (95% CI, 0.72 to 1.71) p (interaction)=0.68
Schroder, 2014^96^ ERSPC^*^ [underlined: ERSPC site-specific reports] Netherlands (Rotterdam): Roobol, 2013^92^ | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, and France)^†^ | [underlined: 13.0-years followup] ≤54 years IG: 0.9 per 10,000 PY CG: 1.1 per 10,000 PY RR=0.84 (95% CI, 0.28 to 2.49; p=0.75) 55-59 years: IG: 2.8 per 10,000 PY CG: 3.3 per 10,000 PY RR=0.81 (95% CI, 0.93 to 1.03; p=0.09) 60-64 years: IG: 5.0 per 10,000 PY) CG: 5.7 per 10,000 PY RR=0.90 (95% CI, 0.71 to 1.15; p=0.41) 65-69 years: IG: 7.0 per 10,000 PY CG: 10.3 per 10,000 PY RR=0.69 (95% CI, 0.55 to 0.87; p=0.002) 70+ years: IG: 14.4 per 10,000 PY) CG: 12.4 per 10,000 PY RR=1.17 (95% CI, 0.82 to 1.66; p=0.40) | NR | NR | NR
Schroder, 2014^96^ ERSPC^*^ [underlined: ERSPC site-specific reports] Netherlands (Rotterdam): Roobol, 2013^92^ | Sweden (Göteborg) | NR | NR | NR | NR
Schroder, 2014^96^ ERSPC^*^ [underlined: ERSPC site-specific reports] Netherlands (Rotterdam): Roobol, 2013^92^ | Spain | NR | NR | NR | NR
Schroder, 2014^96^ ERSPC^*^ [underlined: ERSPC site-specific reports] Netherlands (Rotterdam): Roobol, 2013^92^ | Netherlands (Rotterdam) | [underlined: 12.8-years followup] 55-69 years: RR=0.68 (95% CI, 0.53 to 0.89; p=0.004) 70-74 years: RR=1.14 (95% CI, 0.0.78 to 1.68; p=0.50) | NR | NR | NR
Schroder, 2014^96^ ERSPC^*^ [underlined: ERSPC site-specific reports] Netherlands (Rotterdam): Roobol, 2013^92^ | Finland | NR | NR | NR | NR

* Main ERPSC trial includes most patients that are included in site-specific ERSPC reports

† Results for core age group only; excluded France due to incomplete followup

Abbreviations: CCI=Charlson Comorbidity Index; CI=confidence interval; CG=control group; ERSPC=European Randomized Study of Screening for Prostate Cancer; FH=family history; HR=hazard ratio; IG=intervention group assigned to screening; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; RR=relative risk

Table 8 False-Positives, Complications, and Biopsy-Related Mortality Associated With PSA-Based Screening

Study Reference Quality Rating | Location Study Design | False Positives | Screening and Biopsy-Related Complications | Biopsy-Related Mortality
PLCO Andriole, 2009^53^ Pinsky, 2014^103^ Croswell, 2009^107^ Fair | United States RCT | [underlined: Any FP^*^ with PSA after 36.0-months followup] 10.4% (3388/32,576) Cumulative risk of receiving ≥1 FP result, by number of screening tests: 1 test: 5.4% (95% CI, 5.2-5.7) 2 tests: 7.9% (95% CI, 7.5-8.3) 3 tests: 10.4% (95% CI, 9.8-11.0) 4 tests: 12.9% (95% CI, 12.1-3.8) [underlined: Moderately invasive procedure as a result of a FP:] 4.6% (1491/32413) Cumulative risk of receiving at least 1 biopsy as a result of a FP, by number of screening tests: 1 test: 1.7% (95% CI, 1.5 to 1.8) 2 tests: 3.0% (95% CI, 2.5 to 3.4) 3 tests: 4.2% (95% CI, 3.5 to 4.9) 4 tests: 5.5% (95% CI, 4.6 to 6.5) | [underlined: Screening & biopsy-related complications:] All complications: 26.2 per 10,000 screenings (primarily dizziness, bruising, and hematoma) Medical complications: 68 per 10,000 diagnostic evaluations (primarily infection, bleeding, clot formation, urinary difficulties) [underlined: Biopsy-related complications] All complications: 20.2 per 1000 biopsies Infectious complications: 7.8 per 1000 biopsies Non-infectious complications: 13.0 per 1000 biopsies Age <70 years vs. ≥70 years All complications: OR=1.4 (95% CI, 0.9 to 2.4; p=0.06) Infectious complications: OR=1.8 (95% CI, 0.8 to 4.0; p=0.09) Non-infectious complications: OR=1.3 (95% CI, 0.7 to 2.4; p=0.23) Non-black race vs. black race All complications: OR=2.6 (95% CI, 1.2 to 5.9; p=0.05) Infectious complications: OR=7.1 (95% CI, 2.7 to 18.0; p<0.001) Non-infectious complications: OR=0.5 (95% CI, 0.1 to 3.6; p=0.53) No comorbidity vs. one or more comorbidities All complications: OR=1.4 (95% CI, 0.9 to 2.3; p=0.08) Infectious complications: OR=0.9 (95% CI, 0.4 to 2.1; p=0.82) Non-infectious complications: OR=1.7 (95% CI, 0.9 to 3.0; p=0.06) | [underlined: 4.0-months followup] IG: 6/6295 (0.95 per 1,000 biopsies) CG: 255/139931 negative screens (1.8 per 1,000 negative screens) RR=0.49 (95% CI, 0.2 to 1.1) [underlined: 6.0-months followup] IG: 14/6295 (2.2 per 1000 biopsies) CG: 411/139931 negative screens (4.9 per 1000 negative screens) RR=0.70 (95% CI, 0.4 to 1.2)
ERSPC Carlsson, 2011^104^ Kilpelainen, 2011^101^ Raaijmakers, 2002^108^ Fair | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, and France)^†^ RCT | Any FP: 17.8% (10972/61604) 1 FP: 74.7% (7752/10972) 2 FPs: 20.1% (2089/10972) 3 FPs: 5.2% (538/10972) | [underlined: Minor complications of biopsy] Hematuria >3 days: 22.6% (1280/5676) Hematospermia: 50.4% (2858/5676) Rectal bleeding: 1.3% (75/5676) Voiding problems: 0.8% (48/5676) [underlined: Major complications of biopsy] Pain after biopsy: 7.5% (286/5676) Fever: 3.5% (200/5676) Hospitalization: 0.5% (27/5676) Urinary retention: 0.4% (20/5676) Nausea/sickness: 0.3% (17/5676) | [underlined: Mortality at 12.0-month followup Screen-negative] 0.89% (330/37235) Screen-positive, biopsied: 0.62% (72/11721) RR=0.54 vs. screen-negative men (95% CI, 0.42 to 0.70; p<0.001)
ProBE cohort Rosario, 2012^102^ Good | United Kingdom Cohort | NR | [underlined: Self-reported symptoms rated as moderate or severe within 7-days of biopsy] Pain: 5.7% (95% CI, 4.4 to 7.3%) Fever: 4.0% (95% CI, 3.0 to 5.4%) Shivers: 3.2% (95% CI, 2.3 to 4.5) Hematuria: 4.8 (95% CI, 3.6 to 6.3) Hematochezia: 1.7% (95% CI, 1.0 to 2.7%) Hematoejaculate: 20.0% (95% CI, 17.2 to 23.1%) [underlined: Self-reported symptoms rated as moderate or severe within 35-days of biopsy] Pain: 7.3% (95% CI, 5.7 to 9.1%) Fever: 5.5% (95% CI, 4.2 to 7.1) Shivers: 5.0% (95% CI, 3.7 to 6.6) Hematuria: 6.2% (95% CI, 4.7 to 7.9) Hematochezia: 2.5% (95% CI, 1.6 to 3.7) Hematoejaculate: 26.6% (95% CI, 23.3 to 30.2) Hospitalization within 35 days: 1.3% (15/1147; 95% CI, 0.8% to 2.1%), including 0.6% (7/1147) admitted for sepsis within 3 days of biopsy Outpatient healthcare contact due to biopsy symptoms: 10.4% (95% CI, 8.7% to 12.3%) | [underlined: 35-days followup] 0% (0/1147; 95% CI, 0.0 to 0.4%)
Walter, 2013^33^ Fair | United States Cohort | NR | Biopsy-related 7-day complications: 5.6% (468/8313) of men who underwent biopsy Biopsy-related 7-day hospitalizations: 1.6% (131/8313) of men who underwent biopsy | [underlined: 7-days followup] 0.12% (9/8313) of men who underwent biopsy

* Authors define false positives as any PSA test score >4 ng/mL without a resulting cancer after three years of followup

* Main ERPSC trial includes most patients that are included in site-specific ERSPC reports

† Results for core age group only; excluded France due to incomplete followup

‡ Denominator includes biopsy procedures confirmed by completion of survey

‡ Excludes 339 men who reported no sexual activity at either the 7-day or 35-day assessment

Abbreviations: CG=control group; ERSPC=European Randomized Study of Screening for Prostate Cancer; FP=false positive; IG=intervention group assigned to screening; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; OR=odds ratio; RR=relative risk

### Summary

Fair-quality evidence on the impact of PSA screening on prostate cancer mortality and morbidity derives from two randomized trials of screening: the PLCO and the ERSPC trials.^96,106^ The PLCO has been characterized as a trial comparing the effectiveness of organized versus opportunistic screening, whereas the ERSPC trial assessed the impact of PSA screening chiefly among men who have not previously been screened.^182^ The PLCO was limited mainly by the high rate of PSA use among control subjects during the screening and post-screening phases of the trial, which would be expected to bias study outcomes toward the null.^106^ The ERSPC trial was limited by unexplained post-randomization differences in prostate cancer treatments in the two study arms; a greater percentage of screening arm subjects with higher-risk cancers underwent radical prostatectomy than control subjects with similar cancers, which may have biased study results in favor of screening.^97^ Randomization to PSA screening in both trials was associated with an appreciable increase in the incidence of prostate cancer. In the ERSPC trial, 28.7 men aged 55 to 69 years needed to be invited to multiple rounds of screening over a 13-year period for one additional man to be diagnosed with prostate cancer.^96^ Within four sites of ERSPC, randomization to screening was associated with reduced incidence of metastatic prostate cancer during a median followup of 12 years (relative risk [RR], 0.70 [95% CI, 0.60 to 0.82]).^94^ After accounting for the 56 percent relative increase in overall incidence of prostate cancer in the screening versus the control arms at these four ERSPC sites, an estimated 12 men would need to be diagnosed with prostate cancer through screening to avert one case of metastatic cancer.

After a median followup of 14.8 years in the PLCO, there was no difference in the risk of prostate cancer mortality in the screening versus control arms (RR, 1.04 [95% CI, 0.87 to 1.24]). After 13.0 years of median followup in the ERSPC trial, randomization to screening versus control was associated with a 21 percent reduction in prostate cancer mortality (RR, 0.79 [95% CI, 0.69 to 0.91]). Based on ERSPC incidence and mortality data, an estimated 27 men need to be diagnosed with prostate cancer to avert one prostate cancer death (95% CI, 17 to 66). In neither trial was screening associated with significantly reduced all-cause mortality. Trial evidence regarding the differential impact of screening on morbidity and mortality within patient subgroups (age, race/ethnicity, comorbidity, prostate cancer risk) was limited or absent. In the PLCO, sample sizes of African-American men (n=3,370) and men with a family history of prostate cancer (n=5,326) were small, limiting power for relevant subgroup analyses.

### Study Characteristics

The ERSPC trial was conducted in asymptomatic men identified by population-based registries in Europe,^96^ while the PLCO enrolled men at participating screening centers in the U.S.^106^ Both trials randomized participants to either receive PSA-based screening (with or without digital rectal examination [DRE]) or no screening. During the screening phases of the trials, 83 percent of men randomized to screening in the ERSPC trial had at least one PSA tests,^96^ while average annual adherence to PSA screening in the intervention arm of the PLCO was 85 percent.^99^ Characteristics of both trials are presented in Table 3.

#### PLCO Trial

In the prostate component of the PLCO trial, 76,683 U.S. men aged 55 to 74 years were recruited from 1993 to 2001 and randomized to either annual PSA screening for six years (with DRE for the first four screening rounds) or usual care. Abnormal screening results (either a PSA level ≥4.0 ng/mL or an abnormal DRE) were forwarded to primary care physicians, who coordinated further diagnostic evaluation. Incident cancers and deaths were ascertained by annual participant questionnaires, supplemented with medical records review, and linkage with the National Death Index.^91^ A 2012 report from the PLCO provides results after a median followup of 13 years,^80^ while a recent publication provides mortality results at a median followup of 14.8 years.^106^

The ages of men in the PLCO screening and control arms were well-matched; 32.3 percent of men were aged 55 to 59 years, 31.3 percent were aged 60 to 64 years, 23.2 percent were aged 65 to 69 years, and 13.2 percent were aged 70 to 74 years.^53^ The majority of men were non-Hispanic white (86.2% of the screening arm and 83.8% of the control arm); only 4.4 percent of the PLCO population was non-Hispanic black. About one in five men enrolled in the study had an enlarged prostate or benign prostatic hyperplasia and approximately 7 percent had a family history of prostate cancer. Approximately one-third of men in both arms received either a PSA test or DRE within the past three years, and 4.3 percent of men had previously received a prostate biopsy.^53^

The PLCO has been characterized as a trial comparing the effectiveness of organized versus opportunistic screening,^182^ because an estimated 46 percent of control participants received routine screening PSA from community physicians in the prior year during the screening phase of the trial, and 78 percent of control subjects received PSA testing for some purpose during the screening phase of the trial (Appendix E Table 1). Nevertheless, during the six-year screening phase of the trial, the extent of PSA testing exposure was greater in the screening than the control arm (mean of 5.3 vs. 3.1 tests, respectively).^99^ During the seven years following the screening phase of the trial, between one-half and two-thirds of men in both trial arms reported PSA testing within the prior year in annual surveys of random samples of PLCO participants. Twelve years after randomization, 91 of 100 of surveyed control arm subjects (95% CI, 83.6% to 95.8%) reported having at least one out-of-trial PSA test.^183^ Because of the extent of PSA use in the PLCO control arm, we rated the overall quality of the trial as fair.

#### ERSPC Trial

The ERSPC trial was initiated in 1993 in the Netherlands and Belgium. Five additional centers joined the study between 1994 and 1998 (Sweden, Finland, Italy, Spain, and Switzerland), and two French centers began in 2000 and 2003. Eligible men were aged 50 to 74 years and were recruited through 2003 (2005 in France). However, most ERSPC reports, including the most recent update,^96^ emphasize outcomes among the 162,388 randomized men in the “core” age group of 55 to 69 years, which was pre-specified based on consideration of rising prostate cancer incidence in the mid-fifties and lower likelihood of definitive treatment in men over age 70 years.^98^ In the core age group, the median age at randomization among men across all sites (excluding France) was 60.2 years.^96^

Recruitment methods differed across sites; four sites obtained informed consent from all men prior to randomization (Belgium, Netherlands, Spain, and Switzerland), while all other sites randomized men from population rolls and only contacted men randomized to screening. Screening PSA protocols varied across ERPSC sites. Most screening intervals were four years, with the exception of Sweden, which used a two-year interval. PSA thresholds prompting biopsy recommendation ranged from 2.5 ng/mL (in later Swedish screening rounds) to 10.0 ng/mL (in the early screening rounds in Belgium); by the end of trial, most sites had adopted a threshold of 3.0 ng/mL. Notably, the Swedish site combined the most intensive screening schedule (biennial) with the lowest positive PSA threshold (2.5 ng/mL). Recently reported mortality results also exclude men from France due to incomplete mortality data from this site. Details of screening protocols by ERSPC sites are provided in Table 3.

ERSPC has been characterized as a trial of PSA screening chiefly among men who have not previously been screened^182^ because PSA screening was uncommon in community practice when the trial was initiated. However, the extent of contamination in the control arm was not assessed at all sites; it was estimated to be approximately 20 percent in Netherlands control arm.^82^ In Finland, baseline contamination among screening subjects was 13.8 percent in 1999. Among control arms subjects in Italy in 1999, 36.6 percent of control arms subjects reported PSA in the prior year.^84^ Due to the rising prevalence of PSA-detected cancers (i.e., stage T1c), recent ERSPC reports suggest substantial opportunistic screening has occurred at some sites during later followup years, although direct measures of out-of-trial screening are lacking.^81,84,96,184^

Since the 2012 USPSTF recommendation, ERSPC centers in Sweden (n=19,899),^81^ Finland (n=80,144),^87^ the Netherlands (n=42,376)^92^ and Spain (n=4,276)^89^ have reported results of extended followup of their individual study populations (Table 3). In brief, the Swedish (Goteborg) trial was initiated in 1995 as a stand-alone, population-based screening trial but joined the Swedish arm of ERSPC soon after in 1996. Of the 19,899 men aged 50 to 70 years in the Goteborg trial, 11,852 (59.5%) were included in analyses of the overall ERSPC core-age group (ages 55 to 69 years). Screening continued through 2008 for up to eight rounds of biennial screening or until men were over age 69 years. Incident cancers and prostate cancer deaths were ascertained by linkage with national cancer and death registries with cause of death adjudicated by causes of death committees blinded to group assignment. In the most recent report from the trial, followup for mortality outcomes was up to 18.0 years. The Finnish, Netherlands, and Spain ERSPC sites have reported followup at medians of 12.0, 12.8, and 15.2 years, respectively.

We rated the ERSPC trial as fair quality on the basis of several considerations. First, recruitment strategies and inclusion criteria differed across sites, yielding potentially heterogeneous study populations. Second, screening and diagnostic protocols differed across sites and over time. Overall, men in the intervention group were screened a mean of 2.3 times, ranging from 1.6 times in Belgium to 3.5 in Sweden. Third, contamination rates in the control arm were not systematically assessed at all sites.^96^ Fourth, among men diagnosed with non-metastatic prostate cancer, a greater proportion of men in the screening arm underwent radical prostatectomy (41.3%) than in the control arm (32.8%), while the opposite was the case for androgen deprivation therapy.^97^ While treatment differences by screening arm would arise if screening produces a shift toward more localized stages, treatment differences across ERSPC study arms persisted even with stratification by clinical stage and tumor grade (Appendix E Table 2). Screening may also induce favorable shifts in tumor characteristics within-stage, and analyses of ERSPC data show that patient and tumor characteristics (age, PSA, tumor size, nodal status, and grade) were much stronger predictors of treatment approach than study arm.^185^ Nevertheless, even after adjusting for these factors, patients randomized to screening were significantly more likely to be treated with prostatectomy as compared to radiotherapy or hormonal therapy.^97^ It remains unclear why risk-adjusted treatment differences emerged in the ERSPC study arms, but the location of screening centers within academic rather than community institutions may have played a role. It is conceivable that treatment differences could have influenced long-term study outcomes independent of screening in the ERSPC trial.

### Findings

#### Prostate Cancer Incidence

After up to 13.0 years of followup, incidence rates of prostate cancer in the screening and control arms of the PLCO trial were 108.4 and 97.1 cases per 10,000 person-years, respectively (RR, 1.12 [95% CI, 1.07 to 1.17]) (Table 5). After a median followup of 13.0 years, incidence rates of prostate cancer in the screening and controls arms of the ERSPC trial were 95.5 and 62.3 cases per 10,000 person-years, respectively (RR, 1.57 [95% CI, 1.51 to 1.62]), or an absolute rate difference of 34.8 cancers per 1000 men (Table 5). The observed risk differences in prostate cancer incidence per 1,000 men imply a number needed to invite (NNI) of 88.0 men in the PLCO trial and 28.7 men in the ERSPC trial for one additional man to be diagnosed with prostate cancer.^80,96^

At all ERSPC sites with separate reports (Sweden, Netherlands, Finland, and Spain), prostate cancer incidence was statistically significantly greater in the screening versus control arms (Table 5).^81,87,89,92^ In the Swedish (Goteborg) trial, observed cumulative incidences of prostate cancer over 18.0 years of followup in the screening and control arms were 16 percent and 11 percent, respectively, compared to expected incidences of approximately 7 percent in the absence of organized (in the screening arm) and opportunistic (in the control arm) screening.^81^ Absolute differences in the percentage of men diagnosed with prostate cancer in the screening and controls arms at three other ERSPC sites with separate reports ranged from 2.1 percent in Finland^87^, 2.4 percent in Spain,^89^ and 6.1 percent in the Netherlands.^92^

#### Cumulative Incidence of Metastatic Cancer

While the PLCO has not reported on cumulative incidence of prostate cancer metastases, the cumulative incidence of metastatic cancer was assessed within four ERSPC sites (Sweden, Netherlands, Finland, and Switzerland).^94^ Among randomized men at these sites, the risk of developing metastatic prostate cancer was 30 percent lower among men randomized to screening as compared to control at a median followup of 12.0 years (RR, 0.70 [95% CI, 0.60 to 0.82]; p=0.001). The absolute reduction in long-term risk of metastatic prostate cancer associated with screening was 3.1 cases per 1,000 men randomized. This absolute reduction in cumulative metastatic disease incidence is less than 10 percent as large in magnitude as the absolute increase in total prostate cancer incidence in the overall ERSPC trial (3.1 fewer metastatic cases vs. 34.8 additional prostate cancers diagnosed per 1,000 men). After accounting for the 55.6 percent relative increase in overall incidence of prostate cancer in the screening versus the control arms at these four ERSPC sites, the number needed to invite to screening (NNI) to avoid one case of metastatic cancer was 328, and the number needed to diagnose with prostate cancer through screening (NND) to avert one case of metastatic cancer was 12.^94^

#### Prostate Cancer-Specific Mortality

At a median followup of 14.8 years in the PLCO trial, the prostate cancer-specific mortality rate was 4.8 per 10,000 person-years among men in the intervention group and 4.6 per 10,000 person-years among men in the control group (RR, 1.04 [95% CI, 0.87 to 1.24]) (Table 6).^106^

Among men in the core age group (ages 55 to 69 years at enrollment) in the ERSPC trial after a median of 13.0 years of followup, the prostate cancer-specific mortality rate was 4.3 per 10,000 person-years in the intervention group and 5.4 per 10,000 person-years in control group (RR, 0.79 [95% CI, 0.69 to 0.91]; p=0.001) (Table 6).^96^ The absolute risk reduction in prostate cancer mortality associated with screening was −0.11 deaths per 1,000 person-years (95% CI: −0.18 to −0.05), or 1.28 fewer prostate cancer deaths per 1,000 men. The relative risk of prostate cancer-specific mortality in the intervention arm as compared to the control arm did not diverge from 11 to 13 years of median followup (RR at 11 years, 0.78 [95% CI, 0.66 to 0.91]; p=0.002).^95^ With followup truncated at 13.0 years, the NNI to prevent one prostate cancer death was 781 (95% CI, 490 to 1929) and the NND was 27 (95% CI, 17 to 66). When men of all ages were included (ages 50 to 74 years at enrollment) in the analyses, randomization to screening was still significantly associated with reduced prostate cancer mortality (RR, 0.83 [95% CI, 0.73 to 0.94]; p=0.004).

The screening-associated impact on prostate cancer-specific mortality differed across ERSPC sites with separate updated reports (Table 6). Within the Netherlands site after a median followup of 12.8 years, men randomized to screening had 20 percent reduced risk of prostate cancer mortality (RR, 0.80 [95% CI, 0.65 to 0.99]; p=0.04).^92^ In the Swedish (Goteborg) trial after up to 18.0 years followup, men randomized to screening had 42 percent reduced risk of prostate cancer mortality compared to men randomized to control (RR, 0.58 [95% CI, 0.46 to 0.72]).^81^ However, at both sites, the absolute risk reduction in prostate cancer mortality was much lower than the excess incidence of prostate cancer associated with screening; the NNI and NND to prevent one death from prostate cancer were 392 and 24 for men in the Netherlands core age group and 139 and 13 for all men in the Swedish (Goteborg) trial, respectively.

Prostate cancer specific mortality was not statistically significantly different in the screening and control groups in the Finnish and Spanish ERSPC sites. After 12.0 years of median followup in the Finnish site, the hazard ratio of prostate cancer death in the screening versus control arms was 0.85 (95% CI, 0.69 to 1.04; p=0.10).^87^ After a median 15.2 years of followup in the Spanish ERSPC site, the prostate cancer mortality rate was 1.4 and 1.9 per 10,000 person-years in the screening and control arms, respectively (p=0.67).^89^

At 13.0 years of median followup, a test for statistical heterogeneity in prostate cancer mortality results across ERSPC sites was not statistically significant (p=0.43) (Appendix E Table 5). Across all ERSPC sites, prostate cancer mortality was statistically significantly reduced at the Netherlands and Swedish sites, although point estimates were in favor at screening at all sites except Switzerland.

#### All-Cause Mortality

After a median followup of 14.8 years, the all-cause mortality rate in the PLCO trial (excluding deaths due to colorectal and lung cancers) was 172.8 per 10,000 person-years in the intervention group and 176.9 per 10,000 person-years in the control arm (RR, 0.98 [95% CI, 0.95 to 1.00]; p=0.11) (Table 6).^106^ This difference was not statistically significant and was not explained by lower rates of prostate cancer death or by clearly lower death rates within any other diagnostic group.

In the ERSPC trial after a median of 13.0 years of followup, overall mortality was 186.0 and 189.0 death per 10,000 person-years in the screening and control groups respectively (RR, 1.00 [95% CI, 0.98 to 1.02]; p=0.82).^96^ Overall mortality was also similar in screening and control arms in the Netherlands, Swedish, Finnish, and Spanish ERSPC sites (Table 6).

## KQ1a Does the Effect of PSA Screening Vary Between a Priori Subgroups: Age, Race/Ethnicity, Family History, or Clinical Risk?

### Age

Both the PLCO and the ERSPC assessed the differential impact of screening on prostate cancer-specific mortality by age at randomization (Table 7). At a median followup of 13.0 years within the PLCO, prostate cancer mortality rates were 2.35 and 1.97 per 10,000 person-years in intervention and control arms, respectively, among men aged 55 to 64 years at randomization (RR, 1.19 [95% CI, 0.83 to 1.72]); the analogous rates for men aged 65 to 74 years were 6.17 and 6.02 per 10,000 person-years (RR, 1.01 [95% CI, 0.77 to 1.37]). However, a test for interaction between patient age and trial arm with respect to prostate cancer mortality was not statistically significant (p=0.81).^80^

Within the ERSPC, the relative risk of prostate cancer-specific mortality associated with screening compared with no screening stratified by age at randomization was 0.84 among men ages 50 to 54 years (95% CI, 0.28 to 2.49), 0.81 among men ages 55 to 59 years (95% CI, 0.93 to 1.03; p=0.09), 0.90 among men ages 60 to 64 years (95% CI, 0.71 to 1.15; p=0.41), 0.69 among men ages 65 to 69 years (95% CI, 0.55 to 0.87), and 1.17 among men aged 70 years or older (95% CI, 0.82 to 1.66). A formal statistical test for heterogeneity in risk ratios across these age groups was non-significant (p=0.18).^96^

### Race/Ethnicity

Neither the PLCO nor the ERSPC investigators have reported whether screening effects differed by racial/ethnic group. Although potentially greater benefits of screening among African-American men have been postulated,^186^ the sample size of 3,370 non-Hispanic black men who were randomized in the PLCO trial (4.4% of the overall population) was relatively small.

### Family History

In the PLCO trial, Liss et al. (2015) assessed whether PSA screening was associated with reduced prostate cancer mortality among white men who reported a family history of prostate cancer on baseline questionnaires (n=4,833, or 7.4% of the total study population). The analysis excluded non-white men due to concerns about small sample sizes and an absence of prostate cancer deaths among non-Hispanic black men with a family history of prostate cancer. After a median followup of 11.6 years, the multivariate hazard ratio for prostate cancer death among men with a family history of prostate cancer who were randomized to screening was lower relative to control subjects, although not statistically significantly so (HR, 0.49 [95% CI, 0.22 to 1.10]; p=0.08) (Table 7).^88^ However, the analysis lacked a formal test of statistical interaction between randomization to screening versus control and family history.

The impact of family history on screening outcomes has not been reported within the overall ERSPC trial. Within the Finnish site, Saarimaki, et al. reported on incidence rates, PSA test performance, and cancer characteristics among men randomized to screening with and without a first-degree relative with prostate cancer. However, data on family history were lacking for men randomized to the control arm, so the differential impact of screening among men with and without a family history could not be assessed.^93^

### Clinical Risk Assessment

With a median followup of 13 years, PLCO investigators assessed whether comorbidity modified the effect of screening versus control assignment on prostate cancer mortality. Comorbidity was assessed using medical history information from a baseline questionnaire and was classified as 0 versus ≥1 comorbidities using a modification of the Charlson comorbidity index (CCI). Overall, 30 percent of PLCO subjects were classified as having one or more comorbidities. The relative risk of prostate cancer mortality among screening versus control arm subjects was 1.00 (95% CI, 0.76 to 1.31) among men with a CCI score of 0 as compared to 1.11 (95% CI, 0.72 to 1.71) among men with a CCI score ≥1; however this interaction was not statistically significant (p=0.68).^80^

Neither trial reported on the differential effects of screening among men by other clinical risk factors; ethical and practical concerns may preclude pre-planned subgroup analyses by baseline PSA as this would require obtaining and withholding PSA results from the control subjects.^187^

## KQ2 What Are the Harms of PSA-Based Screening for Prostate Cancer and Diagnostic Followup?

We identified two fair-quality RCTs and five cohort studies (two good- and three fair-quality) that examined the harms associated with PSA-based screening and associated diagnostic followup (Tables 3, 4, 8, and 9).^33,53,90,96,101^–^105,109^–^113^ Below we summarize evidence on the potential downstream harms that may be triggered by PSA screening, ranging from short-term consequences, such as false-positive biopsy, to longer-term consequences, such as overdiagnosis. Within each potential adverse consequence, we also summarize evidence on variation in adverse effects by patient subgroup.

Table 4 Study Characteristics of Cohort Studies of Physical or Psychological Harms of Prostate Cancer Screening

Study Reference Quality Rating | Location Study Population | PSA Screening Protocol | | | Diagnostic Procedures | Followup
Study Reference Quality Rating | Location Study Population | PSA Threshold (ng/mL) | Screening Interval | Additional Screening Tests (If Any) | Diagnostic Procedures | Followup
Walter, 2013^33^ Fair | United States VA health care cohort (N=295,645) Age (mean): 73 years | 4.0 | NR | NR | Prostate biopsy | 5 years (planned)
ProBE cohort Rosario, 2012^102^ Good | United Kingdom Men attending PSA screening at 8 medical practices in the UK (N=1,147); cohort was embedded in the ProtecT trial Age (mean): 62.1 years | 3.0 | NR | NR | TRUS-guided biopsy | 35 days (planned)
Fowler, 2006^110^ McNaughton-Collins, 2004^111^ Good | United States Men attending primary care at single academic medical center, including men with recent benign biopsy after abnormal PSA screening (n=163) and men with normal PSA screening (n=237) | 2.5 | NA | NA | Prostate biopsy | 6 weeks, 6 months, 12 months
Katz, 2007^112^ Fair | United States Men receiving care at university-affiliated hospitals or primary care practices who either had an abnormal PSA or DRE result but negative biopsy findings (n=109), or who had a normal PSA result (n-101) | 4.0 | NA | NA | Prostate biopsy | 5 weeks
Brindle, 2006^113^ Fair | United Kingdom Men attending general practice centers who had an abnormal PSA result and received a prostate biopsy (n=569); cohort was identified during case-finding for the ProtecT trial Age (mean): 61.9 years | 3.0 | NR | NR | TRUS-guided biopsy | NR

Abbreviations: ProBE=Prostate Biopsy Effects; ProtecT=Prostate testing for cancer and Treatment; TRUS=transrectal ultrasound

Table 9 Estimates of Overdiagnosis of Prostate Cancer Based on Excess Incidence in the Screening Arms of Randomized, Controlled Trials

Study Reference Quality Rating | Location | Followup (median) Sample Size (n) Randomization Method | Numerator (Excess Cases With Long-Term Followup) | Denominator #1 (Prostate Cancer Diagnosed in Screening Arm During Screening Phase) | Denominator #2 (Screen-Detected Prostate Cancer During Screening Phase) | Overdiagnosis Estimates, Method #1 (%) | Overdiagnosis Estimates, Method #2 (%)
PLCO Andriole, 2012^80^ Fair | United States | 13.0 years N=76,693 1:1 randomization | 425 | 2,577 | 2,049 | 16.4 | 20.7
ERSPC^*^ Schroder, 2014^96^ Fair [underlined: ERSPC site-specific reports] Sweden (Göteborg): Hugosson, 2010^85^ Spain: Lujan, 2014^89^ Netherlands (Rotterdam): Roobol, 2013^92^ Finland: Kilpelainen, 2013^87^ | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, and France)^†^ | 13.0 years N=162,388 1:1.23 randomization | 2,461^‡^ | 7,408 | 4,883 | 33.2 | 50.4
| Sweden (Göteborg) | 14.0 years N=20,000 1:1 randomization | 420 | 896 | NR | 46.8 | NA
| Spain | 15.2 years N=4276, 1:1 randomization (at end, was1.29:1) | 58^‡^ | 161 | NR | 36.0 | NA
| Netherlands (Rotterdam) | 12.8 years N=42,376 1:1 randomization | 1,244 | 2,597 | 2,113 | 47.9 | 58.9
| Finland | 12.0 years N=80,144 1:1.52 randomization | 680^‡^ | 2,883 | 2,661 | 23.6 | 25.6

* Main ERPSC trial includes most patients that are included in site-specific ERSPC reports

† Results for core age group only; excluded France due to incomplete followup

‡ Prostate cancer cases in control arm were weighted according to the randomization ration

§ Overdiagnosis method 1: percentage of all cancer diagnosed during the screening phase that are overdiagnosed

|| Overdiagnosis method 2: percentage of screen-detected cancers that are overdiagnosed

Abbreviations: ERSPC=European Randomized Study of Screening for Prostate Cancer; PLCO=Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial

### Summary

Evidence on the harms of PSA screening and diagnostic followup derives from two fair-quality randomized trials of screening and five cohort studies (two good- and three fair-quality). Among men randomized to screening in the U.S. PLCO trial, 28.2 percent had at least one positive screening during up to six annual screening rounds, and 13.4 percent underwent prostate biopsy, over two-thirds of which (67.7%) were negative for prostate cancer.^103^ Compared to the PLCO, rates of positive screening tests and biopsy in the ERSPC trial were higher (32.3 positive screens and 27.7 biopsies per 100 men randomized to screening), and three-quarters of ERSPC biopsies (75.8%) did not reveal prostate cancer.^101^ Cohort studies suggest that men who receive abnormal PSA screening but normal biopsy results have increased worry about prostate cancer for at least one year after biopsy. Trial and cohort data suggest that 2 to 5 percent of men undergoing biopsy will have infectious or non-infectious complications, requiring hospitalization in 0.5 to 1 percent.^33,102,103^ Subgroup analyses from the ERSPC trial demonstrate that men older than age 70 years are at higher risk of having false-positive PSA screening (20.6%) compared to men younger than age 55 years (3.5%).^101^ In the PLCO and one U.S. cohort study, non-white men were at increased risk of infectious complications after biopsy compared to white men.^33,101^ Based on excess incidence data from the two trials, 20.7 percent and 50.4 percent of cancer detected by PSA screening in the PLCO and ERSPC trials, respectively, were estimated to be overdiagnosed.^53,96^

### Study Characteristics

We included results from the two screening RCTs (PLCO^106^ and ERSPC^96^) as well as five cohort studies^33,102,110^–^113^ that reported on the downstream physical or psychological harms resulting from a positive PSA screening test (Tables 3 and 4).

#### RCTs

##### PLCO Trial

The design of the PLCO trial has been described previously; three publications^53,103,107^ reported harms among men in the screening arm of the trial. In the PLCO, a PSA threshold of 4.0 ng/mL or a positive DRE resulted in notification of patients’ primary care physicians regarding the need for diagnostic followup.^103^ After a median followup of 11.5 years, Andriole et al. (2009) reported immediate harms stemming from the PSA screening procedure itself,^53^ while Pinsky et al (2014) compared the rate of biopsy-related complications and mortality among men randomized to the screening arm who had at least one prostate biopsy compared to men who did not receive a biopsy.^103^ Crosswell et al. (2009) reported on the frequency of false-positive PSA screening during the first four rounds of screening among men randomized to the PLCO screening arm.^107^ Men receiving a positive PSA and biopsy were slightly older (63.7 years versus 62.4 years) and were more likely to have prostatic enlargement (34.0% versus 23.2%) than men with a negative screen and no biopsy, but were less likely to be a current or former smoker and had lower comorbidity rates.^103^ We rated the overall PLCO trial as fair quality, mainly due to contamination in the control arm, although this limitation would not be expected to bias estimates of screening-related harms in the screening arm of the trial.

##### ERSPC Trial

The design of the ERSPC trial has been described previously; four publications^101,104,105,108^ reported harms among cohorts of men randomized to the screening arm of the ERSPC trial. In this trial, diagnostic referral and intervention protocols varied among ERSPC sites. For most ERSPC sites, a PSA threshold of 3.0 ng/mL was used for biopsy indication, although some sites initially used higher thresholds, findings from DRE or transrectal ultrasound (TRUS), or ratio of free to total PSA. After one year of followup, Carlsson et al. (2011)^104^ assessed the rate of excess mortality after prostate biopsies among first-time screen-positive men from three sites (Finland, Sweden and the Netherlands) compared with a cohort of first-time screen-negative men. Kilpelainen et al. (2011)^101^ reported on false-positive screens among men randomized to the screening arm of five sites (Finland, Sweden, the Netherlands, Belgium, and Italy). Raajimakers et al. (2002)^108^ reported on complications of initial prostate biopsies prompted by abnormal PSA screening tests within the Rotterdam site. Vasarainen et al (2013)^105^ reported the effects of PSA screening on health-related quality of life in the Finnish arm of the ERSPC. We rated the overall ERSPC as fair quality, in part due to the variability in screening protocols and thresholds for biopsy referral.

#### Cohort Studies

Embedded within the multicenter Prostate Testing for Cancer and Treatment (ProtecT) trial, the Prostate Biopsy Effect (ProBE) cohort study recruited asymptomatic men referred for biopsy at eight U.K. centers due to elevated PSA screening tests (PSA concentrations 3.0 to 19.9 ng/mL).^102^ All men completed questionnaires regarding symptoms, health status, and healthcare utilization at baseline, immediately after biopsy, and at 7 and 35 days post-biopsy. Men had a mean age of 62.1 years (standard deviation [SD], 5.1 years) and mean PSA of 4.2 ng/mL (interquartile range [IQR], 3.5 to 5.8).

In a fair quality cohort study using electronic health record data, Walter et al. (2013)^33^ identified a cohort of Veterans Affairs health system patients (n=295,645) who had a single PSA screening test in 2003. Among this cohort, potential biopsy candidates were identified based on PSA results exceeding 4.0 ng/mL; the study prospectively followed this cohort for up to five years. Among men in this cohort, the mean age was 73.0 years, nearly 90% of men were white, and 62.4% had no comorbidities.

The 2008 USPSTF review identified two prospective cohort studies^110,111,113^ and one cross-sectional study evaluating psychological harms of PSA screening.^112^ In a good-quality study within one U.S. academic medical center,^110,111^ a cohort of men undergoing PSA screening were identified and surveyed by mail regarding worry and concern about prostate cancer at 6 weeks, 6 months, and 12 months after either normal PSA screening (n=193) or benign biopsy (n=287). In a fair-quality prospective cohort study embedded as part of case-finding for the ProtecT trial,^113^ men aged 50 to 69 years who were attending a clinic for PSA screening (n=7,344) completed questionnaires regarding baseline depression, anxiety, and general health status, and the subsample of men with abnormal screening results completed the same measures prior to biopsy (n=569). Lastly, in a fair-quality cross-sectional study within a single U.S. academic institution,^112^ men were surveyed regarding anxiety, worry about prostate cancer, and general health status by telephone either 2 months after a normal PSA screening results (n=101) or after a benign biopsy prompted by abnormal PSA screening (n=109).

### Findings

#### Exposure to Followup Testing and False Positives

##### Followup Testing

Among men randomized to screening in the PLCO who had at least one screening test (n=35,870), 10,798 men (28.2%) had at least one elevated PSA screen (≥4.0 ng/mL) during up to six screening rounds. Of men with elevated PSA tests, 4,836 (44.8% of men with positive screens, 12.6% of men randomized to screening) underwent one or more biopsies, resulting in a total of 6,295 biopsies (16.4 biopsies per 100 men randomized to screening). Of 6,295 biopsies performed on these 4,836 men, 67.7% did not result in a prostate cancer diagnosis.^103^

Among men randomized to screening in the ERSPC core age group (n=72,891), men were screened on average 1.9 times over a median followup of 13.0 years. During this period, there were 23,574 positive PSA tests (0.32 positive tests per man randomized to screening). Among men with positive screening tests, there were 20,188 prostate biopsies performed (27.7 biopsies per 100 men randomized to screening). Of the 20,188 biopsies performed, 15,305 (75.8%) did not result in a prostate cancer diagnosis.^96^

In the fair-quality VA cohort study of men undergoing a single PSA screening test, 8.5 percent of screened men (n=25,208) had a PSA exceeding 4.0 ng/mL. Of those men, most (51.2%) underwent further PSA testing without biopsy, and 8,313 underwent biopsy (32.9% of men with elevated PSA). Of men undergoing biopsy, 37.2% did not have prostate cancer.^33^ The higher positive predictive value of biopsy in this cohort (62.8%) compared to the two trials (24.2% and 32.3% in ERSPC and PLCO, respectively) may be attributable to the older age of men in the cohort as well as the selection of men for biopsy based on repeated PSA or other clinical features.

##### False-Positive Testing

Among men who underwent at least one PSA screen during the initial four PLCO screening rounds (n=32,576), the cumulative incidence of false-positive PSA screening was 10.4 percent (defined as a PSA>4 ng/mL with the absence of a prostate cancer diagnosis within three years of positive screening) (Table 8).^107^ After four rounds of screening, the risk of undergoing biopsy on account of a false-positive PSA screen was 5.5 percent (95% CI, 4.6% to 6.5%).

Longitudinal post-biopsy followup was reported for five ERSPC centers (Belgium, Finland, Italy, Netherlands, and Sweden), enabling classification of abnormal PSA screening results as true- versus false-positive (Table 8).^101^ False-positive screening results were defined as elevated PSA results without a histological prostate cancer diagnosis occurring within one year of the screen. Each site reported results for three screening rounds, while Sweden reported results of six screening rounds. Among men randomized to screening who were screened at least once (n=61,604), 17.8 percent (n=10,972) had at least one false-positive screening test. Cumulative false-positive rates were lower at sites with a higher screen-positive PSA threshold of 4.0 ng/mL (9.0% in Italy and 11.9% in Finland), as compared to sites with lower thresholds of 2.5 to 3.0 ng/mL (cumulative false-positive rates of 15.6%, 27.8%, and 44.9% in Belgium, Netherlands, and Sweden, respectively). In addition to the lower screen-positive threshold, there were up to six biennial screening rounds at the Swedish site (as compared to a maximum of three rounds every fourth year at the other sites), which contributed to the higher cumulative false-positive rate at the Swedish site.

#### Physical and Psychological Harms of PSA Screening and Diagnostic Followup

##### PSA Testing

PSA screening requires venipuncture, and the PLCO reported rare adverse effects of this procedure, including bleeding (0.3 events per 10,000 men screened) and dizziness, fainting, or bruising (26.2 events per 10,000 men screened) (Table 8).^53^

##### Complications of Diagnostic Followup

Among 4,836 men who underwent biopsy within the PLCO, biopsy complications occurred at a rate of 20.2 per 1,000 biopsies (approximately 2% overall), including 7.8 infectious and 13.0 non-infectious complications per 1,000 biopsies (non-infectious complications consisted predominately of bleeding or urinary difficulties) (Table 8). Biopsy was not associated with increased short-term (120-day) mortality relative to men with negative PSA screens (RR, 0.49 [95% CI, 0.2 to 1.1]).^103^

Among 5,676 men undergoing prostate biopsy after abnormal PSA at the ERSPC Rotterdam site, 22.6 percent experienced hematuria lasting more than 3 days, 7.5 percent reported significant post-biopsy pain, 3.5 percent experience fever, and 0.5 percent were hospitalized (the large majority due to infectious complications).^108^ Among men randomized at three ERSPC centers (Finland, Netherlands, and Sweden), prostate biopsy was not associated with overall mortality during a one-year post-biopsy followup as compared to screen-negative men who did not undergo biopsy.^104^

Among men in the ProBE cohort (n=1,147), 7.4 percent reported moderate or severe hematuria immediately after biopsy (95% CI, 6.0% to 9.1%), and 89.4 percent (87.4% to 91.1%) reported one or more infective/hemorrhagic symptoms within 7 days of biopsy. During the 35 days after biopsy, 7.3 percent of men (95% CI, 5.7% to 9.1%) reported pain to be a moderate or serious problem, 5.5 percent experienced fevers that were a moderate or serious problem (95% CI, 4.2% to 7.1%), and 26.6 percent considered hemoejaculation to be a moderate or serious problem (95% CI, 23.3% to 30.2%). Within 35 days of biopsy, 1.3 percent of men were admitted to hospital for biopsy-related complications (95% CI, 0.8% to 2.1%), including 0.6 percent of men who were admitted for sepsis within 3 days of biopsy. Overall, 10.4 percent of men sought outpatient care for biopsy-related symptoms (95% CI, 8.7% to 12.3%). There were no biopsy related deaths (95% CI, 0% to 0.4%).

Of men with abnormal PSA screens who underwent prostate biopsy and were followed in the fair-quality VA cohort study, (n=8,313), 5.6 percent had infectious or urinary complications within seven days of biopsy, and 1.6 percent were hospitalized (Table 8); comparison rates for a non-biopsy control group were not provided.^33^

##### Psychological Harms of PSA Screening

In a prospective cohort study^110,111^ and a cross-sectional study,^112^ men who had abnormal PSA screening tests but benign biopsy results had significantly increased worry about prostate cancer at both six- to eight-week as well as one-year followup compared to men with normal PSA screening results. At 12 months followup, 33 percent of men with a benign biopsy after abnormal screening thought about prostate cancer either “a lot” or “some” as compared to 18 percent of men who had normal PSA screening (p=0.005). However, in a U.K. prospective cohort study, men who had received abnormal PSA screening results had no increase in anxiety or depression relative to baseline prior to PSA screening and similar scores on the Mental Health Component of the SF-12.^113^ Likewise, in a comparative, cross-sectional U.S. study (n=210), men with benign biopsies after abnormal PSA screening did not have statistically significantly greater trait anxiety than men who received normal results approximately two months after receiving final test results.^112^

##### Impact on Health-Related Quality of Life

Within the Finnish arm of the ERSPC trial, a subsample of men randomized to the screening arm were asked to complete the SF-36 health and functional status assessments at invitation, after PSA screening, after receiving a PSA result, after DRE, and after TRUS with biopsy (n, range: 215 to 386). As compared to status at invitation, health and functional status were essentially unchanged at every other point in the screening process. While prostate biopsy is an invasive procedure that is associated pain and discomfort, within the sub-sample of men who underwent TRUS and biopsy after positive PSA (n=319), biopsy was not associated with any change in the SF-36 bodily pain subscale as compared to pre-biopsy.^105^ In a cross-sectional study of U.S. men,^112^ overall SF-36 scores (as well subscale scores) were similar among men who had normal PSA screening results and men who had abnormal PSA screening results with subsequent benign biopsies.

#### Overdiagnosis of Prostate Cancer

Using the approach described in the Methods, we assessed the rate of overdiagnosis using data from the PLCO, the overall ERSPC trial, and four ERSPC sites reporting extended followup (Sweden, Netherlands, Finland and Spain). The PLCO and overall ERSPC reported excess incidence after a median of 13.0 years followup, while median followup at ERSPC subsites ranged from 12.0 years (Finland) to 15.2 years (Spain).

As shown in Table 9 when overdiagnosis is estimated as a percentage of all prostate cancers diagnosed, 16.4 percent and 33.2 percent of prostate cancers were overdiagnosed in PLCO and overall ERSPC trials, respectively. When estimated as a percentage of cancers detected by screening during the screening phase, 20.7 percent and 50.4 percent of cancers were overdiagnosed in the PLCO and ERSPC trials, respectively.

The extent of overdiagnosis varied across ERSPC sites (Table 9). When estimated as a percentage of all prostate cancers diagnosed, the extent of overdiagnosis within ERSPC subsites ranged from 23.6 percent to 47.9 percent in Finland and the Netherlands, respectively. At these two sites, we could identify the number of cancers detected by screening, and the extent of overdiagnosis of screen-detected cases was 25.6 percent in Finland and 58.9 percent in the Netherlands. The two ERSPC sites with the largest extent of overdiagnosis (Sweden and Netherlands) were those with relatively more intensive screening protocols (PSA biopsy thresholds of 2.5 to 3.0 ng/mL at each site, biennial screening in Sweden and every four years in the Netherlands, and comparatively high rates of biopsy). Sweden and the Netherlands were also the only ERSPC sites to report statistically significant reductions in prostate cancer mortality, suggesting that a reduction in prostate cancer mortality with PSA screening may necessitate a higher level of overdiagnosis.^85,92^

These estimates of overdiagnosis should be interpreted cautiously for several reasons.^188^ Due to the long lead-time of prostate cancer, the duration of post-screening followup may be insufficient for incident cases to accrue fully in control arms. For example, at the ERSPC sites with screening rounds every four years (Netherlands, Finland, and Spain), the 12 to 15 year median followup period would allow approximately 4 to 7 years of followup after the third and final screening rounds. Estimates of overdiagnosis could be lower with longer-term followup. However, use of screening in the control arm during and after the screening phase of the trial may reduce the excess incidence that would be observed with strict adherence to screening protocol and cessation of screening in both trial arms at the end of the screening phase.^67^ In both the PLCO and ERSPC, there was evidence of substantial PSA screening in both screening and control groups during post-trial followup.^86,96,183^ The use of PSA screening during and after the screening phase among control subjects would reduce trial-based estimates of overdiagnosis. Thus, the precise extent of overdiagnosis in the PLCO and ERSPC may be difficult to discern even after many additional years of post-trial followup.

## KQ2a Do the Harms of PSA Screening Vary Between a Priori Subgroups: Age, Race/Ethnicity, Family History, or Clinical Risk?

### Age

Among ERSPC participants, false-positive rates were higher among older as compared to younger men, ranging from 3.5 percent in men younger than 55 years to 20.6 percent in men older than 70 years during the first screening round.^101^

In the VA cohort study, the proportion of PSA tests exceeding 4.0 ng/mL that resulted in a prostate biopsy was higher among younger men (50.5% among men aged 65 to 69 years) compared with older men (25.4%, 16.5% and 10.0% among men aged 75 to 79 years, 80 to 84 years, and older than 85 years, respectively).^33^

Biopsy complications in the PLCO were more common in men aged 70 years or older compared to men younger than age 70 years (28.2 vs. 17.7 complications per 1000 biopsies, respectively), although this difference did not reach statistical significance in adjusted analyses (OR, 1.4 [95% CI, 0.9 to 2.4]; p=0.06).^103^

### Race/Ethnicity

Two studies compared the risk of biopsy complications by race/ethnicity. In the PLCO trial, infectious complications were significantly more common in black men as compared to non-black men (OR, 7.1 [95% CI, 2.7 to 18.0]; p<0.001); however, the same was not true for non-infectious complications (OR, 0.5 [95% CI, 0.1 to 3.6]; p=0.08).^103^ Due the small sample size of biopsies among black men in the PLCO (n=142), confidence intervals were wide around the odds ratio for infectious complications, and it is unclear why black men would be at elevated risk for infectious biopsy complications.

### Family History

No studies assessed the risk for screening or diagnostic-related harms based on family history of prostate cancer.

### Clinical Risk Assessment

The PLCO trial did not find any significant difference in total, infectious, or non-infectious complications based on level of comorbidity.

No studies assessed the risk for screening or diagnostic-related harms based other measures of clinical risk, such as baseline PSA.

## KQ3 Is There Evidence That Various Treatment Approaches for Early-Stage or Screen-Detected Prostate Cancer Reduce Morbidity and Mortality?

Three good-quality RCTs^74,116^–^119,121^–^124,132,133,136^ and 10 cohort studies (3 good-quality and 7 fair-quality)^75,114,115,125,127^–^131,134,135^ compared the benefits of various active treatments to conservative management for early-stage or screen-detected prostate cancer (Tables 10, 11, and 16–19). Of the three RCTs, only the recently published Prostate Testing for Cancer and Treatment (ProtecT) trial assessed the impact of various treatment approaches on long-term outcomes of screen-detected prostate cancer, while patient samples in prior trials included men with clinically-detected rather than screen-detected cancers.

Table 10 Study Characteristics of Randomized, Controlled Trials of Prostate Cancer Treatment Benefits and Harms

Study Reference Quality Rating | Study Location Recruitment | Followup | Treatment Approaches (n) Conservative Management Definition | Participant and Tumor Characteristics | Outcomes Reported
ProtecT Hamdy, 2016^121^ Lane, 2014^126^ Good | United Kingdom Men were recruited from 337 primary care centers in nine cities | 10.0 years (median) | Radical prostatectomy (n=553) Radiation therapy (n=545, EBRT; included neoadjuvant ADT concurrently and for 3 to 6 months prior to radiation) Active monitoring (n=545) Active monitoring: serum PSA every 2 months in the first year and 6 to 12 monthly thereafter. A rise of at least 50% during the previous 12-months triggered a review. Management options included continued monitoring or further tests, and radical or palliative treatments as required. | Age (median): 62 years Age (range): 49 to 69 years Race/Ethnicity: White: 98% (1606/1643) African-Caribbean: <1% (10/1643) Other: 2% (37/1643) Family history of prostate cancer: 7% (119/1643) PSA (median): 4.6 ng/mL PSA (range): 3.0-19.9 ng/mL | Mortality; morbidity; harms
SPCG-4 Bill-Axelson, 2014^117^ Good | Sweden, Finland, Iceland Men were recruited from clinical treatment centers | 13.4 years (median) 3 weeks to 23.2 years (range) | Radical prostatectomy (n=347) Watchful waiting (n=348) Watchful waiting: men assigned to observation who did not receive any immediate treatment Men who experienced local progression were offered transurethral resection of the prostate. | Age (mean): 65 years Tumor Risk: Low: 36% (249/695) Intermediate: 40% (281/695) High: 24% (165/695) Tumor Stage: T1b: 12% (83/695) T1c: 11.7% (81/695) T2: 76% (529/695) Unknown: 0.3% (2/695) Gleason Score: 2 to 4: 13% (90/695) 5 to 6: 47% (331/695) 7: 23% (159/695) 8 to 10: 5% (35/695) Unknown: 11.5% (80/695) | Mortality; morbidity; harms
PIVOT Wilt, 2017^74^ Wilt, 2012^133^ Good | United States Men recruited from 44 VA and 8 NCI sites | 12.7 years (median) | Radical prostatectomy (n=364) Observation (n=367) Observation: men were offered palliative (non-curative) therapies (e.g., transurethral resection of the prostate for local progression causing urinary obstruction, ADT and/or targeted radiation therapy for evidence of distant spread). | Age (mean): 67 years Tumor Risk: Intermediate/high: 66% Tumor Stage: T1c:50% Gleason Score: ≥7: 48% | Mortality; morbidity; harms
Fransson, 2009^71^ Fransson, 2001^70^ Fair | Sweden Men were recruited from treatment centers | 10.0 years (median) | Radiotherapy (n=59) Watchful waiting (n=49) Watchful waiting: regular monitoring and deferred treatment until time of disease progression | Age (mean): 77.5 years Age (range): 54 to 88 years Tumor stage: T1: 25% (14/57) T2: 75% (43/57) | Harms

Abbreviations: ADT=androgen deprivation therapy; PIVOT=Prostate Cancer Intervention versus Observation Trial; ProtecT=Prostate testing for cancer and Treatment; SPCG-4=Scandinavian Prostate Cancer Group Study Number 4

Table 11 Study Characteristics of Cohort Studies of Prostate Cancer Treatment Benefits and Harms

Study Reference Quality Rating | Study Location Recruitment | Followup | Treatment Approaches (n) Conservative Management Definition | Participant and Tumor Characteristics | Outcomes Reported
Barocas, 2017 Good | United States Men were identified in 5 SEER registries (Atlanta, Los Angeles, Louisiana, New Jersey, and Utah) and the CaPSURE database | 3.3 years | Radical Prostatectomy (n=1,523) Radiation Therapy (n=598, EBRT) Active Surveillance (n=429) Active Surveillance: absence of treatment or no treatment administered within 1 year of diagnosis | Age (mean): 63.8 years Race/ethnicity White: 73% (1874/2550) Black: 14% (358/2550) Hispanic: 7% (186/2550) Asian: 3% (80/2550) Other: 1% (37/2550) Comorbidity 0-2: 28% (687/2550) 3-4: 42% (1024/2550) ≥5: 30% (728/2550) Tumor Stage T1c: 76% (1933/2550) T2: 24% (606/2550) Gleason Score ≤7: 90% (2298/2550) >7: 10% (252/2550) | Mortality (survival) Harms
Chen, 2017 Good | United States Men were identified in the North Carolina Central Cancer Registry | 2 years | Radical Prostatectomy (n=469) Radiation Therapy (n=358, including EBRT [n=249] and brachytherapy [n=109]) Active Surveillance (n=314) Active surveillance: medical records indicating that active surveillance was the selected treatment strategy | Race/ethnicity White: 72% (825/1141) African American: 25% (290/1141) Other: 3% (26/1141) | Harms
Lu-Yao, 2014^70^ Good | United States Men were identified in the SEER-Medicare database | 9.2 years (median) | ADT(n=25,125) Conservative management (n=41,592) Conservative management: no evidence of receiving surgery, radiotherapy, or ADT during the first 180 days following diagnosis | NR | Mortality
Sun, 2014^131^ Fair | United States Men were identified in the SEER-Medicare database | 2 to 15 years (range) | Radical prostatectomy (n=15,532) Radiation therapy (n=33,613) Observation (n=17,942) Observation: absence of active treatment within 6 months of prostate cancer diagnosis | NR | Mortality
Abdollah, 2012^114^ Fair | United States Men were identified in the SEER-Medicare database | 2 to 15 years (range) | Radiation therapy (n=20,986) Observation (n=20,986) Observation: absence of active treatment within 6 months of prostate cancer diagnosis | Age: 65 to 69 years: 22.8% 70 to 74 years: 35.8% 75 to 80 years: 41.4% Comorbidity 0: 42.3% 1:27.5% ≥2: 30.2% | Mortality
Thong, 2010^161^ Fair | Netherlands Men were identified in the Eindhoven Cancer Registry (ECR) | 5 to 10 years (range) | Radiation therapy (n=71; EBRT) Active surveillance (n=71) Active surveillance: stage and tumor grade <2 at time of diagnosis who received no active treatment | Age (mean): 76 years Tumor stage: T1: 80% (114/142) T2: 20% (28/142) | Harms
Ladjevardi, 2010^125^ Fair | Sweden Men were identified in Sweden’s National Prostate Cancer Register (NPCR) | 4.4 years (median) 0 to 12 years (range) | Radical prostatectomy (n=12,950) Radiation therapy (n=6,308, including EBRT [n=4443] and brachytherapy [n=1865]) Conservative management (n=12,645; watchful waiting, n=9,435, palliative treatment [included ADT], n=3,210) Conservative management: not clearly defined, but includes both watchful waiting and men on palliative treatment | Age (mean): 65.2 years Tumor stage: T0: <1% (220/31903) T1: 54.5% (17438/31903) T2: 34.3% (10933/31903) T3: 9.6% (3071/31903) TX:<1% (241/31903) | Mortality
CDC-NPCR Breast, Colon, and Prostate Cancer Data Quality and Patterns of Care Study (PoC1) Schymura, 2010^129^ Fair | United States Random samples of prostate cancer patients were selected from the databases of participating cancer registries in seven states | 5 years | Radical prostatectomy (n=1310) Radiation therapy (n=1037, including EBRT or brachytherapy) ADT (n=339) Watchful waiting (n=614) Watchful waiting: no therapy within six months of diagnosis | Age: <60 years: 18% (601/3300) 60 to 64 years: 17% (565/3300) 65 to 69 years: 22% (730/3300) 70 to 74 years: 21 % (703/3300) 75 to 79 years: 14% (453/3300) ≥80 years: 8% (248/3300) Race/ethnicity: Non-Hispanic white: 80% (2649/3300) Non-Hispanic black: 14% (460/3300) Non-Hispanic other: 2% (56/3300) Hispanic: 3% (113/3300) Unknown: 1% (22/3300) | Mortality (survival)
National Prostate Cancer Register of Sweden Follow-Up Study Stattin, 2010^130^ Fair | Sweden Men identified in the Swedish Cancer Registry | 8.2 years (median) | Radical prostatectomy (n=3399) Radiation therapy (n=1429) Surveillance (n=2021) Surveillance: combined active surveillance and watchful waiting (no further definition provided) | Age: <60 years: 26.8% (1836/6849) 60 to 64 years: 29.7% (2036/6849) 65 to 69 years: 43.5% (2977/6849) Tumor stage: T1: 58.6% (4015/6849) T2: 41.4% (2834/6849) Gleason score: 2 to 6: 85.8% (5875/6849) 7: 14.2% (974/6849) Comorbidity: 0 to 1:92.7% (6347/6849) ≥2: 7.3% (502/6849) | Mortality
Smith, 2009^159^ Fair | Australia Men were identified in the New South Wales central cancer registry. | 3.8 years (mean) | Radical prostatectomy (n=981) Radiation therapy (n=394, including EBRT [n=123], low-dose brachytherapy [n=58], high-dose brachytherapy [n=47], EBRT/ADT [n=166]) ADT(n=61) Active surveillance (n=200) Active surveillance: no further definition provided | Age (mean): 61.2 years Age (range): 37 to 69 years Tumor stage: T1: 54.4% (889/1636) T2: 45.7% (747/2636) Gleason score: 2 to 6: 55.0% (894/1636) 7: 34.3% (557/1636) 8 to 10: 10.7% (173/1636) Comorbidity: 0:37.9% (623/1636) 1:32.1% (529/1636) ≥2: 30.1% (484/1636) | Harms
Zhuo, 2009^135^ Fair | United States Men were identified in the Ohio Cancer-Aging Linked Database (CALD), which combines data from the Ohio Cancer Incidence Surveillance System (OCISS) and Medicare | 7 years | [underlined: Monotherapy]: Radical prostatectomy (n=936) Radiation therapy (n=1520, including EBRT [n=876] and brachytherapy [n=644]) ADT (n=2947) No treatment (n=2306) No treatment: no definitive therapy within 6 months of diagnosis) | Age: 65 to 69 years: 21.5% (2186/10179) 70 to 74 years: 32.1% (3263/10179) ≥75 years: 46.8% (4760/10179) Race/ethnicity: Non-African American: 91.0% (9265/10179) African American: 9.0% (914/10179) Gleason score: <7: 66.4% (6761/10179) 7 to 10: 23.8% (2418/10179) Unknown: 9.8% (1000/10179) | Mortality
Albertsen, 2007^115^ Fair | United States Men identified in the Connecticut Tumor Registry (CTR) | 13.3 years (median) | Radical prostatectomy (n=802) Radiation therapy (n=702) No initial therapy (n=114) No initial therapy: observation (not further defined) | Gleason score: 2 to 4:4% 5: 6% 6: 47% 7: 26% 8 to 10: 17% | Mortality
Wong, 2006^134^ Good | United States Men were identified in the SEER-Medicare database | 12.0 years | Active treatment (n=32,022, including radical prostatectomy [n=13,292] and EBRT or brachytherapy [n=18,249], alone or in combination) Observation (n=12,608) Observation: no Medicare data indicating prostatectomy, radiation therapy or hormonal therapy | Age (mean): 72 years Tumor stage: ≤T2a: 55% T2b-T2c: 45% | Mortality
Hoffman, 2003^145^ Fair | United States Men identified in the SEER registry as part of the Prostate Cancer Outcomes Study (PCOS) | 2.0 years | Radical prostatectomy (n=1373) Radiation therapy (n=583) ADT(n=179) No treatment (n=230) No treatment: no active treatment | Age (mean): 66 years Age (range): 39 to 88 years Race/ethnicity: Non-Hispanic white: 74.0% (1751/2365) Non-Hispanic black: 13.2% (311/2365) Hispanic: 12.8% (303/2365) | Harms
Litwin, 2002^151^ Fair | United States Men were drawn from the Cancer of the Prostate Strategic Urologic Research Endeavor (CaPSURE) database | 1.6 years (mean) | Radical prostatectomy (n=282) Radiation therapy (n=104) Watchful waiting (n=66) Watchful waiting = no further definition provided | Age (mean): 65.5 years Race/ethnicity: White: 89.2% (403/ 452) African American: 8.2% (37/452) Other: 2.4% (11/452) | Harms
Potosky, 2002^154^ Fair | United States Men identified in the SEER registry as part of the Prostate Cancer Outcomes Study (PCOS) | 1.0 year | ADT (n=245) No treatment (n=416) No treatment: no active treatment | Age: 40 to 59 years: 4% (27/661) 60 to 69 years: 22% (145/661) 70 to 79 years: 53% (350/661) ≥80 years: 21% (139/661) Tumor stage: T1: 33% (221/661) T2: 51% (338/661) Unknown: 15% (101/661) | Harms
Bacon, 2001^139^ Fair | United States Men who participated in the Health Professionals Followup Study (HPFS) | 5.0 years | Radical prostatectomy (n=421) Radiation therapy (n=290, including EBRT [n=221] and brachytherapy [n=69]) Hormonal therapy (n=33) Other (n=67; not otherwise defined) Watchful waiting (n=31) Watchful waiting: no further definition provided | Age (mean): 71 years Tumor stage: T1: 3% (23/842) T2: 86% (726/842) Other: 11% (93/842) | Harms
Schapira, 2001^156^ Fair | United States Men were identified through surveillance of the pathology laboratories at participating hospitals | 1.0 year | Radical prostatectomy (n=42) Radiation therapy (n=51) Expectant management (n=29) Expectant management: no further definition provided | Age (median): 69 years Tumor stage: T1: 50% (61/122) T2: 50% (61/122) | Harms
Siegal, 2001^158^ Fair | United States Men registered at the Center for Prostate Disease Research | 4.3 years (median) | Radical prostatectomy (n=419) Radiation therapy (n=319; EBRT) Watchful waiting (n=64) Watchful waiting: no further definition provided | Age: ≤70 years: 62% (500/802) >70 years: 33% (268/802) Unknown: 5% (34/802) Race/ethnicity: White: 70% (563/802) Black: 24% (190/802) Other/unknown: 6% (49/802) Gleason score: 2 to 4: 42% (340/802) 5 to 7: 44% (349/802) 8 to 10: 5% (41/802) Unknown: 9% (72/802) | Harms
Smith, 2000^160^ Fair | United States Men enrolled in a serial prostate cancer screening study at a university center | 3.8 years | Radical prostatectomy (n=1247) Radiation therapy (n=189) Hormone therapy (n=67) Cryotherapy (n=28) Observation (n=120) Observation: no further definition provided | Age (mean): 67 years Race/ethnicity: African American: 4.0% (66/1651) White/other: 96.0% (1585/1651) | Harms
Lubeck, 1999^152^ Fair | United States Men were drawn from the Cancer of the Prostate Strategic Urologic Research Endeavor (CaPSURE) database | 2.0 years | Radical prostatectomy (n=351) Radiation therapy (n=75) Hormone therapy (results not abstracted, as 32% [51/179] had stage T3 or higher at baseline) Observation (n=87) Observation: no surgery, radiation or medical therapy within the first year following diagnosis | Age (mean): 66.0 years Tumor stage: T1: 25% (174/692) T2: 62% (427/692) T3/T4: 5% (33/6692) Other: 8% (52/692) | Harms
Litwin, 1995a&b^149,150^ Fair | United States Men were identified from the tumor registry of a large managed care population | 6.0 years | Radical prostatectomy (n=98) Radiation therapy (n=56) Observation (n=60) Observation: no further definition provided | Age (mean): 73 years | Harms

Abbreviations: ADT=androgen deprivation therapy; EBRT=external beam radiation therapy

Table 16 The Effect of Radiation Therapy^*^ Compared With Conservative Management^†^ on Prostate Cancer-Specific Morbidity and Mortality and All-Cause Mortality

Study Reference Quality Rating | Study Design Followup | Prostate-Cancer Specific Mortality | All-Cause Mortality | Morbidity
ProtecT Hamdy, 2016^121^ | RCT 10.0 years (median) | RT: 0.7% (4/545) AS: 1.5% (8/545) HR=0.51 (95% CI, 0.15 to 1.69) | RT: 10.1% (55/545) AS: 10.8% (59/545) HR=0.94 (95% CI, 0.65 to 1.36) | [underlined: Progression to Metastatic Disease] RT: 2.9% (16/545) AS: 6.0% (33/545)
Barocas, 2017^75^ Good | Cohort 3.3 years (median) | RT: 0.3% (2/598) AS: 0% (0/429) | RT: 3.9% (21/598; 95% CI, 2.3 to 5.5%) AS: 2.9% (12/429; 95% CI, 1.3 to 4.6%) | NR
Ladjevardi, 2010^125^ Fair | Cohort 4.4 years (median) | NR | HR=0.54 (95% CI, 0.49 to 0.59) | NR
Schymura, 2010^129^ Fair | Cohort 5.0 years | NR | [underlined: 5-year survival (unadjusted)] RT: 86.0% WW: 75.5% In multivariate survival analysis with radical prostatectomy the reference category: HR (death with RT)=1.66 (95% CI, 1.24 to 2.21) HR (death with WW)=2.30 (95% CI, 1.70 to 3.12) | NR
Stattin, 2010^130^ Fair | Cohort 8.2 years (median) | RT: 2.8% (40/1429) AS: 2.9% (58/2021) [underlined: 10-year cumulative mortality] RT: 3.3% (95% CI, 2.5 to 5.7) AS: 3.6% (95% CI, 2.7 to 4.8) RR=0.70 (95% CI, 0.45 to 1.1) | RT: 13.7% (196/1429) AS: 20.4% (413/2021) [underlined: 10-year cumulative mortality] RT: 18.3% (95% CI, 15.7 to 21.3%) AS: 23.4% (95% CI, 21.3 to 25.8%) RR=0.68 (95% CI, 0.57 to 0.82) | NR
Zhuo, 2009^135^ Fair | Cohort 7.0 years | EBRT: adjusted HR=0.66 (95% CI, 0.41 to 1.04); P=0.07 Brachytherapy: adjusted HR=0.45 (95% CI, 0.23 to 0.87); p=0.018 | EBRT: adjusted HR=0.63 (95% CI, 0.53 to 0.75) Brachytherapy: adjusted HR=0.40 (95% CI, 0.32 to 0.52) | NR
Albertsen, 2007^115^ Fair | Cohort 13.3 years (median) | RT: 18% WW: 16% RR=1.5 (95% CI, 0.9 to 2.6) | RT: 55% WW: 57% RR=1.2 (95% CI, 0.9 to 1.5) | NR
Wong, 2006^134^ Good | Cohort 12.0 years | NR | Adjusted HR=0.81 (95% CI, 0.78 to 0.85) | NR

* When studies reported outcomes for both internal (brachytherapy) and external (EBRT) radiation therapy, we abstracted data as such; however, most studies only reported radiation therapy at the aggregate level

† Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting) as well as observation or no treatment

Abbreviations: AS=active surveillance; EBRT=external beam radiation therapy; HR=hazard ration; RT=radiation therapy; RR=relative risk; WW=watchful waiting

Table 17 The Effect of Radiation Therapy^*^ Compared With Conservative Management^†^ on Prostate Cancer-Specific Morbidity and Mortality and All-Cause Mortality, by Subgroup and Risk Factor

Study Reference Quality Rating | Study Design Followup | Outcome | Age | Tumor Risk or Tumor Stage | Gleason Score | Other
Abdollah, 2012^114^ Fair | Cohort 2-15 years (range) | Prostate cancer-specific mortality | 65-69 years HR=0.93 (95% CI, 0.72 to 1.19; p=0.6) 70-74 years: HR=0.84 (95% CI, 0.68 to 1.03; p=0.08) 75-80 years: HR=0.70 (95% CI, 0.59 to 0.80; p<0.001) | Low/intermediate risk HR=0.91 (95% CI, 0.80 to 1.04; p=0.2) High risk HR=0.59 (95% CI, 0.50 to 0.68; p<.001) | NR | [underlined: Comorbidity] Charlson Score=0 HR=0.81 (95% CI, 0.67 to 0.98; p=0.03) Charlson Score=1 HR=0.87 (95% CI, 0.75 to 0.99; p=0.04) Charlson Score≥2 HR=0.79 (95% CI, 0.65 to 0.96; p=0.01)
Stattin, 2010^130^ Fair | Cohort 8.2 years (median) | Prostate cancer-specific mortality | NR | Low risk RT: 0.4% (5/1429) WW: 1.3% (14/2021) Intermediate risk RT: 2.5% (35/1429) WW: 2.2% (44/2021) [underlined: 10-year mortality] Low risk RT:1.8% (95% CI, 0.65 to 4.0%) WW: 2.4% (95% CI, 1.2 to 4.1) RR=0.94 (95% CI, 0.31 to 2.85) Intermediate risk RT: 3.8% (95% CI, 2.6 to 5.4%) WW: 5.2% (95% CI, 3.7 to 6.9) RR=0.66 (95% CI, 0.42 to 1.06) | NR | NR

* When studies reported outcomes for both internal (brachytherapy) and external (EBRT) radiation therapy, we abstracted data as such; however, most studies only reported radiation therapy at the aggregate level

† Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting) as well as observation or no treatment

Abbreviations: AS=active surveillance; EBRT=external beam radiation therapy; HR=hazard ration; RT=radiation therapy; RR=relative risk; WW=watchful waiting

Table 18 The Effect of Androgen Deprivation Therapy Compared With Conservative Management^*^ on Prostate Cancer-Specific Morbidity and Mortality and All-Cause Mortality

Study Reference Quality Rating | Study Design Followup | Prostate-Cancer Specific Mortality | All-Cause Mortality | Morbidity
Lu-Yao, 2014^127^ Good | Cohort 9.2 years (median) | [underlined: 9.2-years followup] ADT: 1,890/112,769 events PY (1.7 per 100 PY) WW: 1,849/115,151 events per PY (1.6 per 100 PY) HR=1.01 (95% CI, 0.90 to 1.14) | [underlined: 9.2-years followup] ADT: 13,633/134,658 events per PY (rate: 10.1 per 100 PY) WW: 13,314/135,202 events per PY (rate: 9.8 per 100 PY) HR=1.04 (95% CI, 0.99 to 1.09) | NR
Schymura, 2010^129^ Fair | Cohort 5.0 years | NR | [underlined: 5-year survival]^†^ HT: 65.2% WW: 75.5% | NR
Zhuo, 2009^135^ Fair | Cohort 7.0 years | Adjusted HR=1.32 (95% CI, 1.01 to 1.73; p=0.044) | Adjusted HR=0.89 (95% CI, 0.80 to 0.98; p=0.024) | NR

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting) as well as observation or no treatment

† This study reported adjusted hazard ratios using radical prostatectomy as the reference; this data is not presented.

Abbreviations: AS=active surveillance; ADT=androgen deprivation therapy; HR=hazard ration; PY=person years; RR=relative risk; WW=watchful waiting

Table 19 The Effect of Androgen Deprivation Therapy Compared With Conservative Management^*^ on Prostate Cancer-Specific Morbidity and Mortality and All-Cause Mortality, by Subgroup and Risk Factor

Study Reference Quality Rating | Study Design Followup | Outcome | Age | Tumor Risk | Gleason Score | Other
Lu-Yao, 2014_127_ Good | Cohort 9.2 years (median) | All-cause mortality | NR | NR | Gleason score 5 to 7: HR=1.03 (95% CI, 0.96 to 1.10) Gleason score 8-10: HR=1.03 (95% CI, 0.96 to 1.10) | NR
Lu-Yao, 2014_127_ Good | Cohort 9.2 years (median) | Prostate cancer-specific mortality | NR | NR | Gleason score 5 to 7: HR=1.00 (95% CI, 0.85 to 1.18) Gleason score 8–10: HR=0.99 (95% CI, 0.84 to 1.17) | NR

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting) as well as observation or no treatment

Abbreviations: AS=active surveillance; ADT=androgen deprivation therapy; HR=hazard ration; PY=person years; RR=relative risk; WW=watchful waiting

### Summary

The ProtecT trial randomized men with localized, screen-detected prostate cancer to one of three study arms (radical prostatectomy [RP; n=553], radiation therapy [RT; n=545] with neoadjuvant androgen deprivation therapy [ADT], and active surveillance [AS; n=545]).^126,136^ In each arm, prostate cancer survival was approximately 99 percent at median followup of 10.0 years, and no statistically significant differences were observed in the primary outcome of prostate cancer mortality. During the 10-year followup, the incidence of metastatic disease among men randomized to AS (6.3 cases per 1,000 person-years) was higher than among men randomized to RP or RT (2.4 and 3.0 cases per 1,000 person-years; p=0.004 for overall difference across arms). Approximately 27 and 33 men with screen-detected localized cancer would need to be treated with RP and RT (rather than AS), respectively, to prevent one man from progressing to metastases within 10 years. In earlier RCTs that included men with clinically diagnosed rather than screen-detected prostate cancer, RP was associated with statistically significantly reduced prostate cancer mortality compared to watchful waiting among all men in the SPCG-4 (median followup, 13.4 years; RR, 0.56 [95% CI, 0.41 to 0.77])^117^ but not in the U.S. Prostate Cancer Intervention Versus Observation Trial (PIVOT) trial (median followup, 12.7 years; HR, 0.63 [95% CI, 0.39 to 1.02)]).^136^ In both the SPCG-4 and the PIVOT trials, RP was also associated with reduced progression to metastatic or systemic disease (SPCG-4 at 13.4 y median followup: RR, 0.57 [95% CI, 0.44 to 0.75]; PIVOT at 12.7 median followup: HR, 0.64 [95% CI, 0.42 to 0.97)]).^117,136^ Thus, randomized trial evidence to date suggests that active treatment with RP or RT for early-stage, screen-detected prostate cancer is likely to reduce risk of clinical progression and metastatic disease and likely reduces prostate cancer mortality in men similar to those in the SPCG-4 with clinically detected or palpable tumors. The long-term impact of active treatments on prostate cancer mortality among men with screen-detected, lower-risk cancer remains unclear. We found no RCTs evaluating long-term outcomes of primary androgen deprivation therapy (ADT) for early-stage prostate cancer.

In eight cohort studies of RP^75,115,125,129^–^131,134,135^ and eight cohort studies of RT,^75,114,115,125,129,130,134,135^ both treatment approaches were predominately associated with improved prostate-cancer survival for men with early-stage prostate cancer, including studies that used propensity score or instrumental variable approaches to address potential unmeasured confounding. In a fair-quality cohort study using instrumental variable analyses, primary androgen deprivation therapy for early-stage prostate cancer was associated with no significant differences in prostate cancer mortality or overall mortality compared to conservative management.^127^ Interpretation of the cohort data, however, is difficult because many studies included men with both screen-detected cancers and cancer detected due to clinical symptoms. In addition, providers may select healthier men for active treatments and sicker men for primary ADT or conservative management; even with careful multivariate adjustment, residual confounding may affect cohort results.

### Study Characteristics

Overall, we identified three randomized controlled trials^117,121,133^ and ten cohort studies^75,114,115,125,127,129^–^131,134,135^ reporting all-cause mortality, prostate cancer-specific mortality, or morbidity for active prostate cancer treatments compared with conservative management strategies (i.e., active surveillance, watchful waiting, or observation) (Tables 10 and 11). We identified three RCTs^117,121,133^ and eight cohort studies^75,115,125,129^–^131,134,135^ that compared RP with conservative management, and one RCT^121^ and eight cohort studies^75,114,115,125,129,130,134,135^ that compared RT with conservative management. One RCT, the VACURG trial, which was graded poor quality and only discussed descriptively in the 2012 review, was excluded from the current review due to poor quality. Three cohort studies^127,129,135^ assessed the effectiveness of primary ADT compared with conservative management. We did not identify any RCTs or cohort studies comparing high-intensity focused ultrasound (HIFU) or cryotherapy with conservative management. Median followup ranged from 2.0 years^114,131^ to 13.4 years^117^ across all studies and of 10.0 years^121,133^ to 13.4 years^117^ in the RCTs.

Although each of the three treatment-related RCTs received a good-quality rating, several differences are notable. First, patient recruitment occurred during different points in the period of PSA uptake, yielding important differences in the prognosis of enrolled men. All men in the ProtecT trial had cancer that were detected by PSA screening, and approximately 77 percent of men had low-grade cancers (Gleason score = 6) with favorable prognoses. Even so, some men randomized to AS in ProtecT had intermediate grade tumors (or other tumor characteristics) such that they would not have been considered sufficiently low-risk to receive AS at many centers.^32^ In contrast to ProtecT, approximately half of men in the PIVOT trial had PSA-detected cancers, and most men in the SPCG-4 trial had palpable tumors that were diagnosed prior to the PSA screening era. Prognoses of men with clinically-detected prostate cancer would be expected to be poorer than men with screen-detected cancer.

Second, PIVOT and SPCG-4 included men up to age 75 years, while ProtecT limited recruitment to men aged 69 years or less. Third, only one of the three trials (PIVOT) included US men and was conducted exclusively among veterans which may limit generalizability to the general US screening population. Finally, the treatment protocol for men in the conservative management arm differed across trials. In the ProtecT trial, men in conservative management arm received “active monitoring,” which consisted chiefly of periodic PSA testing to monitor disease progression with urological evaluation and potential biopsy if PSA rose beyond specified thresholds. In contrast, in the PIVOT and SPCG-4 trials, conservatively managed men received “watchful waiting,” emphasizing palliative approaches when men experienced clinical progression.

Information on the interventions delivered was limited in most cohort studies. For example, of the 11 studies of radical prostatectomy, only one specified the type of prostatectomy performed (nerve-sparing versus non-nerve sparing).^75^ Similarly, of the 9 studies of radiation therapy, five^75,125,129,134,135^ specified the type of radiation therapy delivered (EBRT or brachytherapy, or a combination) but only one^135^ stratified outcomes by the type of radiation therapy delivered. Most cohort studies compared active treatments to a group of men who did not receive immediate active treatment, and thus the conservative management may have included men undergoing a watchful waiting approach or active surveillance.

### Findings

#### Radical Prostatectomy

We identified three RCTs^117,121,133^ and eight cohort studies^75,115,125,129^–^131,134,135^ that evaluated risk of all-cause mortality and prostate cancer-specific mortality associated with radical prostatectomy (RP) as compared with conservative management for treatment of men with localized (stages T1 or T2) prostate cancer. One of the eight cohort studies only presented results stratified by subgroups (e.g. age, comorbidities, etc.);^131^ therefore this study will be discussed only in the subsequent section addressing effectiveness among patient subgroups.

##### RCTs

ProtecT. Conducted in the U.K., the recently published ProtecT study^121^ randomized 1,643 men aged 50 to 69 years with PSA screen-detected localized prostate cancer to RP, RT, or active surveillance. ProtecT recruited men who were diagnosed with localized prostate cancer within practices participating in the CAP trial (Cluster randomized trial of PSA testing for Prostate cancer) in which participating U.K. primary care practices were randomized to PSA screening versus no screening. (Results of the CAP trial have not been reported and are expected in 2018.) The PSA threshold for diagnostic evaluation was 3.0 ng/dL. Among 2,896 men diagnosed with prostate cancer after screening, 270 (9.3%) were ineligible because they had advanced disease at diagnosis, 209 (7.2%) had localized disease but were excluded for other reasons (e.g., deemed unfit for radical treatment). Of the remaining men, 1,643 (62%) agreed to be randomized to RP (n=553), RT (n=545) or active surveillance (n=545).

At 10.0 years median followup, the hazard ratio (HR) for all-cause mortality with RP as compared to active surveillance was not statistically significant (0.93 [95% CI, 0.21 to 1.93]). The prostate cancer mortality rate for men randomized to RP was 0.9 per 1,000 person years (95% CI, 0.4 to 2.2) compared to 1.5 per 1,000 person years among men randomized to active surveillance (95% CI, 0.7 to 3.0), but this difference was not statistically significant. There were no differences in prostate cancer-specific mortality between treatment and non-treatment groups as cancer-specific survival remained above 98.8 percent in all study arms. Over half of men randomized to active surveillance eventually received radical treatment (54.8% [95% CI, 50.4 to 59.3%]); thus, nearly half the men in the monitoring arm remained stable without any curative treatment at 10 years.

A pre-specified secondary outcome of ProtecT^121^ was clinical progression, defined as progression to metastases, clinical T3 or T4 disease, long-term androgen deprivation therapy, ureteric obstruction, rectal fistula, or need for a urinary catheter due to obstruction. At a median of 10 years followup, 8.4 percent of men who underwent RP experienced clinical progression as compared to 20.6 percent of men randomized to active surveillance (HR, 0.39 [95% CI, 0.27 to 0.54]). Men who received RP were less than half as likely to progress to metastatic disease (2.4 per 1,000 person years [95% CI, 1.4 to 4.2]) compared with men randomized to active surveillance (6.3 per 1,000 person years [95% CI, 4.5 to 8.8]). Over a ten year period, an estimated 27 men would need to be treated with RP rather than receiving active surveillance to avert one case of metastatic prostate cancer.

PIVOT. Conducted in U.S. Veterans Affairs medical centers, the PIVOT study (n=731)^133^ randomized men with localized prostate cancer (approximately half of which were not palpable and were detected via PSA testing) to RP or observation. The first publication from PIVOT reported outcomes at a median followup of 10 years,^133^ while a recent publication reported outcomes at a median of 12.7 years of followup.^133^ After a median followup of 12.7 years, RP was not associated with statistically significant decrease in the trial’s primary outcome of all-cause mortality compared with observation (HR, 0.84 [95% CI, 0.70 to 1.01]; absolute risk reduction, 5.5% [95% CI, −1.5% to 12.4%]). RP was not associated with significant decrease in risk of prostate cancer-specific mortality compared to observation (HR, 0.63 [95% CI, 0.39 to 1.02]). After a median followup of 12.7 years, the percentage of men in the PIVOT trial who experienced systemic progression of their prostate cancer was significantly lower among men randomized to RP as compared to observation (HR 0.64 [95% CI, 0.42 to 0.97]; absolute risk reduction, 4.5% [95% CI, −0.3% to 9.4%]. Similarly, after a median followup of 10.0 years, the incidence of bone metastases was significantly lower for men randomized to RP as compared with men randomized to observation (4.7% vs. 10.6%; HR, 0.40 [95% CI, 0.22 to 0.70]).

SPCG-4. In the SPCG-4 trial (n=695),^117^ men with localized prostate cancer identified in the pre-PSA era in several Scandinavian countries were randomized to RP or watchful waiting. After a median of 13.4 years of followup, RP was associated with a decrease in risk for all-cause mortality versus watchful waiting (RR, 0.71 [95% CI, 0.59 to 0.86]; absolute difference, 12.7% [95% CI, 5.1% to 20.3%]). Similarly, RP was associated with significantly reduced prostate cancer-specific mortality compared to watchful waiting (RR, 0.56 [95% CI, 0.41 to 0.77]; absolute difference, 11.0% [95% CI, 4.5% to 17.5%]) and reduced risk of progression to metastatic disease (RR, 0.57 [95% CI, 0.44 to 0.74]; absolute risk difference, 12.2% [95% CI, 5.1 to 19.3%]).

##### Cohort Studies

Seven cohort studies compared mortality or morbidity among men with localized prostate cancer treated with RP versus conservative management (median n=3,242; followup duration: 3-13 years).^75,115,125,129,130,134,135^ In three of four cohort studies that compared prostate cancer-specific mortality among patients undergoing RP versus conservative management,^130,134,135^ RP was associated with statistically significantly reduced prostate cancer mortality in three studies as compared to conservative management, while few prostate cancer deaths occurred in the fourth cohort study, which had a short median followup of three years.^75^ All seven cohorts^75,115,125,129,130,134,135^ reported on all-cause mortality; radical prostatectomy was associated with statistically significantly decreased risk of all-cause mortality compared to conservative management in all but two cohorts.^75,115^ No cohort studies assessed the impact of radical prostatectomy on cancer-related morbidity (i.e. metastatic disease).

#### Radiation Therapy

One RCT^121^ and eight cohort studies^75,114,115,125,129,130,134,135^ evaluated mortality or morbidity outcomes associated with RT as compared with conservative management in men with localized prostate cancer. One of the eight cohort studies only presented results stratified by subgroups so it is discussed in a later subsection addressing subgroups.^114^ Only the ProtecT trial (and none of the cohort studies) assessed the impact of radiation therapy on cancer-related morbidity (e.g., progression to metastatic disease).

##### RCTs

ProtecT. Within the good-quality ProtecT trial, approximately one-third of men with screen-detected prostate cancer (n=545) were randomized to EBRT, and outcomes were compared to a group randomized to active surveillance (n=545). Patients receiving radiation therapy in ProtecT also received neoadjuvant ADT beginning 3 to 6 months prior to and during radiation therapy. At 10.0 years of median followup, randomization to EBRT was not associated with a statistically significant reduction in all-cause mortality compared with active surveillance (HR, 0.94 [95% CI, 0.65 to 1.36]). Prostate cancer mortality was also not significantly lower among men randomized to EBRT versus active surveillance (HR, 0.51 [95% CI, 0.15 to 1.69]). Furthermore, prostate cancer-specific survival remained above 98.8 percent in all study arms at a median followup of 10 years.

At 10.0 years median followup, 8.4 percent of men who were randomized to EBRT experienced clinical progression as compared to 20.6 percent of men randomized to active surveillance (HR, 0.39 [95% CI, 0.27 to 0.55]). Men who received radiation therapy were about half as likely to progress to metastatic disease (3.0 per 1,000 person years [95% CI, 1.9 to 4.9]) compared with men on active surveillance (6.3 per 1,000 person years [95% CI, 4.5 to 8.8]). Approximately 33 men with screen-detected localized prostate cancer would need to be treated with radiation therapy (with neoadjuvant androgen deprivation therapy) rather than active surveillance to avert one case of metastatic prostate cancer.

##### Cohort Studies

Seven cohort studies compared mortality outcomes among men with localized prostate cancer receiving RT vs conservative management (median n=3,450; followup duration, 3 to 13 years).^125,130,134,135,75,115,129^ In four of seven studies,^125,130,134,135^ RT (EBRT, brachytherapy, or unspecified modality) was associated with a statistically significant reduction in all-cause mortality (median HR, 0.62 [range, 0.40 to 0.81]). Among the four cohort studies^115,130,135^ that reported prostate cancer-specific mortality, RT was not associated with a statistically significant reduction in three studies,^75,115,130^ while brachytherapy was associated with statistically significantly reduced prostate cancer-specific mortality in the fourth (HR, 0.45 [95% CI, 0.23 to 0.87]).^135^ In the single study that presented separate hazard ratios for EBRT and brachytherapy,^135^ there was no statistically significant difference in prostate cancer survival at 7.0 years of median followup between the two modalities, but all-cause mortality was significantly lower (compared to a referent of no treatment) among men who received brachytherapy (HR 0.40 [95% CI, 0.32 to 0.52]) compared to men who received EBRT (HR, 0.63 [95% CI, 0.53 to 0.75]).

We did not identify any cohort studies that assessed the impact of RT on cancer-related morbidity (i.e., metastatic disease).

#### ADT

We found no RCTs comparing ADT with conservative management for localized or screen-detected prostate cancer. Three cohort studies^129,135,189^ evaluated risk of all-cause or prostate cancer-specific mortality among men with localized prostate cancer receiving ADT as compared to conservative management. We did not identify any studies that assessed the impact of ADT on cancer-related morbidity (i.e. bone pain from metastases or progression to advanced-stage cancer).

##### Cohort Studies

Three cohort studies^129,135,189^ of men with localized prostate cancer and median followup durations ranging from 5.0 to 15.0 years examined the association between ADT with all-cause and prostate cancer-specific mortality outcomes as compared with conservative management strategies. The largest and most recent study^189^ (n=66,717) was a fair-quality retrospective analysis of Medicare patients identified from SEER-Medicare linked records who received either ADT as primary therapy (n=25,125) or no therapy (n=41,592) during the first six months following diagnosis. In an instrumental variable analysis, ADT was not associated with any difference in prostate cancer-specific mortality (adjusted HR, 1.01 [95% CI, 0.90 to 1.14]) or all-cause mortality (adjusted HR, 1.04 [95% CI, 0.99–1.09]) compared to conservative management. Results from another fair-quality analysis of elderly men with localized prostate cancer^135^ (n=4,316) were mixed; men who received primary ADT as monotherapy were more likely to die of prostate cancer compared with no treatment (HR, 1.32 [95% CI, 1.01 to 1.73]), but were less likely to die overall (HR, 0.89 [95% CI, 0.80 to 0.98]). A multivariable analysis of men recruited from seven state registries (n=3,297) yielded no significant differences in all-cause mortality between men who received primary ADT as compared to those on watchful waiting.^129^

#### Cryotherapy

We did not identify any RCTs or cohort studies that assessed the impact of cryotherapy on all-cause mortality, prostate cancer-specific mortality, or morbidity.

#### HIFU

We did not identify any RCTs or cohort studies that assessed the impact of HIFU on all-cause mortality, prostate cancer-specific mortality, or morbidity.

## KQ3a Does the Effectiveness of These Treatment Approaches Vary Between a Priori Subgroups: Age, Race/Ethnicity, Family History, or Clinical Risk?

Below we summarize evidence from included studies on the differential impact of alternative treatment approaches among a priori subgroups. In the ProtecT trial,^121^ tests for significant interaction between patient and tumor characteristics (age, baseline PSA, Gleason score, and clinical stage T1c vs. T2) and treatment effects on prostate cancer mortality were all non-significant. Because prostate cancer survival exceeded 99 percent at 10 years followup in all patient and treatment strata, we do not discuss these ProtecT subgroup analyses further below.

### Age

#### Radical Prostatectomy

Two studies evaluated the differential impact of RP, compared with conservative management, on morbidity and mortality outcomes by age. In the PIVOT trial,^133^ no significant age-related differences in the association between RP and all-cause mortality were observed among men greater or less than age 65 years at diagnosis after a median followup of 12.7 years (Table 15). However, after a median followup of 13.4 years in the SPCG-4 trial,^117^ the risk of all-cause mortality for RP versus watchful waiting was significantly reduced among men younger than 65 years at diagnosis (RR, 0.50 [95% CI, 0.37 to 0.68]) but not significantly reduced among men aged 65 years and older at diagnosis (RR, 0.92 [95% CI, 0.73 to 1.18]). In both the PIVOT and SPCG-4 trials tests for interaction were not significant when assessing whether patient age at diagnosis modified the impact of prostatectomy on prostate cancer mortality or progression to metastatic disease.

Table 15 The Effect of Radical Prostatectomy Compared With Conservative Management^*^ on Prostate Cancer-Specific Morbidity and Mortality and All-Cause Mortality, by Subgroup and Risk Factor

Study Reference Quality Rating | Study Design Followup | Outcome | Age | Tumor Risk or Tumor Stage | Gleason Score | Other
PIVOT Wilt, 2017^74^ Wilt, 2012^133^ Good | RCT 12.7 years (median) | All-cause mortality | Age <65 years RP: 47.5% (58/122; 95% CI, 38.9 to 56.3) WW: 59.5% (78/131; 95% CI, 51.0 to 67.6) RR=0.80 (95% CI, 0.63 to 1.01) HR=0.84 (95% CI, 0.70 to 1.01) Age >65 years RP: 68.2% (165/242; 95% CI, 62.1 to 73.7) WW: 70.8% (167/236; 95% CI, 64.7 to 76.2) RR=0.96 (95% CI, 0.86 to 1.09) HR=0.88 (95% CI, 0.71 to 1.09) P=0.56 for test of interaction by age | Low risk RP: 55.4% (82/148; 95% CI, 47.4 to 63.2) WW: 56.1% (83/148; 95% CI, 48.0 to 63.8) RR=0.99 (95% CI, 0.81 to 1.21) HR=0.98 (95% CI, 0.72 to 1.33) Intermediate risk RP: 59.7% (77/129; 95% CI, 47.4 to 63.2) WW: 74.2% (89/120; 95% CI, 65.7 to 81.2) RR=0.80 (95% CI, 0.67 to 0.96) HR=0.68 (95% CI, 0.50 to 0.92) High risk RP:71.4% (55/77; 95% CI, 60.5 to 80.3) WW: 73.8% (59/80; 95% CI, 63.2 to 82.1) RR=0.97 (95% CI, 0.80 to 1.17) HR=0.78 (95% CI, 0.54 to 1.13) P=0.08 for test of interaction by tumor risk category | Gleason score <7 RP: 57.1% (145/254; 95% CI, 50.9 to 63.0) WW: 64.0% (167/261; 95% CI, 58.0 to 69.6) RR=0.95 (95% CI, 0.78 to 1.03) HR=0.0.82 (95% CI, 0.65 to 1.02) Gleason score ≥7 RP: 69.4% (68/98; 95% CI, 59.7 to 77.6 WW: 73.3% (63/86; 95% CI, 63.1 to 81.5) RR=0.95 (95% CI, 0.79 to 1.14) HR=0.83 (95% CI, 0.59 to 1.17) P=0.84for test of interaction by Gleason score | [underlined: Baseline PSA] ≤10 ng/mL RP: 58.8% (140/238; 95% CI, 52.5 to 64.9) WW: 62.7% (151.241; 95% CI, 56.4 to 68.5) RR=0.94 (95% CI, 0.81 to 1.08) >10 ng/mL RP: 65.9% (83/126; 95% CI, 57.2 to 73.6) WW: 74.4% (93/125; 95% CI, 66.1 to 81.2) RR=0.89 (95% CI, 0.75 to 1.04) P=0.06 for test of interaction by race/ethnicity [underlined: Race] White RP: 64.7% (150/232; 95% CI, 58.3 to 70.5) WW: 70.5% (155/220; 95% CI, 64.1 to 76.1) RR=0.92 (95% CI, 0.81 to 1.04) Black RP: 57.7% (64/111; 95% CI, 48.4 to 66.4) WW: 62.0% (75/121; 95% CI, 53.1 to 70.1) RR=0.93 (95% CI, 0.75 to 1.15) Other RP: 42.9% (9/21; 95% CI, 24.5 to 63.5) WW: 57.7% (15/26; 95% CI, 39.0 to 74.5) RR=0.74 (95% CI, 0.41 to 1.34) P=0.87 for test of interaction by race/ethnicity [underlined: Comorbidities] None (Charlson score=0) RP: 52.2% (117/206; 95% CI, 45.7 to 58.7) WW: 58.2% (128/206; 95% CI, 51.6 to 64.5) RR=0.90 (95% CI, 0.76 to 1.06) HR=0.84 (95% CI, 0.65-1.07) One or more (Charlson Score≥1) RP: 75.7% (106/155; 95% CI, 68.0 to 82.1) WW: 79.6% (117/158; 95% CI, 72.4 to 85.3) RR=0.95 (95% CI, 0.84 to 1.03) HR=0.85 (95% CI, 0.65-1.10) P=0.79 for test of interaction by comorbidity status
| | Prostate cancer-specific mortality | Age <65 years RP: 7.4% (9/122; 95% CI, 3.9 to 13.4) WW: 11.5% (15/131; 95% CI, 7.1 to 18.0) RR=0.64 (95% CI, 0.29 to 1.42) HR=0.63 (95% CI, 0.28 to 1.43) Age >65 years RP: 7.4% (18/242; 95% CI, 4.8 to 11.5) WW: 11.4% (27/236; 95% CI, 8.0 to 16.1) RR=0.65 (95% CI, 0.37 to 1.15) HR=0.63 (95% CI, 0.35 to 1.15) P=0.99 for test of interaction by age | Low risk RP: 4.1% (6/148; 95% CI, 1.9 to 8.6) WW: 5.4% (8/148; 95% CI, 2.8 to 10.3) RR=0.75 (95% CI, 0.27 to 2.11) HR=0.74 (95% CI, 0.26 to 2.13) Intermediate risk RP: 8.5% (11/129; 95% CI, 4.8 to 14.6) WW: 15.8% (19/120; 95% CI, 10.4 to 23.4) RR=0.54 (95% CI, 0.27 to 1.08) HR=0.53 (95% CI, 0.25 to 1.11) High risk RP: 13.0% (10/77; 95% CI, 7.2 to 22.3) WW: 18.8% (15/80; 95% CI, 11.7 to 28.7) RR=0.69 (95% CI, 0.33 to 1.45) HR=0.64 (95% CI, 0.29 to 1.41) P=0.89 for test of interaction by tumor risk category | Gleason score <7 RP: 4.7% (12/254; 95% CI, 2.7 to 8.1) WW: 7.7% (20/261; 95% CI, 5.0 to 11.5) RR=0.62 (95% CI, 0.31 to 1.23) HR=0.70 (95% CI, 0.37 to 1.32) Gleason score ≥7 RP: 15.3% (15/98; 95% CI, 9.5 to 23.7%) WW: 24.4% (21/86; 95% CI, 16.6 to 34.5) RR=0.63 (95% CI, 0.35 to 1.14) HR=0.54 (95% CI, 0.26 to 1.13) P=0.62 for test of interaction by Gleason score | [underlined: Race/Ethnicity] White: RP: 7.3% (18/232; 95% CI, 4.6 to 11.4) WW: 12.7% (28/220; 95% CI, 9.0 to 17.8) RR=0.58 (95% CI, 0.32 to 1.02) HR=0.55 (95% CI, 0.30 to 1.01) Black: RP:7.2% (8/111; 95% CI, 3.7 to 13.6) WW: 9.1% (11/121; 95% CI, 5.2 to 15.6) RR=0.79 (95% CI, 0.33 to 1.90) HR=0.78 (95% CI, 0.32 to 1.91) Other: RP:9.5%(2/21; 95% CI, 2.7 to 28.9) WW: 11.5% (3/26; 95% CI, 4.0 to 29.0) RR=0.83 (95% CI, 0.15 to 4.49) HR= 0.82 (95% CI, 0.14 to 4.65) P=0.49 for test of interaction by race/ethnicity [underlined: Comorbidities] None (Charlson score=0) RP: 8.5% (19/206; 95% CI, 5.5 to 12.9) WW: 11.4% (25/206; 95% CI, 7.8 to 16.2) RR=0.75 (95% CI, 0.42 to 1.32) HR=0.72 (95% CI, 0.40 to 1.11) One or more (Charlson Score≥1) RP: 5.7% (8/155; 95% CI, 2.9 to 10.9) WW: 11.6% (17/158; 95% CI, 7.4 to 17.7) RR=0.49 (95% CI, 0.22 to 1.11) HR=0.49 (95% CI, 0.21 to 1.13) P=0.44 for test of interaction by Gleason score [underlined: Baseline PSA] ≤10 RP: 6.7% (16/238; 95% CI, 4.2 to 10.6) WW: 9.5% (23/241; 95% CI, 6.4 to 13.9) RR=0.70 (95% CI, 0.38 to 1.30) HR=0.70 (95% CI 0.37 to 1.32) >10 RP: 8.7% (11/126; 95% CI, 4.9 to 15.0) WW: 15.2% (19/125; 95% CI, 10.0 to 22.5) RR=0.57 (95% CI, 0.29 to 1.16) HR=0.54 (95% CI 0.26 to 1.13) P=0.62 for test of interaction by tumor risk category
| | Bone metastases (at10y median followup) | Age <65 years RP: 5.7% (7/122; 95% CI, 2.8 to 11.4) WW: 9.9% (13/131; 95% CI, 5.9 to 16.2) RR=0.58 (95% CI, 0.24 to 1.40; p=0.19) Age >65 years RP: 4.1% (10/242; 95% CI, 2.3 to 7.4) WW: 11.0% (26/236; 95% CI, 7.6 to 15.7) RR=0.38 (95% CI, 0.19 to 0.76; p=0.002) | Low risk RP: 4.1% (6/148; 95% CI, 1.9 to 8.6) WW: 6.7% (9/148; 95% CI 3.2 to 11.2) RR=0.67 (95% CI, 0.24 to 1.38; p=0.39) Intermediate risk RP: 4.7% (6/129; 95% CI, 2.2 to 9.8) WW: 15.8% (19/120; 95% CI 10.4 to 23.4) RR=0.29 (95% CI, 0.12 to 0.71; p=0.002) High risk RP: 5.2% (4/77; 95% CI, 2.0 to 12.6) WW: 13.8% (11/80; 95% CI, 7.9 to 23.0) RR=0.38 (95% CI, 0.13 to 1.14; p=0.03) | Gleason score <7 RP: 3.5% (9/254; 95% CI, 1.9 to 6.6) WW: 8.1% (21/261; 95% CI, 5.3 to 12.0) RR=0.44 (95% CI, 0.21 to 0.94; p=0.02) Gleason score ≥7 RP:7.1% (7/98; 95% CI, 3.5 to 14.0%) WW: 20.9% (18/86; 95% CI, 13.7 to 30.7) RR=0.34 (95% CI, 0.15 to 0.78; p=0.003) | [underlined: Race/Ethnicity] White: RP: 5.2% (12/232; 95% CI 3.0 to 8.8) WW: 12.7% (28/220; 95% CI, 9.0 to 17.8) RR=0.41 (95% CI, 0.21 to 0.78; p=0.002) Black: RP: 2.7% (3/111; 95% CI 0.9 to 7.7) WW: 6.6% (8/121; 95% CI, 3.4 to 12.5) RR=0.41 (95% CI, 0.11 to 1.50; p=0.15) Other: RP:9.5% (2/21; 95% CI, 2.7 to 28.9) WW: 11.5% (3/26; 95% CI, 4.0 to 29.0) RR=0.83 (95% CI, 0.15 to 4.49; p=0.83) [underlined: Comorbidities] None (Charlson score=0) RP: 6.3% (14/206; 95% CI, 3.8 to 10.2) WW: 8.6% (19/206; 95% CI, 5.6 to 13.1) RR=0.51 (95% CI, 0.27 to 0.94; p=0.02) One or more (Charlson score ≥1) RP: 2.1% (3/155; 95% CI 0.7 to 6.1) WW: 8.2% (12/158; 95% CI, 4.7 to 13.7) RR=0.26 (95% CI, 0.08 to 0.91; p=0.02) [underlined: Baseline PSA] ≤10 RP: 5.0% (12/238; 95% CI, 2.9 to 8.6%) WW: 8.7% (21/241; 95% CI, 5.8 to 13.0%) RR=0.58 (95% CI, 0.29 to 1.15; p=0.09) >10 RP: 4.0% (5/126; 95% CI, 1.7 to 9.0%) WW: 14.4% (18/125; 95% CI, 9.3 to 21.6%) RR=0.28 (95% CI, 0.11 to 0.72; p=0.001)
ProtecT Hamdy, 2016^121^ Good | RCT 10.0 years (median) | Prostate cancer-specific mortality | Age <65 years RP: 0.5% (3/553) AS: 0.2% (1/545) Age ≥65 years RP: 0.4% (2/553) AS: 1.3% (7/545) | T1c RP: 0.5% (3/553) AS: 0.9% (5/545) T2 RP: 0.4% (2/553) AS: 0.6% (3/545) | Gleason score 6 RP: 0.5% (3/553) AS: 0.6% (3/545) Gleason score ≥7 RP: 0.4% (2/553) AS: 0.9% (5/545) | NR
Bill-Axelson, 2014^117^ SPCG-4 Good | RCT 13.4 years (median) | All-cause Mortality | Age <65 years RP: 40.0% (69/173; 95% CI, 32.7 to 49.0) WW: 65.6% (112/171; 95% CI, 58.2 to 73.9) RR=0.50 (95% CI, 0.37 to 0.68; p<0.001) Age ≥65 years RP: 69.8% (131/188; 95% CI, 63.1 to 77.4) WW: 71.7% (135/188; 95% CI, 64.9 to 79.3) RR=0.92 (95% CI, 0.73 to 1.18; p=0.52) | Low risk RP: 43.4% (51/118; 95% CI, 34.8 to 54.1) WW: 59.1% (85/144; 95% CI, 50.7 to 68.8) RR=0.57 (95% CI, 0.40 to 0.81; p=0.002) Intermediate risk RP: 57.1% (87/152; 95% CI, 49.0 to 66.4) WW: 72.5% (95/131; 95% CI, 64.5 to 81.6) RR=0.71 (95% CI, 0.53 to 0.95; p=0.02 High risk RP: 73.3% (62/85; 95% CI, 63.8 to 84.2) WW: 78.8% (67/85; 95% CI, 69.7 to 89.2) RR=0.84 (95% CI, 0.60 to 1.19; p=0.34) | NR | NR
Bill-Axelson, 2014^117^ SPCG-4 Good | RCT 13.4 years (median) | Prostate cancer-specific mortality | Age <65 years RP: 18.3% (31/169; 95% CI, 13.1 to 25.7) WW: 34.1% (58/170; 95% CI, 27.3 to 42.5) RR=0.45 (95% CI, 0.29 to 0.69; p=0.002) Age ≥65 years RP: 17.3% (32/185; 95% CI, 12.5 to 24.0) WW: 23.9% (41/172; 95% CI, 18.2 to 31.5) RR=0.75 (95% CI, 0.47 to 1.19; p=0.19) | Low risk RP: 10.2% (11/108; 95% CI, 5.8 to 18.0) WW: 14.0% (20/143; 95% CI, 9.1 to 21.5) RR=0.54 (95% CI, 0.26 to 1.13; p=0.17) Intermediate risk RP: 15.1% (24/159; 95% CI, 10.2 to 22.2) WW: 39.3% (50/127; 95% CI, 31.3 to 49.3) RR=0.38 (95% CI, 0.23 to 0.62; p<0.001) High risk RP: 33.1% (28/85; 95% CI, 24.0 to 45.7) WW: 35.7%(29/81; 95% CI, 26.3 to 48.5) RR=0.87 (95% CI, 0.52 to 1.46; p=0.84)
Bill-Axelson, 2014^117^ SPCG-4 Good | RCT 13.4 years (median) | Progression to metastatic disease | Age <65 years RP: 28.7% (45/157; 95% CI, 22.2 to 37.1) WW: 44.5% (76/171; 95% CI, 37.3 to 53.0) RR=0.49 (95% CI, 0.34 to 0.71; p<0.001) Age ≥65 years RP: 23.8% (44/185; 95% CI, 18.4 to 30.9) WW: 32.7% (62/190; 95% CI, 26.4 to 40.5) RR=0.68 (95% CI, 0.46 to 1.00; p=0.04) | Low risk RP: 13.6% (15/110; 95% CI, 8.4 to 21.9) WW: 24.2% (35/145; 95% CI, 17.8 to 33.0) RR=0.40 (95% CI, 0.21 to 0.73; p=0.006) Intermediate risk RP: 25.0% (37/148; 95% CI, 18.8 to 33.3) WW: 44.9% (59/131; 95% CI, 36.9 to 54.7) RR=0.49 (95% CI, 0.32 to 0.74; p<0.001) High risk RP: 45.9% (37/81; 95% CI, 35.8 to 58.8) WW: 50.8%(44/87; 95% CI, 40.6 to 63.5) RR=0.81 (95% CI, 0.52 to 1.26; p=0.39) | NR | NR
Sun, 2014^131^ Fair | Cohort 2-15 years (range) | All-cause Mortality | <10 years’ life expectancy HR=0.54 (95% CI, 0.39 to 0.75) > 10 years’ life expectancy HR=0.59 (95% CI; 0.49 to 0.71) | <10 years’ life expectancy ≤T1c:HR=0.31 (95% CI, 0.17 to 0.55) T2a/b: HR=0.60 (95% CI, 0.41 to 0.87) T2c: HR=0.35 (95% CI, 0.14 to 0.85) >10 years’ life expectancy ≤T1c:HR=0.56 (95% CI, 0.44 to 0.71) T2a/b: HR=0.67 (95% CI, 0.50 to 0.89) T2c: HR=0.41 (95% CI, 0.21 to 0.80) | NR | NR
Sun, 2014^131^ Fair | Cohort 2-15 years (range) | Prostate cancer-specific mortality | <10 years’ life expectancy HR=0.03 (95% CI, 0.02 to 0.42; p=0.01) ≥10 years’ life expectancy HR=0.36 (95% CI, 0.19 to 0.69; p=0.002) | <10 years’ life expectancy ≤T1c:HR=2.99 (95% CI, 0.10 to 86.80; p=0.5) T2a/b: HR=0.07 (95% CI, 0.02 to 0.83; p=0.04) T2c: NR ≥10 years’ life expectancy ≤T1c:HR=0.37 (95% CI, 0.19 to 0.69; p=0.04) T2a/b: HR=0.60 (95% CI, 0.21 to 1.73; p=0.4) T2c: HR=0.03 (95% CI, 0.003 to 0.20; p<0.001) | NR | NR
Stattin, 2010^130^ Fair | Cohort 8.2 years (median) | Prostate cancer-specific mortality | NR | Low risk RP: (0.3%) 4/3399 WW: (1.3%) 14/2021 Intermediate risk RP: (2.4%) 52/3399 WW: (4.7%) 442021 [underlined: 10-year Mortality] Low risk RP: 0.4% (95% CI, 0.13 to 0.97%) WW: 2.4% (95% CI, 1.2 to 4.1%) RR=0.29 (95% CI, 0.09 to 0.87) Intermediate risk RP: 3.4% (95% CI, 2.5 to 4.7%) WW: 5.2% (95% CI, 3.7 to 6.9%) RR=0.53 (95% CI, 0.35 to 0.80) | NR | NR

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: AS=active surveillance; HR=hazard ration; RP=radical prostatectomy; RR=relative risk; WW=watchful waiting

#### Radiation Therapy

One good-quality, propensity-adjusted analysis of elderly men identified in the linked SEER-Medicare database (n=68,797) observed that RT (compared to observation) was associated with a statistically significant reduction in prostate cancer mortality among men aged 75 to 80 years (HR, 0.70 [95% CI, 0.59 to 0.80]) but not among men aged 65 to 69 years (HR, 0.93 [95% CI, 0.72 to 1.19]; p=0.60) or 70 to 74 years (HR, 0.80 [95% CI, 0.68 to 1.03]; p=0.08).^114^

#### ADT

We found no studies that compared differential outcomes of ADT by patient age relative to a conservative management referent group.

### Race/Ethnicity

#### Radical Prostatectomy

In analyses for effect modification in the PIVOT trial, there was no evidence of differential impact of prostatectomy as compared to conservative management on study outcomes by race/ethnicity.^133^

#### Radiation Therapy and ADT

We found no studies assessing differential impact of radiation therapy or androgen deprivation therapy as compared with conservative management by racial/ethnic group.

### Family History

We did not identify any studies that assessed the variation of treatment-associated mortality and morbidity by patient family history.

### Clinical Risk Assessment

We assessed studies for evidence of differential impact of treatments by clinical risk assessment, considering pre-treatment factors such as tumor characteristics, clinical stage, baseline PSA, or a combination of these factors.

#### Radical Prostatectomy

Two trials evaluated the differential impact of RP, compared with conservative management, on morbidity and mortality outcomes by clinical risk (Table 15). Tests for interaction in the PIVOT trial^133^ by tumor risk category were not significant for the primary outcome of all-cause mortality (p=0.08), although men with intermediate risk tumors randomized to RP had significantly reduced all-cause mortality as compared to men randomized to observation (HR 0.68 [95% CI, 0.50 to 0.92]). However, tests for interaction between tumor risk category and prostate cancer mortality were not significant (p=0.89), and hazard ratios for prostate cancer mortality associated with RP did not differ significantly across tumor risk categories. A similar pattern was observed when comparing outcomes for men with baseline PSA ≤ 10 ng/mL versus PSA > 10 ng/mL, with all-cause mortality being statistically significantly reduced with RP only among men with baseline PSA > 10 ng/mL (HR, 0.73 [95% CI, 0.54 to 0.98]) but not among men with baseline PSA ≤ 10 ng/mL (HR, 0.91 [95% CI, 0.72 to 1.14]). Caution is warranted when interpreting these subgroup analyses due to the risk Type I error with multiple comparisons. In the SPCG-4 trial,^117^ a statistical test for difference in RP impact on prostate cancer mortality by tumor risk was not significant (p=0.07). No tests of interaction were reported for all-cause mortality or progression to metastases.

Two fair-quality cohorts performed subgroup analyses by clinical risk category for RP versus conservative management. In a fair-quality Swedish cohort study comparing outcomes of localized prostate cancer among men treated with RP or surveillance (n=6,849), relative risk reductions in prostate cancer-specific mortality associated with RP were not statistically significantly different between men with low risk tumors (RR, 0.29 [95% CI, 0.09 to 0.87]) and men with intermediate risk tumors (RR, 0.53 [95% CI, 0.35 to 0.80]).^130^ Similarly, a large, fair-quality SEER analysis (n=67,087) that stratified men by life expectancy of greater or less than ten years found that life expectancy did not seem to modify the association between RP and lower all-cause and prostate cancer mortality.^131^

#### Radiation Therapy

Two fair-quality cohort studies assessed whether prostate cancer mortality reductions associated with radiation therapy differed by either tumor risk or grade.^114,130^ In a stratified competing risks mortality analysis (n=68,797), RT was associated with significantly reduced prostate cancer mortality for men with high-risk tumors (HR, 0.59 [95% CI, 0.50 to 0.68]) but not for men with low or intermediate risk tumors.^114^ A smaller population-based cohort analysis of Swedish men who received RT or watchful waiting did not detect a significant difference in outcomes based on tumor risk.^130^

#### ADT

In an instrumental variable analyses from a good-quality cohort study of older U.S. men in SEER regions (n=66,717), primary ADT was not associated with significant differences in prostate cancer mortality or all-cause mortality either in men with moderately differentiated tumors (Gleason<7) or in men with poorly differentiated tumors (Gleason ≥7).^127^

No studies of ADT reported whether morbidity outcomes differed by tumor risk or grade.

## KQ4 What Are the Harms of the Various Treatment Approaches for Early-Stage or Screen-Detected Prostate Cancer?

Four RCTs (3 good-quality and 1 fair-quality)^70,71,74,126,132,133,136,147,148,166^ and 14 cohort studies (2 good- and 12 fair-quality)^75,76,139,145,149^–^152,154,156,158^–^161^ compared the harms of various active treatments to conservative management for early-stage or screen-detected prostate cancer (Figures 2–5; Tables 10, 11, and 20–26). These studies compared radical prostatectomy (RP), radiation therapy (RT), androgen deprivation therapy (ADT), or cryotherapy with conservative management (active surveillance [AS] or watchful waiting [WW]) or no treatment. In addition, we identified six fair-quality uncontrolled observational studies of RP^137,138,140,155,164,165^, one of RT,^157^ and seven of high-intensity focused ultrasound (HIFU)^141^–^143,146,153,162,163^ meeting inclusion criteria (Table 12).

Figure 2 Relative Risk of Urinary Incontinence After Radical Prostatectomy vs. Conservative Management* for Treatment of Localized Prostate Cancer

Note: Measurement of followup varied across studies; some studies reported mean/median followup, while others reported ranges or longest followup point.

*Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: CM=conservative management; RCT=randomized controlled trial; RR=relative risk

Figure 2 is a forest plot depicting the relative risk of urinary incontinence after radical prostatectomy for treatment of localized prostate cancer compared with conservative management approaches (i.e., watchful waiting or active surveillance).

Figure 3 Relative Risk of Erectile Dysfunction After Radical Prostatectomy vs. Conservative Management* for Treatment of Localized Prostate Cancer^†^

Note: Measurement of followup varied across studies; some studies reported mean/median followup, while others reported ranges or longest followup point.

*Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

†Data from Donovan et al. (in press) are the source of marked heterogeneity, potentially because of the crossover of many active surveillance patients to radical treatments during the six years of median followup. Excluding those data and pooling only data from Wilt (2012) and Johansson (2009) results in a RR=1.82 (95% CI, 1.62 to 2.04; I^2^=0.0%)

Abbreviations: CM=conservative management; RCT=randomized controlled trial; RR=relative risk

Figure 3 is a forest plot depicting the relative risk of erectile dysfunction after radical prostatectomy for treatment of localized prostate cancer compared with conservative management approaches (i.e., watchful waiting or active surveillance).

Figure 4 Relative Risk of Urinary Incontinence After Radiation Therapy vs. Conservative Management* for Treatment of Localized Prostate Cancer

Note: Measurement of followup varied across studies; some studies reported mean/median followup, while others reported ranges or longest followup point.

*Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: CM=conservative management; RCT=randomized controlled trial; RR=relative risk

Figure 4 is a forest plot depicting the relative risk of urinary incontinence after radiation therapy for treatment of localized prostate cancer compared with conservative management approaches (i.e., watchful waiting or active surveillance).

Figure 5 Relative Risk of Erectile Dysfunction After Radiation Therapy vs. Conservative Management for Treatment of Localized Prostate Cancer

Note: Measurement of followup varied across studies; some studies reported mean/median followup, while others reported ranges or longest followup point.

*Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: CM=conservative management; RCT=randomized controlled trial; RR=relative risk

Figure 5 is a forest plot depicting the relative risk of erectile dysfunction after radiation therapy for treatment of localized prostate cancer compared with conservative management approaches (i.e., watchful waiting or active surveillance).

Table 20 The Effect of Radical Prostatectomy Compared With Conservative Management^*^ on Urinary, Sexual, and Bowel Function and Other Physical Harms

Study Reference Quality Rating | Study Design Followup | Urinary Function | Sexual Function | Bowel Function
ProtecT Donovan, 2016^144^ Good | RCT 6.0 years | Use of one or more pads per day in the past 4 weeks RP: 17.4% (79/455) AS: 8.4% (38/453) | Erectile dysfunction characterized by patients as a “moderate or big problem” RP: 49.7% (227/457) AS: 39.8% (147/437) Erections not firm enough for intercourse RP: 83.5% (385/461) AS: 70.3% (318/452) | Fecal incontinence more than once per week: RP: 1.9% (9/468) AS: 2.6% (12/462) Loose stools about half the time or more frequently: RP: 12.2% (57/468) AS: 13.1% (61/466) Bloody stools about half the time or more frequently RP: 1.1% (5/470) AS: 1.3% (6/465)
PIVOT Wilt, 2012^133^ Good | RCT 2.0 years | Urinary incontinence characterized by patients as “have lots of problems with urinary dribbling,” “lose larger amounts of urine than dribbling but not all day,” “have no control over urine,” or “have an indwelling catheter” RP: 17.1% (49/287) WW: 6.3% (18/284) p<0.001 | Inability to have an erection or an erection sufficient for vaginal penetration RP: 81.1% (231/285) WW: 44.1% (124/281) p<0.001) | Bowel dysfunction characterized by patients as a “moderate” or “big” problem RP: 12.2% (35/286) WW: 11.3% (32/281) p=0.74
SPCG-4 Johansson, 2009^147^ Good | RCT 4.1 years (mean) 2 to 8 years (range) | Urinary incontinence 2 to 3 years RP: 42.3% (22/52) WW: 11.3% (6/53) RR=3.7 (95% C, 1.6 to 8.5) 4 to 5 years RP: 47% (26/55) WW: 28% (15/54) RR=1.7 (95% CI, 1.0 to 2.8) 6 to 8 years RP: 56% (31/55) WW: 25% (12/48) RR=2.3 (95% CI, 1.3 to 3.9) Overall RP: 48.8% (79/162) WW: 21.3% (33/155) RR=2.3 (95% CI, 1.6 to 3.2) | Erectile dysfunction2 to 3 years RP: 80.4% (41/51) WW: 37.3% (19/51) RR=2.2 (95% CI, 1.5 to 3.2) 4 to 5 years RP: 77.8% (42/54) WW: 42.6% (23/54) RR=1.8 (95% CI, 1.3 to 2.6) 6 to 8 years RP: 83.3% (45/54) WW: 54.7% (29/53) RR=1.5 (95% CI, 1.2 to 2.0) Overall RP: 80.5% (128/159) WW: 44.9% (71/158) RR=1.8 (95% CI, 1.5 to 2.2) | Fecal leakage 2 to 3 years RP: 1.9% (1/52) WW: 5.7% (3/53) RR=0.3 (95% CI, 0.04 to 3.2) 4 to 5 years RP: 0% (0/53) WW: 7.5% (4/53) 6 to 8 years RP: 0% (0/57) WW: 3.9% (2/51) Overall RP: 0.6% (1/162) WW: 5.7% (9/157)
Barocas, 2017^75^ Good | Cohort 3.3 years | Urinary leakage characterized by patients as a “moderate or big problem” Baseline RP: 7% (110/1523) AS: 5% (20/429) 6 months RP: 19% (268/1448) AS: 3% (13/411) OR=10.3 (95% CI, 5.8-18.1) 1 year RP: 15% (211/1425) AS: 4% (16/387) OR=6.0 (95% CI, 3.6-9.9) 3 years RP: 14% (175/1307) AS: 6% (20/349) OR=2.9 (95% CI, 1.8-4.7) | Erection insufficient for penetration Baseline RP: 39% (573/1523) AS: 41% (166/429) 6 months RP: 80% (1128/1448) AS: 43% (169/411) OR=12.6 (95% CI, 9.4-16.9) 1 year RP: 74% (1027/1425) AS: 41% (152/387) OR=7.6 (95% CI, 5.8-10.1) 3 years RP: 70% (893/1307) AS: 51% (168/349) OR=3.4 (95% CI, 2.5-4.6) | Bowel urgency characterized by patients as a moderate or big problem Baseline RP: 5% (72/1523) AS: 4% (16/429) 6 months RP: 3% (47/1448) AS: 4% (17/411) OR=1.1 (95% CI, 0.6-2.1) 1 year RP: 4% (50/1425) AS: 3% (13/387) OR=0.9 (95% CI,0.5-1.6) 3 years RP: 3% (34/1307) AS: 5% (18/349) OR=0.5 (95% CI, 0.3-0.9)
Chen, 2017^76^ Good | Cohort 2.0 years | Urinary obstruction and irritation characterized by patients as having at least 1 very distressful symptom RP: 17% (62/374) AS: 39% (86/222) Urinary incontinence characterized by patients as having at least 1 very distressful symptom RP: 16% (58/360) AS: 10% (21/206) | Poor sexual function characterized by patients as having at least 1 very distressful symptom RP: 76% (285/373) AS: 57% (130/227) | Poor bowel function characterized by patients as having at least 1 very distressful symptom RP: 10% (33/333) AS: 13% (26/198)
Smith, 2009^159^ Fair | Cohort 3.8 years | Urinary leakage that required one or more pads per day to control Baseline RP: 1.1% (11/981) AS: 6.0% (12/200) 3 years RP: 12.3% (111/981) AS: 3.4% (6/200) RR=3.7 (95% CI, 2.4 to 5.7) | Being unable to obtain an erection sufficient for sexual intercourse Baseline RP: 21.0% (206/981) AS: 26.5% (53/200) 3 years RP: 70.8% (695/981) AS: 47.0% (94/200) RR=1.5 (95% CI, 1.3 to 1.8) | Bowel dysfunction characterized by patients as a “moderate” or “big” problem Baseline RP: 4.4% (43/981) AS: 13.5% (27/200) 3 years RP: 3.3% (32/981) AS: 5.5% (11/200)
Hoffman, 2003^145^ Fair | Cohort 2.0 years | Urinary leakage once per week or less: RP: 27.2% (367/1373) WW: 14.9% (40/230) Urinary leakage daily or more often RP: 35.3% (484/1373) WW: 8.3% (19/230) RR=4.3 (95% CI, 2.8 to 6.6) | Some or a lot of erectile dysfunction RP: 25.7% (351/1373) WW: 34.2% (75/230) No erections at all RP: 58.4% (757/1373) WW: 32.5% (60/230); RR=2.1 (95% CI, 1.7 to 2.6) | Bowel urgency some days RP: 14.1% (201/1373) WW: 15.9% (38/230) Bowel urgency almost every day RP:0.9%(11/1373) WW: 0.2% (1/230)
Schapira, 2001^156^ Fair | Cohort 1.0 years | Use of≥1 pad per day for control of urine Baseline RP: 2.4% (1/42) AS: 0% (0/25) 3 Months RP: 73.8% (31/42) AS: 0% (0/27) 12 months RP: 43.2% (16/37) AS: 4.0% (1/25) RR=11.0 (95% CI, 1.6 to 7.8) | Not having an erection firm enough for sexual intercourse Baseline RP: 33.3% (14/42) AS: 64.0% (16/25) 3 Months RP: 100.0% (42/42) AS: 63.0% (17/27) 12 months RP: 89.2% (33/37) AS:68.0% (17/25)) RR=1.3(CI, 0.98 to 1.8) | NR
Siegal, 2001^158^ Fair | Cohort 4.3 years | NR | Erection insufficient for intercourse Pretreatment RP: 22.7% (89/392) WW: 45.3% (29/64) Posttreatment RP: 90.1% (53/392) WW: 62.5% (40/64) RR=1.4(CI, 1.2 to 1.8) | NR
Smith, 2000^160^ Fair | Cohort 3.8 years | Frequent dribbling Aged <70 years Pretreatment RP:3% WW: 5% 12 months RP:6% WW: 6% 18 months RP: 7% WW: 5% Aged ≥70 years Pretreatment RP: 4% WW: 6% 12 months RP: 11% WW: 6% 18 months RP: 7% WW: 4% No urinary control Aged <70 years Pretreatment RP: 0% WW: 0% 12 months RP: 1% WW: 0% 18 months RP: 1% WW: 0% Aged ≥70 years Pretreatment RP: 1% WW: 0% 12 months RP:1% WW: 0% 18 months RP: 1% WW: 0% | Not firm enough for sexual activity Aged <70 years Pretreatment RP: 9% WW:0 12 months RP: 18% WW: 13% 18 months RP: 17% WW: 27% Aged ≥70 years Pretreatment RP: 23% WW: 17% 12 months RP: 26% WW: 4% 18 months RP: 25% WW: 32% No erections at all Aged <70 years Pretreatment RP: 3% WW: 0% 12 months RP:33% WW: 0% 18 months RP: 32% WW: 0% Aged ≥70 years Pretreatment RP: 11% WW: 7% 12 months RP: 57% WW: 8% 18 months RP: 57% WW:11% | NR
Litwin, 1995^149^ Fair | Cohort 6.0 years | Occasional dribbling RP: 45% (42/94) WW:29%(18/63) Frequent dribbling RP: 11% (10/94) WW: 6% (4/63) No urinary control RP: 10% (9/94) WW: 3% (2/63) | Poor ability to function sexually during the last 4 weeks: RP: 12.5% (12/96) WW: 11.1% (7/63) Very poor ability to function sexually during the last 4 weeks: RP: 66.7% (64/96) WW: 38.1% (24/63) | Rectal urgency about once a week RP: 15.5% (15/97) WW: 9.5% (6/63) Rectal urgency more than once a week RP: 7.2% (7/97) WW: 4.8% (3/63) Rectal urgency about once a day RP: 9.3% (9/97) WW: 12.7% (8/63) Rectal urgency more than once a day RP: 4.1% (4/97) WW: 4.8% (3/63

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: AS=active surveillance; HR=hazard ration; RP=radical prostatectomy; RR=relative risk; WW=watchful waiting

Table 21 The Effect of Radiation Therapy Compared With Conservative Management^*^ on Urinary, Sexual, and Bowel Function and Other Physical Harms

Study Reference Quality Rating | Study Design Followup | Urinary Function | Sexual Function | Bowel Function
ProtecT Donovan, 2016^144^ Good | RCT 6.0 years | Use of one or more pads per day in the past 4 weeks RT: 3.5% (16/452) AS: 8.4% (38/453) | Erectile dysfunction characterized by patients as a “moderate or big problem” RT: 36.2% (162/447) AS: 39.8% (147/437) | Fecal incontinence more than once per week: RT: 4.1% (19/465) AS: 2.6% (12/462) Loose stools about half the time or more frequently: RT: 15.5% (72/466) AS: 13.1% (61/466) Bloody stools about half the time or more frequently RT: 5.6% (26/466) AS: 1.3% (6/465)
Fransson, 2001^70^ Fair | RCT 2.5 years (median) | Regular use of pads for urinary incontinence RT: 17.5% (10/59) WW: 2.0% (1/49) RR=8.3 (95% CI, 1.1 to 6.3) | NR | Use of sanitary shields for stool leakage RT: 8.6% (5/59) WW: 2.1% (1/49) P=0.346
Barocas, 2017^75^ Good | Cohort 3.3 years | Urinary leakage characterized by patients as a “moderate or big problem” Baseline RT: 4% (24/598) AS: 5% (20/429) 6 months RT: 5% (31/580 AS: 3% (13/411) OR=1.5 (95% CI, 0.8-3.0) 1 year RT: 6% (32/560) AS: 4% (16/387) OR=1.2 (95% CI, 0.6-2.3) 3 years RT: 5% 24/482) AS: 6% (20/349) OR=0.7 (95% CI, 0.4-1.2) | Erection insufficient for penetration Baseline RT: 56% (319/598) AS: 41% (166/429) 6 months RT: 71% (371/580) AS: 43% (169/411) OR=2.6 (95% CI, 1.9-3.5) 1 year RT: 72% (387/560) AS: 41% (152/387) OR=2.3 (95% CI, 1.7-3.2) 3 years RT: 71% (326/482) AS: 51% (168/349) OR=1.6 (95% CI, 1.1-2.3) | Bowel urgency characterized by patients as a moderate or big problem Baseline RT: 4% (21/598) AS: 4% (16/429) 6 months RT: 7% 43/580) AS: 4% (17/411) OR=2.5 (95% CI, 1.4-4.6) 1 year RT: 7% (40/560) AS: 3% (13/387) OR= 1.5 (95% CI, 0.8-2.8) 3 years RT: 7% (34/482) AS: 5% (18/349) OR=1.5 (95% CI, 0.8-2.9)
Chen, 2017^76^ Good | Cohort 2.0 years | Urinary obstruction and irritation characterized by patients as having at least 1 very distressful symptom BT: 37% (29/80) EBRT: 35% (65/187) AS: 39% (86/222) Urinary incontinence characterized by patients as having at least 1 very distressful symptom BT: 13% (10/77) EBRT: 9% (15/168) AS: 10% (21/206) | Poor sexual function characterized by patients as having at least 1 very distressful symptom BT: 62% (48/77) EBRT: 63% (120/189) AS: 57% (130/227) | Poor bowel function characterized by patients as having at least 1 very distressful symptom BT: 12% (9/72) EBRT: 19% (29/156) AS: 13% (26/198)
Shah, 2012^157^ Fair | Uncontrolled Observational 6.6 years (median) | Dysuria EBRT African American: NR White: NR Brachytherapy: African American: 34.4% White: 22.9% p=0.31 Urinary retention EBRT African American: 3.4% White: 10.4% p=0.60 Brachytherapy: African American: 19.2% White: 25.7% p=0.59 Urinary frequency/urgency EBRT African American: 24.1% White: 30.7% p=0.83 Brachytherapy: African American: 53.8% White: 54.8% p=0.80 Urinary incontinence EBRT African American: 6.7% White: 8.9% p<0.001 Brachytherapy: African American: 3.8% White: 8.7% p=0.82 Urinary stricture EBRT African American: 0% White: 2.6% p=0.68 Brachytherapy: African American: 0% White: 3.9% p=0.79 | NR | Diarrhea EBRT African American: 0% White: 5.9% p=0.61 Brachytherapy African American: 3.7% White: 7.5% p=0.89 Rectal pain/tenesmus EBRT African American: 3.4% White: 8.0% p=0.64 Brachytherapy African American: NR White: NR Rectal bleeding EBRT African American: 10.3% White: 17.8% p=0.74 Brachytherapy African American: NR White: NR
Thong, 2010^161^ Fair | Cohort 5 to 10 years | NR | Problem maintaining an erection occasionally RT: 6.7% (4/60) AS: 5.0% (3/60) Nearly Always RT: 71.6% (43/60) AS: 48.3% (29/60) Problem getting an erection Occasionally RT: 15.9% (10/63) AS: 8.3% (5/60) Nearly Always RT: 68.3% (43/63) AS: 46.7% (28/60) RR=1.5 (95% CI, 1.1 to 2.0) | NR
Smith, 2009^159^ Fair | Cohort 3.8 years (mean) | Urinary leakage that required one or more pads per day to control Baseline EBRT: 0% AS: 6.0% (12/200) 3 years EBRT: 2.4% (3/123) AS: 3.4% (6/200) RR=0.81 (95% CI, 0.21 to 3.2) | Being unable to obtain an erection sufficient for sexual intercourse Baseline EBRT: 28.4% (35/123) AS: 26.5% (53/200) 3 years EBRT: 58.5% (72/123) AS: 47.0% (94/200) RR=1.2 (95% CI, 1.0 to 1.5) | Bowel dysfunction characterized by patients as a “moderate” or “big” problem Baseline EBRT: 10.6% (13/123) AS: 13.5% (27/200) 3 years EBRT: 13.0% (16/123) AS: 5.5% (11/200)
Hoffman, 2003^145^ Fair | Cohort 2.0 years | Urinary leakage once per week or less RT: 22.2% (133/583) WW: 14.9% (40/230) Urinary leakage daily or more often RT: 12.2% (71/583) WW: 8.3% (19/230) RR=1.5 (95% CI, 0.91 to 2.39) | Some or a lot of erectile dysfunction RT: 34.3% (186/583) WW: 34.2% (75/230) No erections at all RT: 39.1% (228/583) WW: 26.1% (60/230) RR=1.5 (95% CI, 1.2 to 1.9) | Bowel urgency some days RT: 28.6% (168/583) WW: 15.9% (38/230) Bowel urgency almost every day RT: 3.2% (19/583) WW: 0.2% (1/230)
Schapira, 2001^156^ Fair | Cohort 1.0 years | Use of≥1 pad per day for control of urine Baseline RT: 4.5% (2/44) AS: 0% 3 Months RT: 9.3% (4/43) AS: 0% 12 months RT: 7.9% (3/38) AS: 4.0% (1/25) RR=2.0 (95% CI, 0.22 to 18.0) | Not having an erection firm enough for sexual intercourse Baseline RT: 68.2% (30/44) AS: 0% 3 Months RT: 76.7% (33/43) AS: 0% 12 months RT: 75.0% (30/40) AS: 68.0% (17/25) RR=1.1 (95% CI, 0.80 to 1.5) | NR
Siegel, 2001^158^ Fair | Cohort 4.3 years (median) | NR | Erection insufficient for intercourse Pretreatment RT: 38.9% (123/315) WW: 45.3% (29/64) Posttreatment (4.3 years) RT: 85.4% (269/315) WW: 62.5% (40/64) RR=1.4 (95% CI, 1.1 to 1.7) | NR
Smith, 2000^160^ Fair | Cohort 3.8 years | Frequent dribbling Aged <70 years Pretreatment RT: 4% WW: 5% 12 months RT: 2% WW: 6% 18 months RT: 2% WW: 5% Aged ≥70 years Pretreatment RT:1% WW: 6% 12 months RT: 7% WW: 6% 18 months RT: 7% WW: 4% No Control Aged <70 years Pretreatment RT: 0% WW: 0% 12 months RT: 0% WW: 0% 18 months RT: 0% WW: 0% Aged ≥70 years Pretreatment RT: 0% WW: 0% 12 months RT: 0% WW: 0% 18 months RT: 0% WW: 0% | Not firm enough for sexual activity Aged <70 years Pretreatment RT: 24% WW:0 12 months <70 years RT: 25% WW: 13% 18 months RT: 26% WW: 14% Aged ≥70 years Pretreatment RT: 24% WW: 17% 12 months RT: 35% WW: 27% 18 months RT: 36% WW: 32% No Erections at All Aged <70 years Pretreatment RT: 2% WW: 0% 12 months RT:21% WW: 0% 18 months RT:21% WW: 0% Aged ≥70 years Pretreatment RT: 18% WW: 7% 12 months RT: 36% WW: 8% 18 months RT: 40% WW: 11% | NR
Litwin, 1995b^149^ Fair | Cohort 6.0 years | Occasional urinary dribbling RT: 40.7% (22/54) WW: 28.6% (18/63) Frequent urinary dribbling RT: 5.6% (3/54) WW: 6.3% (4/63) No urinary control RT: 1.8% (1/54) WW: 3.2% (2/63) | Poor ability to function sexually during the last 4 weeks RT: 9.1% (5/55) WW: 11.1% (7/63) Very poor ability to function sexually during the last 4 weeks RT: 61.8% (34/55) WW: 38.1% (24/63) | Rectal urgency about once a week RT: 3.7% (2/54) WW: 9.5% (6/63) Rectal urgency more than once a week RT: 7.4% (4/54) WW: 4.8% (3/63) Rectal urgency about one a day RT: 5.6% (3/54) WW: 12.7% (8/63) Rectal urgency more than once a day RT: 16.7% (9/54) WW: 4.8% (3/63)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: AS=active surveillance; BT=brachytherapy; EBRT=external beam radiation therapy; HR=hazard ratio; RT=radiation therapy; RR=relative risk; WW=watchful waiting

Table 22 The Effect of Androgen Deprivation Therapy Compared With Conservative Management^*^ on Urinary, Sexual, and Bowel Function

Study Reference Quality Rating | Study Design Followup | Urinary Function | Sexual Function | Bowel Function
Smith, 2009^159^ Fair | Cohort 3.8 years (mean) | Urinary leakage that required one or more pads per day to control Baseline ADT: 6.6% (4/61) AS: 6.0% (12/200) 3 years ADT: 3.3% (2/61) AS: 3.4% (6/200) RR=1.1 (95% CI, 0.23 to 5.3) | Being unable to obtain an erection sufficient for sexual intercourse Baseline ADT: 39.3% (24/61) AS: 26.5% (53/200) 3 years ADT: 73.8% (45/61) AS: 47.0% (94/200) RR=1.6 (95% CI, 1.3 to 1.9) | Bowel dysfunction characterized by patients as a “moderate” or “big” problem Baseline ADT: 9.8% (6/61) AS: 13.5% (27/200) 3 years ADT: 6.4% (3/61) AS: 5.5% (11/200)
Hoffman, 2003^145^ Fair | Cohort 2.0 years | Urinary leakage once per week or less ADT: 29.2% (50/179) WW: 14.9% (40/230) Urinary leakage daily or more often ADT: 11.2% (20/179) WW: 8.3% (19/230) RR=1.4 (95% CI, 0.74 to 2.5) | Some or a lot of erectile dysfunction ADT: 8.1% (17/179) WW: 34.2% (75/230) No erections at all ADT: 85.8% (135/179) WW: 26.1% (60/230) RR=2.9 (95% CI, 2.3 to 3.6) | Bowel urgency some days ADT: 15.8% (30/179) WW: 15.9% (38/230) Bowel urgency almost every day ADT: 3.3% (7/179) WW: 0.2% (1/230)
Potosky, 2002^154^ Fair | Cohort 1.0 years | NR | Impotence ADT: 77.3% (68/88) WW: 26.9% (60/223) RR=2.9 (95% CI, 2.2 to 3.7) | NR
Smith, 2000^160^ Fair | Cohort 3.8 years | Frequent dribbling Aged >70 years Pretreatment ADT: 0% WW: 5% 12 months ADT: 0% WW: 6% 18 months ADT: 0% WW: 5% Aged ≥70 years Pretreatment ADT: 8% WW: 6% 12 months ADT:13% WW: 6% 18 months ADT: 13% WW: 4% No control Aged <70 years Pretreatment ADT: 0% WW: 0% 12 months ADT: 14% WW: 0% 18 months ADT: 17% WW: 0% Aged ≥70 years Pretreatment ADT: 0% WW: 0% 12 months ADT: 0% WW: 0% 18 months ADT: 0% WW: 0% | Not firm enough for sexual activity Aged >70 years Pretreatment ADT: 14% WW: 0% 12 months ADT: 43% WW: 13% 18 months ADT: 40% WW: 14% Aged ≥70 years Pretreatment ADT: 30% WW: 17% 12 months ADT: 18% WW: 4% 18 months ADT: 18% WW: 32% No erections at all Aged <70 years Pretreatment ADT:14% WW: 0% 12 months ADT:43% WW: 0% 18 months ADT: 40% WW: 0% Aged ≥70 years Pretreatment ADT: 18% WW: 7% 12 months ADT: 73% WW: 8% 18 months ADT: 71% WW: 11% | NR

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: ADT=androgen deprivation therapy; AS=active surveillance; HR=hazard ration; RR=relative risk; WW=watchful waiting

Table 23 The Effect of Cryotherapy Therapy Compared With Conservative Management^*^ on Urinary, Sexual, and Bowel Function

Study Reference Quality Rating | Study Design Followup | Urinary Function | Sexual Function | Bowel Function
Smith, 2000^160^ Fair | Cohort 3.8 years | Frequent dribbling Aged <70 years Pretreatment Cryotherapy: 0% WW: 6% 12 months Cryotherapy: 0% WW: 0% 18 months Cryotherapy: 0% WW: 5% Aged ≥70 years Pretreatment Cryotherapy: 0% WW: 2% 12 months Cryotherapy: 0% WW: 0% 18 months Cryotherapy: 0% WW: 4% No Control Aged <70 years Pretreatment Cryotherapy: 0% WW: 0% 12 months Cryotherapy: 0% WW: 0% 18 months Cryotherapy: 0% WW: 0% Aged ≥70 years Pretreatment Cryotherapy: 0% WW: 0% 12 months Cryotherapy: 0% WW: 0% 18 months Cryotherapy: 0% WW: 0% | Not firm enough for sexual activity Aged <70 years Pretreatment Cryotherapy: 20% WW: 0% 12 months Cryotherapy: 13% WW: 13% 18 months Cryotherapy: 0% WW: 14% Aged ≥70 years Pretreatment Cryotherapy: 25% WW: 18% 12 months Cryotherapy: 50% WW: 27% 18 months Cryotherapy: 0% WW: 32% No Erections at All Aged <70 years Pretreatment Cryotherapy: 0% WW: 0% 12 months Cryotherapy: 40% WW: 0% 18 months Cryotherapy: 33% WW: 0% Aged ≥70 years Pretreatment Cryotherapy: 25% WW: 7% 12 months Cryotherapy: 50% WW: 8% 18 months Cryotherapy: 100% WW: 11% | NR

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: AS=active surveillance; HR=hazard ration; RR=relative risk; WW=watchful waiting

Table 24 The Effect of High-Intensity Focused Ultrasound on Urinary, Sexual, and Bowel Function

Study Reference Quality Rating | Study Design Followup | Urinary Function | Sexual Function | Bowel Function
Uchida, 2015^163^ Fair | Uncontrolled observational study 47 to 108 months | Urinary incontinence 2.3% (21/918) Urethral stricture (19.7%) 181/981 Epididymitis (6.2%) 57/918 Rectourethral fistula (0.1%) 1/981 Bladder neck contracture (0.8%) 7/918 Acute pyelonephritis (0.3%) 3/918 | Erectile dysfunction 6-months: 57.5% (77/134) 1-year: 50.8% (65/128) 2-years: 34.9% (37/106) | NR
Crouzet, 2014^143^ Fair | Uncontrolled observational study 6.4 years (median) | Urinary incontinence (grade 1) 18.7% (187/1002) Urinary incontinence (grade 2 or 3) 5.0% (50/1002) Urinary tract infection 3.9% (39/1002) Acute urinary retention 7.6% (76/1002) Bladder outlet obstruction 16.6% (166/1002) Hematuria 5.5% (55/1002) Stenosis 9.0% (90/1002) Fistula 0.4% (4/1002) | NR | NR
Pfeiffer, 2012^153^ Fair | Uncontrolled observational study 5.8 years (median) | Urinary incontinence (grade 1) 26.5% (51/191) Urinary incontinence (grade 2 or 3) 7.3% (14/191) Recurrent urinary tract infection 26.5% (51/191) Rectourethral fistulas 1.6% (3/191) | NR | NR
Inoeu, 2011^146^ Fair | Uncontrolled observational study 6 to 24 months | Urinary incontinence (grade 1) 3 months: 10.8% (16/137) 6 months: 0.7% (1/137) Urethral stricture 6.8% (10/137) Urinary tract infection 4.1% (6/137) Acute epididymitis 2.7% (4/137) | Erectile dysfunction Post-treatment (among potent men pre-treatment): 37.3% (22/59) | NR
Blana, 2008^141^ Fair | Uncontrolled observational study 4.8 years (mean) | Urinary incontinence (grade 1) 6.1% (10/163) Urinary incontinence (grade 2 or 3) 1.8% (3/163) Bladder outlet obstruction 24.5% (40/163) Urinary tract infection 6.7% (11/163) | Erectile dysfunction Post-treatment (among potent men pre-treatment): 44.7% (34/76) | NR
Blana, 2004^142^ Fair | Uncontrolled observational study 23 months (mean) | Urinary incontinence (grade 1) 5.8% (8/137) Urinary incontinence (grade 2-3) 0% Urinary tract infection 4.4% (6/137) Rectourethral fistula 0.7% (1/137) Urethral obstruction 11.7% (16/137) | Erectile dysfunction Post-treatment (among potent men pre-treatment): 52.7% | NR
Thuroff, 2003^162^ Fair | Uncontrolled observational study 407 days (mean) | Urinary incontinence (grade 1) 10.9% (44/402) Urinary incontinence (grade 2 or 3) 4.5% (18/402) Urinary tract infection 14.0% (56/402) Urethrorectal fistula 1.2% (5/402) | Erectile dysfunction 8.7% (35/402) | NR

Table 25 Surgical Complications and Mortality Associated With Radical Prostatectomy

Study Reference Quality Rating | Study Design Followup | Surgical Complications | Surgical Mortality
ProtecT Hamdy, 2016^121^ Good | RCT 90-days | Blood transfusion: 2.5% (14/553) Thromboembolic or cardiovascular events: 1.6% (9/553) Requiring intervention for anastomotic problems: 1.6% (9/553) Rectal injury: 0.18% (1/553) | 0% (0/5553)
PIVOT Wilt, 2012^133^ Good | RCT 30-days | Any complication: 21.4% (60/280) Wound infection: 4.3% (12/280) Urinary tract infection: 2.5% (7/280) Additional surgical repair: 2.5% (7/280) Bleeding requiring transfusion: 2.1% (6/280) Urinary catheter present > 30 days after surgery: 2.1 % (6/280) Sepsis: 1.1% (3/280) Bowel injury requiring surgical repair: 1.1% (3/280) Myocardial infarction: 1.1% (3/280) Deep vein thrombosis: 0.7% (2/280) Pneumonia: 0.7% (2/280) Stroke: 0.4% (1/280) Pulmonary embolism: 0.7% (2/280) Renal failure or dialysis: 0.4% (1/280) Other event: 10.0% (28/280) | 0.4% (1/280)
Bjorklund, 2016^140^ Fair | Uncontrolled observational study 90-days | NR | 0.17% (39/22344) Age at surgery (per 1-year increase): OR=1.07 (95% CI, 1.00 to 1.13) Comorbidity: 0=reference 1: OR=1.02 (95% CI, 0.31 to 3.36) ≥2: OR=2.23 (95% CI, 0.77 to 6.40) Tumor risk: Low risk=reference Intermediate risk: OR=1.23 (95% CI, 0.55 to 2.74) High risk: OR=2.89 (1.18 to 7.06)
Rabbani, 2010^155^ Fair | Uncontrolled observational study 37 months | [underlined: Open retropublic radical prostatectomy] Any complication: 27.5% (950/3458) Early complications (<30 days) Hypotension: 0.4% (14/3458) Respiratory distress: 0.2% (7/3458) Acute renal insufficiency: 0.2% (7/3458) Lymphocele: 0.8% (28/3458) Rectal or bowel injury: 0.7% (24/3458) Hematoma: 0.5% (17/3458) Intermediate complications (31-90 days) Sepsis: 0.03% (1/3458) Bladder neck contracture: 2.3% (80/3458) Urethral stricture: 0.6% (21/3458) Urinary retention: 0.4% (14/3458) Late complications (>90 days) Cerebrovascular accident or transient ischemic attack: 0.09% (3/3458) Acute renal insufficiency: 0.03% (1/3458) Bladder neck contracture: 2.8% (97/3458) Inguinal hernia: 1.2% (41/3458) Urethral stricture: 0.4% (14/3458) [underlined: Laparoscopic radical prostatectomy] Any complication 39.0% (442/1134) Early complications (<30 days) Hypotension: 0.5% (6/1134) PE: 0.4% (5/1134) MI/ischemia: 0.3% (3/1134) Urinoma/urine leak: 1.3%(15/1134) Lymphocele: 1.1% (12/1134) Abscess: 1.1% (12/1134) Intermediate complications (31-90 days) Lymphocele: 1.1% (5/1134) Incisional hernia: 0.2% (2/1134) Urethral stricture: 0.2% (2/1134) Late complications (>90 days) Incisional hernia: 1.1%(12/1134) Bladder neck contracture:0.7% (8/1134) Inguinal hernia: 0.5%(6/1134) [underlined: Hazard ratios] Risk of any medical complication, RP vs. LP: HR=1.9 (95% CI, 1.5 to 2.4; p<0.001) Risk of any surgical complication, RP vs. LP: HR=1.6 (95% CI, 1.3 to 1.9; p<0.001) Risk of complication according to race, black vs. white: HR=1.4 (95% CI, 1.0 to 2.0; p=0.027) | 0.13% (6/4592)
Walz, 2008^164^ Fair | Uncontrolled observational study 30-days | NR | 0.52% (48/9208) Age ≥69 years: 0.33% <69 years: 1.19% OR=3.1 (p<0.001) Comorbidity None: 0.23% One: 0.80% OR=3.0 (p=0.002)
Alibhai, 2005^137^ Fair | Uncontrolled observational study 30-days | Genitourinary: 7.53% (829/11010) Wound: 5.04% (555/11010) Misc. Surgical: 5.23% (576/11010) Misc. Medical: 3.88% (427/11010) Cardiac: 2.81% (309/11010) Respiratory: 2.66% (293/11010) Vascular: 1.95% (215/11010) | 0.48% (53/11,010) Age: <60 years: 0.19% (6/3199) 60 to 69 years: 0.58% (38/6587) 70 to 79 years: 0.66% (8/1217)
Augustin, 2003^138^ Fair | Uncontrolled observational study 30-days | Any adverse event: 19.9% (247/1243) Major complication: 4.0% (50/1243) Readmission due to major complication: 0.6% (8/1243) Minor complications: 15.8% (197/1243) Any intraoperative AE: 0.7% (9/1243); - AV blockage: 0.1% (1/1243); - Orturator nerve injury: 0.1% (1/1243); - Rectal injury: 0.2% (3/1243); - Ureteral injury: 0.1 % (4/1243); Any postoperative AE: 4% (51/1243); - Arrhythmia: 0.2% (2/1243); - CHF: 0.2% (3/1243); - MI: 0.1% (1/1243); - Myocardial ischemia: 0.1% (1/1243); - Severe hypotension: 0.1% (1/1243); - Deep vein thrombosis: 1.0% (12/1243); - Pulmonary embolism: 0.2% (2/1243); - Acute renal insufficiency: 0.2% (2/1243); - Sepsis: 0.2% (3/1243); - Wound infection: 0.1% (1/1243); - Postoperative bleeding: 0.2% (3/1243) | 0% (0/1243)
Yao, 1999^165^ Fair | Uncontrolled observational study 30-days | Serious cardiac event: 3% Serious pulmonary event: 6%; - Pulmonary embolism: 0.4%; - Deep vein thrombosis: 0.05%; Serious wound: 0.7% Serious surgical complication: 0.8% | 0.5%

Abbreviations: AE=adverse event; AV=atrioventricular; CHF=congestive heart failure; HR=hazard ratio; MI=myocardial infarction; OR=odds ratio; PE=pulmonary embolism

Table 26 Summary of Cohort Study-Based UCLA-PCI and SF-36 Scores for Radical Prostatectomy, Radiation Therapy, and Androgen Deprivation Therapy Compared With Conservative Management^*^

Scale | Measure | Radical Prostatectomy | | Radiation Therapy | | Androgen Deprivation Therapy
Scale | Measure | Number of Studies (References) | Median Difference in Mean Scores (Range)^†^ | Number of Studies (References) | Median Difference in Mean Scores (Range)^†^ | Number of Studies (References) | Median Difference in Mean Scores (Range)^†^
UCLA-PCI | Urinary function | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^160^) | −17.0 (−30.0 to −6.0) | 7(^139,^ ^150,^ ^152,^ ^156,^ ^159^–^161^) | −3.3 (−6.0 to 7.2) | 3(^138,^ ^159,^ ^160^) | −4.0 (−9.0 to 1.2)
UCLA-PCI | Urinary bother | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^160^) | −7.0 (−17.0 to 0.7) | 7(^139,^ ^150,^ ^152,^ ^156,^ ^159^–^161^) | −4.5 (−18.5 to 0.3) | 3(^138,^ ^159,^ ^160^) | −10.7 (−17.0 to −5.0)
UCLA-PCI | Sexual function | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^160^) | −22.0 (−35.0 to −2.0) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^160^) | −12.1 (−20.0 to 9.9) | 3(^138,^ ^159,^ ^160^) | −31.0 (−35.8 to −29.0)
UCLA-PCI | Sexual bother | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^160^) | −24.0 (−35.0 to 21.8) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^160^) | −8.0 (−23.0 to 7.5) | 3(^138,^ ^159,^ ^160^) | −15.0 (−20.0 to 0.6)
UCLA-PCI | Bowel function | 5(^139,^ ^150,^ ^152,^ ^156,^ ^159^) | 0.2 (0.5 to 2.0) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^161^) | −6.0 (−11.0 to 2.1) | 2(^139,^ ^159^) | NA (−10.0 to −4.6)
UCLA-PCI | Bowel bother | 5(^139,^ ^150,^ ^152,^ ^156,^ ^159^) | 1.1 (−5.0 to 5.0) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^159,^ ^161^ | −8.3 (−17.0 to 3.0) | 2(^139,^ ^159^) | NA (−6.0 to −0.9)
SF-36 | Physical component summary score | 2(^139,^ ^159^) | NA (1.8 to 3.2) | 3(^139,^ ^159,^ ^161^) | 0.8 (−3.0 to 2.1) | 2(^139,^ ^159^) | NA (−8.1 to −3.0)
SF-36 | Mental component summary score | 2(^139,^ ^159^) | NA (0.0 to 0.6) | 3(^139,^ ^159,^ ^161^) | −0.6 (−1.6 to 0.9) | 2(^139,^ ^159^) | NA (−3.0 to 0.1)
SF-36 | Physical function | 6(^75,^ ^139,^ ^150,^ ^152,^ ^156,^ ^160^) | 8.6 (2.0 to 16.8) | 7(^75,^ ^139,^ ^150,^ ^152,^ ^156,^ ^160,^ ^161^) | −7.4 (−18.0 to 11.0) | 2(^139,^ ^159^) | NA (−13.0 to −3.0)
SF-36 | Physical role function | 5(^139,^ ^150,^ ^152,^ ^156,^ ^160^) | 5.3 (−2.0 to 9.5) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^160,^ ^161^) | −7.4 (−22.0 to 0.4) | 3(^139,^ ^154,^ ^160^) | −11.0 (−23.0 to −11.0)
SF-36 | Bodily pain | 5(^139,^ ^150,^ ^152,^ ^156,^ ^160^) | 4.0 (−5.0 to 10.0) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^160,^ ^161^) | −2.0 (−7.0 to 0.5) | 3(^139,^ ^154,^ ^160^) | −6.0 (−8.0 to −1.0)
SF-36 | General health | 5(^139,^ ^150,^ ^152,^ ^156,^ ^160^) | 5.0 (2.2 to 20.8) | 6(^139,^ ^150,^ ^152,^ ^156,^ ^160,^ ^161^) | 1.0 (−9.2 to 7.0) | 2(^139,^ ^159^) | NA (−5.0 to −2.0)
SF-36 | Vitality | 7(^75,^ ^139,^ ^150^–^152,^ ^156,^ ^160^) | 4.5 (−2.0 to 13.8) | 7(^75,^ ^139,^ ^150^–^152,^ ^156,^ ^160,^ ^161^) | −3.0 (−5.0 to 7.0) | 3(^139,^ ^154,^ ^160^) | −7.0 (−7.0 to −7.0)
SF-36 | Social function | 6(^139,^ ^150^–^152,^ ^156,^ ^160^) | 2.0 (−2.0 to 11.0) | 6(^139,^ ^150^–^152,^ ^156,^ ^160,^ ^161^) | −0.5 (−27.1 to 5.0) | 2(^139,^ ^159^) | NA (−10.0 to −4.0)
SF-36 | Emotional role function | 7(^75,^ ^139,^ ^150^–^152,^ ^156,^ ^160^) | 4.7 (−5.0 to 12.8) | 7(^75,^ ^139,^ ^150^–^152,^ ^156,^ ^160,^ ^161^) | −0.4 (−8.0 to 18.2) | 3(^139,^ ^154,^ ^160^) | −15.0 (−16.0 to −3.0)
SF-36 | Mental health | 6(^139,^ ^150^–^152,^ ^156,^ ^160^) | 0.0 (−4.0 to 10.1) | 6(^139,^ ^150^–^152,^ ^156,^ ^160,^ ^161^) | 0.5 (−6.0 to 1.7) | 3(^139,^ ^154,^ ^160^) | −4.0 (−6.0 to 0.0)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

† Differences of 5 to 10 points are generally thought to indicate clinically meaningful changes (Litwin et al, 1998).

Table 27 Study Characteristics, Discrimination, and Calibration of Externally Validated Prostate Cancer Risk Calculators for Significant Prostate Cancer^*^

Reference | Risk Calculator | Setting and Sample | Discrimination | | Calibration | Comments
Reference | Risk Calculator | Setting and Sample | AUC With PSA Alone | AUC With Risk Calculator | Calibration | Comments
Maruf, 2017^78^ | PCPT (v2.0) | 595 men with no prior prostate cancer diagnosis undergoing fusion-guided and standard biopsy at a single U.S. center; 139 men (23.4%) with significant prostate cancer on standard biopsy | NR | 0.71 (predicting significant cancer on standard biopsy) | Underestimated actual risk of significant cancer when estimated risks were 18% to 50%. | High-risk referral cohort with family history of prostate cancer in 29% and prior biopsy in 70%.
Park, 2017^79^ | PCPT (v2.0) | 2,313 Asian men undergoing biopsy at an academic medical center in South Korea; 614 (26.5%) with significant prostate cancer | NR | 0.79 (95% CI, 0.77 to 0.81) | Overestimated actual risk of significant cancer across except when predicted risk was < 10% | At a threshold probability of significant cancer for biopsy of 7%, calculator use would avert 19.5% of biopsies but result in missed diagnosis of 6.4% of significant cancers.
Foley, 2016^167^ | PCPT (v2.0) | 2,001 men undergoing biopsy at 6 Irish tertiary referral centers; 699 men (35%) with significant cancer | NR | 0.69 (95% CI, 0.67 to 0.72) | Underestimated actual risk across range of predicted risks | Decision curve analyses suggest that harms of false-positives would outweigh potential benefits in this high-risk referral population.
Poyet, 2016^168^ | PCPT (v2.0) | 1,996 men undergoing core biopsy in Switzerland academic center; 226 men (11%) with significant prostate cancer | 0.65^†^ | 0.70 | Good calibration below 20% pre-biopsy risk; slightly overestimated risk from 20% to 40% risk | Decision curve analysis suggests true-positives would outweigh false-positives in men with a 8% to 40% pre-biopsy risk of significant cancer.
Lundon, 2015^169^ | PCPT (v1.0) | 556 men undergoing biopsy at single Irish referral centers, 190 (34%) with significant prostate cancer | NR. | 0.79 | Good calibration for Gleason ≥7 cancers | Decision curve analyses suggest benefits of true-positives would slightly outweigh harms of false-positives for men with intermediate pre-biopsy risk. High prevalence of cancer in this referral population.
Ankerst, 2014^170^ Ankerst, 2014^171^ | PCPT (v2.0) | Development of PTPC 2.0 (n=6664 biopsies in 5,826 men) 10 external biopsy cohorts from Europe and U.S. (n=25,449 biopsies for AUC; n=25,512 biopsies for calibration) | NR | 0.75 (median across 11 cohorts) Range: 0.62–0.88 | Calibration mixed (poor in some cohorts, adequate in others) | Mixed results in decision curve analyses. Due to sample sizes, number of cohorts, and cohort diversity, provides broad perspective on calculator performance.
Roobol, 2012^172^ | PCPT (v1.0) | ERSPC Rotterdam (n=322 men referred for biopsy during later screening rounds) | 0.68 (95% CI: 0.57–0.78) | 0.72 (95% CI, 0.61–0.82) | NR | Small sample size. Larger ERSPC biopsy cohorts included in Ankerst, 2014.
Nam, 2011^173^ | PCPT (v1.0) | 2130 men undergoing biopsy at 5 Canadian centers; 18.9% diagnosed with significant cancer | NR | 0.67 (95% CI, 0.64 to 0.70) | Fair-to-good calibration in men with pre-biopsy predicted risk from 5% to 40% | Decision curve analyses suggest benefits of true-positives would outweigh harms of false-positives among men with 15–50% threshold probabilities.
Ngo, 2011^174^ | PCPT (v1.0) | 636 men undergoing biopsy at single U.S. academic center; 34.9% with significant cancer | NR | 0.51 | NR | High-risk referral population.
Trottier, 2011^175^ | PCPT (v1.0) | 982 men undergoing biopsy at single Canadian center; 225 (22.9%) with high-grade disease (defined as Gleason score ≥4) | 0.61** (95% CI, 0.47 to 0.76) | 0.68** (95% CI, 0.65 to 0.72) | Good calibration across the range of predicted risks. | Definition of high-grade included lower-grade cancers than other studies.
Nguyen, 2010^176^ | PCPT (v1.0) | 3,482 men undergoing 4,515 biopsies at U.S. academic center; 23.3% with significant cancer | 0.56 | 0.60 (95% CI, 0.58 to 0.62) | Overestimated risk at low predicted risk; underestimated risk at high predicted risk
Hernandez, 2009^177^ | PCPT (v1.0) | 1,108 men enrolled in a multicenter trial undergoing biopsy; 14% with significant cancer | 0.71 | 0.74 | NR
Foley, 2016^167^ | ERSPC | 2,001 Irish men undergoing biopsy at 6 tertiary referral centers; 699 (35%) with significant cancer | NR | 0.74^†^ (95% CI, 0.72 to 0.76) | Underestimated actual risk across broad range of pre-test risks | In decision curve analyses, harms of false-positives would outweigh benefits of true-positives in this sample. Used TRUS volume estimates. High-risk referral population.
Gomez-Gomez, 2016^77^ | ERSPC | 749 men undergoing biopsy at a single Spanish center; 133 (17.8%) with significant cancer | NR | 0.74 (95% CI, 0.70 to 0.79) | Acceptable calibration below 25% predicted risk of high-grade cancer | Decision curve analyses suggest benefit of true-positives would outweigh harms of false-positives above a threshold probability of 9% for biopsy.
Park, 2017^79^ | ERSPC | 2,313 Asian men undergoing biopsy at an academic medical center in South Korea; 614 (26.5%) with significant prostate cancer | NR | 0.83 (95% CI, 0.81 to 0.85) | Good calibration across range of predicted risks | At a threshold probability of significant cancer for biopsy of 7%, use of the ERSPC calculator would avert 37% of biopsies but result in missed diagnosis of 10.3% of significant cancers.
Poyet, 2016^168^ | ERSPC | 1,996 men undergoing core biopsy in Switzerland academic center; 226 (11%) with significant prostate cancer | 0.65^†^ | 0.73^†^ | Underestimated at low calculated risk and over estimated at high calculated risk for Gleason ≥7 cancers | Used TRUS estimated volume rather than DRE. Decision curve analysis suggests benefits of true-positives would outweigh harms of false-positives in men with a 8% to 40% pre-biopsy risk of significant cancer.
Lundon, 2015^169^ | ERSPC RC3 | 556 Irish men undergoing biopsy at single referral center; 190 (34%) with significant prostate cancer | NR | 0.69^*^ | Good calibration across entire risk range | Used TRUS estimated prostate volume, rather than DRE. Decision curve analyses suggest benefits of true-positives and harms of false-positives closely balanced. High cancer prevalence in this referral population
Roobol, 2012^172^ | ERSPC | ERSPC Rotterdam (n=3,624 for development sample; n=322 for validation sample in later screening rounds) | 0.68^†^ (95% CI, 0.57 to 0.78) | 0.78^†^ (95% CI, 0.69 to 0.87) | NR | Development and validation samples from same clinical trial population. TRUS volume estimates used in development (rather than DRE).
Trottier, 2011^175^ | ERSPC | 982 men undergoing biopsy at single Canadian center; 225 (22.9%) with high-grade disease (defined as Gleason ≥4) | 0.61 (95% CI, 0.47 to 0.76) | 0.78 (95% CI, 0.74 to 0.81) | NR | Definition of high-grade included lower-grade cancers than other studies.

* Significant prostate cancer is defined as Gleason score >7 or stage T2b or higher

† Results given for validation sample

Abbreviations: AUC=area under the curve; ERSPC=European Randomized Study of Screening for Prostate Cancer; NR=not reported; PCPT=Prostate Cancer Prevention Trial; TRUS=transrectal ultrasound

Table 12 Study Characteristics of Uncontrolled Observational Studies of Prostate Cancer Treatment Harms

Study Reference Quality Rating | Study Location Recruitment | Followup | Interventions (n) | Participant and Tumor Characteristics
Bjorklund, 2016^140^ Fair | Sweden Men were identified in the National Prostate Cancer Register of Sweden | 3-months | Radical prostatectomy (n=22,344; [RRP=14820; RARP=7524]) | Age (median): 63.6 years Tumor Risk Low: 43% (9598/22344) Intermediate: 44% (9793/22344) High: 13% (2953/22344)
Uchida, 2015^163^ Fair | Japan Men were recruited from a clinical cohort of patients receiving HIFU at a single institution | 3.9 to 9.0 years (range) | HIFU(n=918) | Age (median): 68 years
Crouzet, 2014^143^ Fair | France Men were recruited from a single site | 6.4 years (median) | HIFU (n=1,002) | Age (median): 71 years Age (range): 48 to 87 years Tumor Risk: Low: 35.6% (357/1002) Intermediate: 45.1% (452/1002) High: 17.4% (174/1002) Undefined: 1.9% (19/1002) Tumor Stage T1: 51.7% (518/1002) T2: 44.8% (449/1002) T3: 2.8% (28/1002) Undefined: 0.7% (7/1002) Gleason Score: ≤6: 55.4% (555/1002) 7: 34.7% (348/1002) ≥8: 8.4% (84/1002) Undefined: 1.5% (15/1002)
Pfeiffer, 2012^153^ Fair | Germany Men were recruited at a single clinical institution among those who received HIFU as a first-line curative therapy | 4.4 years (median) | HIFU(n=191) | Age (median): 69.7 years Age (range): 51 to 82 years Tumor Risk: Low: 37.7% (72/191) Intermediate: 34.6% (66/191) High: 27.7% (53/191) Tumor Stage: T1a/b: 19.4% (37/191) T1c: 35.6% (68/191) T2a: 18.9% (36/191) T2b: 13.1% (25/191) T2c: 7.8% (15/191) cT3a-cT3b: 5.2% (10/191)
Shah, 2012^157^ Fair | United States Men treated at a single institution | 6.6 years (median) | Radiation therapy (n=3180 [EBRT=1154;ART=1036; brachytherapy=540; combined EBRT/HDR=450]) | Age (median): 71 years Age (range): 40 to 92 years Race/Ethnicity White: 91.6% (2912/3180) African American: 8.4% (268/3180) Tumor Stage: T1a to T1c: 46% (1461/3180) T2a to T2c: 50% (1568/3180) T3a to T3c: 4% (141/3180) Gleason Score <7: 60% (1898/3180) ≥7:40% (1266/3180)
Inoeu, 2011^146^ Fair | Japan Men were recruited from population of patients undergoing HIFU at Takanobashi Central Hospital | 3.0 years (mean) | HIFU(n=137) | Age (median): 70 years Age range: 50 to 82 years Tumor risk: Low: 21% (29/137) Intermediate: 50% (68/137) High: 29% (40/137) Tumor stage: T1b:6%(8/137) T1c: 42% (58/137) T2a: 38% (52/137) T2b: 10% (14/137) T2c:4%(5/137) Gleason score: ≤6: 30% (41/137) 7: 47% (64/137) ≥7: 23% (32/137)
Rabbani, 2010^155^ Fair | United States Men were identified from a single institution | 37 months | Radical prostatectomy (n=4592) | Age (mean): 60 years Age (range): 55 to 64 years Race/ethnicity: White: 89% (4067/4592) Black: 7% (317/4592) Other/unknown: 4% (208/4592) Tumor stage: T1: 62% (2864/4592) T2: 34% (1571/4592) T3: 3% (150/4592) Tx:<1% (7/4592)
Blana, 2008^141^ Fair | Germany Men were identified from a single institution | 4.8 years (mean) 3.0 to 8.6 years (range) | HIFU(n=163) | Age (mean): 66 years Tumor stage: T1: 24% (39/163) T2: 76% (124/163)
Walz, 2008^164^ Fair | Canada Men were identified in the Quebec Health Plan database | 1.0 month | Radical prostatectomy (n=9208) | Age (mean): 65 years Age (range): 45 to 89 years
Alibhai, 2005^137^ Fair | Canada Men were identified in the Ontario Cancer Registry | 1.0 month | Radical prostatectomy (n=11,010) | Age (mean): 63 years
Blana, 2004^142^ Fair | Germany Men were identified from a single institution | 22.5 months (mean) 4 to 62 months (range) | HIFU (n=146) | Age (mean): 67 years
Augustin, 2003^138^ Fair | Germany Men were identified from a single institution | 1.0 month | Radical prostatectomy (n=1243) | Age (mean): 62 years Age (range): 40 to 76 years Tumor stage: T1: 65% (806/1243) T2: 34% (422/1243) T3: 1% (15/1243)
Thuroff, 2003^162^ Fair | Germany, France and the Netherlands Participant selection not described | 1.2 years | HIFU (n=402) | Age (mean): 69 years Age (range): 51 to 80 years
Yao, 1999^165^ Fair | United States Medicare claims data | 1.0 month | Radical prostatectomy (n=101,604) | Age (median): 69 years Race/ethnicity: White: 89.5% (90936/101604) Black: 5.1% (5181/101604) Other: 5.4% (5487/101604)

Abbreviations: HIFU=high-intensity focused ultrasound; RARP=robot-assisted laparoscopic radical prostatectomy; RRP=retropubic radical prostatectomy

We included studies reporting on the physical harms associated with treatment (e.g., urinary, bowel, and sexual function), surgical complications (including mortality associated with surgery), and adverse impacts on quality of life. Gastrointestinal effects (e.g., diarrhea, leakage, urgency) were primarily reported in studies of RP or RT, and hormonal side effects (e.g., hot flashes, gynecomastia) were primarily reported in studies of ADT.

The studies used a variety of continuous scales (Table 13) to assess generic and disease-specific quality of life changes following prostate cancer treatments. Commonly used quality of life scales were the Short-Form 36-Item Health Survey (SF-36)^75,139,144,150^–^152,154,156,159^–^161^ and the University of California, Los Angeles Prostate Cancer Index (UCLA-PCI).^139,150,152,156,159^–^161^ The SF-36 scores range from 0 to 100, with higher scores representing better functioning or quality of life across eight areas (subscales). PCI scores also range from 0 to 100, across six areas of urinary, sexual and bowel function or bother (higher scores indicate less bother or better function). For both scales, differences of 5 to 10 points are generally thought to indicate clinically meaningful changes.^190^

Table 13 Quality of Life Measures

Measure | Type | Description | Scales
SF-36 Short-form 36-item Health Survey (also known as Medical Outcomes Study General Health Survey; RAND 36-item Health Survey; UCLA 36-item Health Survey) | General QOL | 36-item self-administered general quality of life measure used to evaluate physical function, social function, bodily pain, emotional wellbeing, energy/fatigue, general health perceptions, role limitations due to physical problems, and role limitations due to emotional problems. | 5-point Likert scales
CARES-SF Cancer Rehabilitation Evaluation System-Short Form | Cancer-specific QOL | 59-item self-administered cancer-specific quality of life measure; one global score and five higher-order factors representing physical, psychosocial, medical interaction, marital, and sexual quality of life. | 5-point Likert scales
BSFI Brief Sexual Function Inventory | Cancer-specific QOL | 11-item self-administered sexual function measure, divided into five domains: sexual drive (2 questions, pooled scores 0-8); erectile function (3 questions, pooled scores 0-12); ejaculation (2 questions, pooled scores 0-8); problem assessment (3 questions, pooled scores 0-12); and overall satisfaction (1 question, score 0-4). | 5-point Likert scales
EROTC-QLQ-C30 European Organization for Research and Treatment of Cancer (EORTC) Quality of Life Questionnaire for Cancer | Cancer-specific QOL | 30-item self-administered quality of life measure for cancer patients, with disease-specific modules available. | 4-and 7-point Likert scales
EPIC Expanded Prostate Cancer Index Composite | Cancer-specific QOL | 32-item self-administered prostate cancer treatment-related quality of life measure assessing urinary, bowel, sexual, and hormone function, as well as overall satisfaction. | 5-point Likert scales
FACT-G Functional Assessment of Cancer Therapy-General | Cancer-specific QOL | 27-item self-administered general quality of life measure with physical, social/family, emotional, and functional well-being subscales. | 5-point Likert scales
HADS Hospital Anxiety and Depression Scale | General QOL | 14-item scale to assess patient anxiety and depression | 0 (not at all) to 3-point linear scale
PCSI Prostate Cancer Symptom Indices | Cancer-specific QOL | 19-item scale measuring treatment-related urinary (8 items), sexual (5 items) and bowel (6 items) problems | 0-100 (higher score indicating more or worse dysfunction)
PCSS Prostate Cancer Symptom Scale | Cancer-specific QOL | 18-item self-administered quality of life measure specific to prostate cancer. | 0-(no problems/very good function) to 10-point linear analogue scale
PTSS Southwest Oncology Group Prostate Treatment-Specific Symptoms Measure | Cancer-specific QOL | 19-item quality of life measure of bowel, bladder, and sexual function specific to prostate cancer. | 5-point Likert scale
QOL-CS scale Quality of Life - Cancer Survivors | Cancer-specific QOL | 41-item self-administered quality of life measure specific to cancer | 11-point Likert scales
QUF94W | Cancer-specific QOL | 43-item self-administered quality of life measure for prostate cancer patients, designed to evaluate side effects after pelvic radiotherapy. | 0-(no problems/very good function) to 10-point linear analogue scale
UCLA-PCI University of California, Los Angeles Prostate Cancer Index | Cancer-specific QOL | 17-item scale measuring treatment-related sexual (8 items), urinary (5 items), and bowel symptoms (4 items) and bother. | Various-point Likert scales

Table 14 The Effect of Radical Prostatectomy Compared With Conservative Management^*^ on Prostate Cancer-Specific Morbidity and Mortality and All-Cause Mortality

Study Name Author, Year Related Publications | Study Design Followup | Prostate-Cancer Specific Mortality | All-Cause Mortality | Morbidity
ProtecT Hamdy, 2016^121^ Good | RCT 10.0 years (median) | RP: 0.9% (5/553) AS: 1.5% (8/545) HR=0.63 (95% CI, 0.21 to 1.93) | RP: 9.9% (55/553) AS: 10.8% (59/545) HR=0.93 (95% CI, 0.65 to 1.35) | [underlined: Progression to Metastatic Disease] RP: 2.5% (13/553) AS: 6.0% (33/545) HR not reported
SPCG-4 Bill-Axelson, 2014^117^ Good | RCT 13.4 years (median) | RP: 17.7% (63/347; 95% CI, 14.0 to 22.4) WW: 28.7% (99/348; 95% CI, 24.2 to 34.2) RR=0.56 (95% CI, 0.41 to 0.77; p=0.001) | RP: 56.1% (200/347; 95% CI, 50.9 to 62.0) WW: 68.9% (247/348; 95% CI, 63.8 to 74.3) RR=0.71 (95% CI, 0.59 to 0.86; p<0.001) | [underlined: Progression to Metastatic Disease] RP: 26.1 % (89/347; 95% CI, 12.7 to 31.4) WW: 38.3% (138/348; 95% CI, 33.4 to 44.0) RR=0.57 (95% CI, 0.44 to 0.75; p<0.001)
PIVOT Wilt, 2017^74^ Wilt, 2012^133^ Good | RCT 12.7 years (median) | RP: 7.4% (27/364; 95% CI 5.2 to 10.6) WW: 11.4% (42/367; 95% CI 8.6 to 15.1) RR=0.65 (95% CI, 0.41 to 1.03) HR=0.63 (95% CI, 0.39-1.02; p=0.06) | RP: 61.3% (223/364; 95% CI, 56.2 to 66.1) WW: 66.8% (245/367; 95% CI, 61.8 to 71.4) RR=0.92 (95% CI, 0.82 to 1.02) HR=0.84 (95% CI, 0.70 to 1.01; p=0.06) | [underlined: Systemic Disease Progression] RP: 10.2% (37/364) WW: 14.7% (54/367) HR=0.64 (95% CI, 0.42 to 0.97) [underlined: Bone Metastases (10 y median followup)] RP: 4.7% (17/364; 95% CI 2.9 to 7.4) WW: 10.6% (39/367; 95% CI 7.9-14.2) RR=0.44 (95% CI, 0.25 to 0.76; p=0.001) HR=0.40 (95% CI, 0.22 to 0.70; p<0.001)
Barocas, 2017^75^ Good | Cohort 3.3 years (median) | RP: 0.1% (1/1523) AS: 0% (0/429) | RP: 1.3% (18/1523; 95% CI, 0.7 to 1.8%) AS: 2.9% (12/429; 95% CI, 1.3 to 4.6%) | NR
Ladjevardi, 2010^125^ Fair | Cohort 4.4 years (median) | NR | Adjusted HR= 0.36 (95% CI, 0.32 to 0.40) | NR
Schymura, 2010^129^ Fair | Cohort 5.0 years | NR | [underlined: 5-Year Survival (unadjusted)] RP: 93.7% WW: 75.4% In multivariate survival analysis with radical prostatectomy the reference category: HR (death with WW)=2.30 (95% CI: 1.70 to 3.12) | NR
Stattin, 2010^130^ Fair | Cohort 8.2 years (median) | [underlined: Overall] RP: 1.7% (56/3399) WW: 2.9% (58/2021) [underlined: 10-year cumulative mortality rate:] RP: 2.4% (95% CI, 1.8 to 3.3) WW: 3.6% (95% CI, 2.7 to 4.8) RR=0.49 (95% CI, 0.34 to 0.71) | [underlined: Overall] RP: 8.4% (286/3399) WW: 20.4% (413/2021) [underlined: 10-year cumulative mortality rate] RP: 11.3% (95% CI, 10.0 to 12.9) WW: 23.4% (95% CI, 21.3 to 25.8) RR=0.49 (95% CI, 0.41 to 0.57) | NR
Zhuo, 2009^135^ Fair | Cohort 7.0 years | Adjusted HR=0.25 (95% CI, 0.13 to 0.48; p<0.0001) | Adjusted HR=0.32 (95% CI, 0.25 to 0.41; p<0.0001) | NR
Albertsen, 2007^115^ Fair | Cohort 13.3 years (median) | RP: 1.0% WW: 16.0% RR=3.4 (95% CI, 1.9 to 5.9) | RP: 25% WW: 57% RR=NR | NR
Wong, 2006^134^ Good | Cohort 12.0 years | NR | Adjusted HR=0.50 (95% CI, 0.47 to 0.53) | NR

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: AS=active surveillance; HR=hazard ratio; RP=radical prostatectomy; RR=relative risk; WW=watchful waiting

### Summary

The harms of active treatments for early-stage or screen-detected cancers vary by modality. After radical prostatectomy, many men will experience urinary incontinence and erectile dysfunction. Across three RCTs with followup duration ranging from one year to six years, pooled analyses indicate that RP approximately doubles the risk of urinary incontinence (RR, 2.27 [95% CI, 1.82 to 2.84]; I^2^=0.0%);^133,148,166^ approximately 7.9 men need to be treated with RP for one man to develop incontinence based on RCT data (95% CI, 5.4 to 12.2). Using pooled data from two RCTs, the risk of erectile dysfunction with RP was also nearly doubled as compared to conservative management (RR, 1.82 [95% CI, 1.62 to 2.04]; I^2^=0.0%);^133,148,166^ we estimate that 2.7 men need to be treated with RP for one man to develop erectile dysfunction (95% CI, 2.2 to 3.6). Approximately 7 percent of patients undergoing prostatectomy will experience major medical or surgical complications, and the median perioperative mortality after RP in 2 RCTs and 6 cohorts was 0.29 percent.^121,133,137,138,140,155,164,191^

While the association between radiation therapy and urinary incontinence varied widely across studies, pooled analyses of seven cohort studies demonstrate an increased risk of erectile dysfunction with RT as compared with conservative management (RR, 1.31 [95% CI, 1.20 to 1.42]; I^2^=22.1%).^75,76,145,150,156,158,159,161^ We estimate that 6.9 men need to be treated with RT for one man to develop erectile dysfunction (95% CI, 5.1 to 10.7). Radiation therapy was also associated with statistically significant increases in the percentage of men experiencing bothersome bowel symptoms.^70,75,76,145,159,166^ Compared to conservative management, RP and RT do not seem to have clinically significant impacts on global quality of life or physical or mental health status aside from the adverse urinary, sexual, and bowel impacts specified above.

Although less commonly used for localized prostate cancer, androgen deprivation therapy (ADT) was associated with erectile dysfunction in 73.8 to 85.6 percent of men in three cohort studies,^145,154,159^ and studies of men with advanced prostate cancer have shown that ADT can cause a range of systemic adverse effects, including osteoporosis, insulin resistance, gynecomastia, and cognitive impairment. Seven uncontrolled observational studies of patients with localized prostate cancer suggest that high-intensity focused ultrasound (HIFU) is commonly associated with erectile dysfunction (range, 37.3% to 52.7%) and local complications, such as bladder outlet obstruction or urethral stricture.^141^–^143,146,153,162,163^

The risk of medical complications and perioperative mortality after RP were significantly greater in older (age greater than 70 years) as compared to younger men;^137,140,164^ however, evidence on whether other treatment harms differ by patient age, race/ethnicity, family history, or clinical risk assessment was limited or absent.

### Study Characteristics

Overall, we identified four RCTs,^71,133,144,148^ 14 cohort studies,^75,76,139,145,149^–^152,154,156^–^161^ and 14 uncontrolled observational studies^137,138,140^–^143,146,153,155,162^–^165^ reporting urinary, sexual or bowel dysfunction, surgical complications, adverse quality of life impacts, or other harms for active prostate cancer treatment compared with conservative management strategies (i.e., active surveillance or watchful, waiting). We identified three RCTs^71,133,144^ and eleven cohort studies^75,76,139,145,149^–^152,156,158^–^160^ that compared RP with conservative management, as well as six uncontrolled studies of surgical harms related to RP.^137,138,140,155,164,165^ We also identified two RCTs^70,71,144^ and 12 cohort studies^75,76,139,145,149^–^152,156^–^161^ that compared RT with conservative management, as well as one uncontrolled observational study of RT.^157^ Four cohort studies of ADT^145,154,159,160^ and one cohort study of cryotherapy^160^ compared harms of treatment versus conservative management. We identified no RCTs or cohort studies of HIFU, but we did identify seven uncontrolled observational studies reporting harms of HIFU.^141^–^143,146,153,162,163^

The design of three of the included RCTs – ProtecT, PIVOT, and the SPCG-4 – were presented in the discussion of KQ3. In the ProtecT trial, 85 percent of the 1,643 men randomized to RP, RT or AS completed a battery of urinary, sexual and bowel function and quality of life assessments (Expanded Prostate Cancer Index Composite [EPIC]; International Consultation on Incontinence Questionnaire [ICIQ]; International Continence Society Male Short-Form [ICSmaleSF]; Hospital Anxiety and Depression Scale [HADS]; SF-12 (an abbreviated version of the SF-36); and the European Organization for Research and Treatment of Cancer Quality of Life Questionnaire for Cancer [EORTC QLQ-C30]) (Table 13) before diagnosis, at six- and twelve-months after randomization, and annually therafter.^144^ The PIVOT trial reported the incidence of 30-day perioperative complications after RP, as well as patient-reported urinary, bowel, and sexual function after two years of followup among men randomized to RP compared with watchful waiting.^133^ In a recent publication with extended followup, the PIVOT trial reported patient-reported adverse events and quality of life up to 10 years post-randomization.^74^ After a mean of 4.1 years, the SPCG-4 reported the incidence of urinary, sexual and bowel dysfunction among men 2 to 3 years, 4 to 5 years, and 6 to 8 years post-randomization to either RP or watchful waiting,^147^ as well as on additional quality of life measures after a median of 12.2 years followup.^148^ One additional, small RCT – the Swedish trial – randomized men to RT (n=59) or watchful waiting (n=49) and collected data using the Prostate Cancer Symptom Scale (PCSS) and the EORTC QLQ-C30 questionnaire after 30 to 41 months and 10.0 years followup.^70,71^

The ProtecT and Swedish trials reported the incidence of physical harms or quality of life across multiple time points.^70,71,144^ However, the ProtecT study only reported one overall measure of significance across all treatment arms and time points, and did not assess any between-arm or between-time point differences.^144^ While the Swedish trial reported results from the same group of randomized men at 30 to 41 months’ followup^70^ and 10 years’ followup,^71^ there was 50 percent loss to followup at 10 years. In addition to varying timing of data collection, the methods for reporting harms (urinary incontinence, erectile dysfunction, and bowel dysfunction) varied across the trials, which may limit the ability to compare data across the different trials. Only the PIVOT study was set in the United States, which may limit the generalizability of results due to differences in treatment practice patterns.

Eleven of the fourteen cohort studies were set in the United States (median followup range, 0 to 15 years). Two studies identified distinct cohorts of men in the SEER registry as part of the Prostate Cancer Outcomes Study (PCOS), which identified 3,500 men diagnosed with prostate cancer between October 1994 and October 1995.^192^ In one cohort, 24 months after diagnosis, men completed a survey that included general and disease-specific measures of health-related quality of life, including urinary, sexual, and bowel function, as well as treatment satisfaction and impacts on other aspects of daily life.^145^ In the second cohort, men completed either a 6-month or 12-month post-diagnosis survey on health-related quality of life. Survey elements included the SF-36 generic health status questionnaire as well as a prostate-cancer-specific instrument designed specifically for the PCOS.^154^ The other cohorts identified men from pathology laboratories^156^ or registries;^75,76,139,145,149^–^152,157^–^161^ all of the men in all but one these cohorts^76^ completed SF-36 or UCLA PCI measures, and eleven studies also reported the incidence of urinary, sexual, or bowel dysfunction.^75,76,145,149,154,156^–^161^

As with the trials, the timing of data collection varied across the cohort studies, as did the methods for reporting and defining harms. Of the 14 cohort studies, five collected data cross-sectionally and lacked baseline measures.^139,145,149,150,160,161^ Among the studies assessing harms longitudinally, there was variation in the data collection time points (for example, collecting data “pretreatment” and “posttreatment”^158^ versus at baseline and three-years^159^), complicating comparison of outcomes across studies. Two recently published U.S. cohort studies examined the trajectory of reported harms across treatment groups from baseline (prior to treatment) over either two^76^ or three years of followup.^75^

Three of the fourteen uncontrolled observational studies were set in the United States – two identified men from a single institution who received RP^155^ or RT^157^ and the other identified a large group of men (n=101,604) in Medicare claims who received RP.^165^ The remaining studies were set in Europe,^138,140^–^143,153,162^ Canada,^137,164^ or Japan.^146,163^ None of the studies of HIFU were set in the U.S.

### Findings

#### Radical Prostatectomy

We identified three RCTs,^133,144,147,148^ and 11 cohort studies^75,76,139,145,149^–^152,156,158^–^160^ reporting on the harms and adverse quality of life impacts of men with early-stage prostate cancer who received RP compared with men who were conservatively managed. We also identified six uncontrolled observational studies with sample sizes exceeding 1,000 men reporting relevant outcomes.^137,138,140,155,164,165^ One cohort only reported data stratified by age; therefore, this will only be discussed in the subsequent section addressing harms among patient subgroups.^160^

##### Urinary, Sexual, and Bowel Function

All three trials found that urinary incontinence was more common among men who were randomized to RP compared with those were conservatively managed (Table 20).^133,144,147^ Six cohort studies reported on the prevalence of urinary incontinence among men who received RP compared with men who were conservatively managed;^75,76,145,149,156,159^ at latest followup, all of the studies reported that incontinence was more common among men who received RP compared with men who were conservatively managed (Table 20). Across the three trials, the pooled relative risk of urinary incontinence was 2.27 (95% CI, 1.82 to 2.84; I^2^=0.0%) and in the six cohort studies, the pooled relative risk was 2.75 (95% CI, 1.78 to 4.23; I^2^=63.0%) (Figure 2). Based on estimated risk differences (computed from pooled relative risks and absolute urinary incontinence risk among conservatively managed men), we estimate that 7.9 men need to be treated with RP for one man to develop incontinence based on RCT data (95% CI, 5.4 to 12.2).

All three trials also found that erectile dysfunction was more common among men who underwent RP compared with men who were conservatively managed; in two trials, the prevalence of men who experienced erectile dysfunction after RP was approximately double that of men in the watchful waiting arms (81.1% vs. 44.1% in PIVOT and 80.5% vs. 44.9% in SPCG-4) (Table 20).^133,147^ Similarly, the seven studies reporting the prevalence of erectile dysfunction^75,76,145,149,156,158,159^ found that it was more common among men who received RP compared with men who were conservatively managed (Table 20). In pooled meta-analyses of the three RCTs, we observed marked heterogeneity (I^2^=87.5%), which was attributable to disparate findings in ProtecT, in which many of the men randomized to active surveillance received radical treatments (either prostatectomy or radiation) during the comparatively long 6 years of median followup (Figure 3).^144^ After excluding ProtecT from the meta-analysis of the RCT data, the pooled relative risk of erectile dysfunction associated with RP versus conservative management was 1.82 (95% CI, 1.62 to 2.04; I^2^=0.0%). In the seven cohort studies, the pooled risk of erectile dysfunction was 1.49 (95% CI, 1.34 to 1.65; I^2^=59.2%) (Figure 3). Using data from the RCTs other than ProtecT, we estimate that 2.7 men need to be treated with RP for one man to develop erectile dysfunction (95% CI, 2.2 to 3.6).

In two trials^144,147^ and five cohort studies,^75,76,145,149,159^ RP was not associated with increased bowel symptoms or dysfunction compared conservative management (Table 20).

In five studies with longitudinal measures,^75,76,144,159,74^ mean urinary and sexual function scores decreased to a nadir during the six to twelve months after RP with some improvement during longer-term followup, although mean urinary and sexual function remained statistically significantly lower than at baseline up to 6 years of followup.

##### Surgical Complications

Two trials reported on surgical complications and mortality associated with radical prostatectomy. In the PIVOT trial, 21.4 percent of men undergoing RP experienced one or more complications within 30 days of surgery, with the most common complications being wound infection (4.3%), thromboembolic or cardiovascular events (2.9% overall, including myocardial infarction [1.1%], deep vein thrombosis [0.7%], stroke [0.4%], and pulmonary embolism [0.7%]), urinary tract infection (2.5%), the need for an additional surgical repair (2.5%), bleeding requiring transfusion (2.1%), or the presence of a urinary catheter more than 30 days post-surgery (2.1%).^133^ The most common events reported for men undergoing RP in the ProtecT trial were bleeding requiring blood transfusion (2.5%), thromboembolic or cardiovascular events (1.6%), reintervention for anastomotic problems (1.6%), or rectal injury (0.2%) (Table 25).^121,133^

Four uncontrolled observational studies reported on 30-day surgical complications associated with radical prostatectomy.^137,138,155,165^ Thromboembolic or cardiovascular events were the most common complications, affecting 0.4 percent^155^ to 9.0 percent of patients^165^ (with the latter incidence reported in a large, U.S. Medicare cohort). In a cohort study of 4,592 men undergoing prostatectomy, 1.7 percent experience major medical complications (most commonly cardiac or pulmonary) and 5.3 percent experienced major surgical complication (requiring re-intervention) within 30 days of surgery.^155^ In a recent trial comparing short-term outcomes among men with localized prostate cancer randomized to open versus robot-assisted laparoscopic prostatectomy, men randomized to robot-assisted prostatectomy had statistically significantly lower estimated blood loss compared to men randomized to open prostatectomy (444 mL vs. 1338 mL; p<.001) and shorter hospital stays (1.6 vs. 3.3 days; p<.001). There were more post-operative complications in men randomized to open versus robot-assisted prostatectomy, although the difference was not statistically significant (4% vs. 9%; p=0.052).^193^

Eight studies reported on prostatectomy-associated mortality. In the PIVOT trial, 1 of 280 men who underwent RP (0.4%) died within 30 days,^133^ while there were no perioperative deaths in the ProtecT trial.^121^ Four studies reported on 30-day perioperative mortality,^137,138,164,165^ with rates ranging from 0.0^138^ to 0.54 percent in a large, U.S. Medicare cohort.^165^ Two studies reported mortality after longer followup: 0.17 percent after 90-days^140^ and 0.13 percent after 37-months^155^ post-radical prostatectomy. Across all eight studies, the median perioperative mortality after RP was 0.29 percent (Table 25). In the single cohort study that compared 90-day mortality among men undergoing robot-assisted RP (n=7,524) versus open retropubic RP (n=14,820), no significant difference in 90-day mortality was found (adjusted OR, 1.14 [95% CI, 0.46 to 2.81]).^140^

##### Generic and Disease-Specific Quality of Life

Across all time points up to 72 months, men in the ProtecT trial who were randomized to RP or AS experienced similar levels of anxiety and depression (as measured by the HADS scale). After five years of followup, global health status scores, functional scale scores, and symptom scales were also similar between men randomized to RP or AS (as measured by the EORTC-QLQC30). Similarly, there were no clinically meaningful differences in scores on the SF-36 physical component or mental component summary scores (Appendix E Table 6).^144^ Across 10 years of median followup in the PIVOT trial, there were no significant differences in the SF-12 Physical or Mental Component Scales among men randomized to RP versus observation.^74^ After a median followup of 12.2 years in the SPCG-4 trial, there were no significant differences in anxiety, depression, sense of well-being, or self-assessed quality of life between men randomized to RP compared to watchful waiting.^148^

Results from cohort studies^75,139,150^–^152,156,159,160^ also suggest that measures of generic quality of life are similar among men with localized who receive RP and conservative management (Table 26; Appendix E Table 6). Six cohort studies (and no RCTs) evaluated urinary, sexual, and bowel function using the UCLA PCI (Table 26; Appendix E Table 7).^139,150,152,156,159,160^ Results based on the UCLA-PCI scores were consistent with pooled findings from the meta-analysis on urinary incontinence and erectile dysfunction; all of the cohort studies found worse urinary function and bother outcomes following RP compared with conservative management and five of the six cohort studies found worse sexual function and sexual/bowel bother outcomes. In these cohort studies, there were no clear differences in bowel function or bowel bother among men undergoing RP compared to those who were conservatively managed.

#### Radiation Therapy

We identified 15 studies (2 RCTs, 12 cohort studies, and one uncontrolled observational study)^70,71,75,76,139,144,145,149^–^152,156^–^161^ reporting on the harms and quality of life impacts among men with localized prostate cancer who received RT compared with men who were conservatively managed. Two of the cohort studies only reported data stratified by either age or race/ethnicity and are only discussed in the subsequent section addressing harms among patient subgroups.^157,160^

##### Urinary, Sexual, and Bowel Function

Because of marked variability in the incidence of urinary incontinence in eight studies comparing RT and conservative management (Figure 4), we did not perform pooled meta-analyses of these data. In the ProtecT trial, over the course of 6 years of median followup, urinary incontinence developed in 8.4 percent of men randomized to active monitoring compared to 3.5 percent of men randomized to RT.^144^ One possible explanation for this difference was the crossover of many subjects in the AS group to active treatments, including RP which is associated with increased risk of urinary incontinence. In contrast, a small RCT (n=108) with 2.5 years of median followup, 17.5 percent of men randomized to RT regularly used urinary pads for incontinence as compared with 2.0 percent of men randomized to conservative management (RR, 8.3 [95% CI, 1.1 to 6.3]).^70^ Six cohort studies found little or no difference in urinary incontinence.^75,76,145,149,156,159^ Figure 4 illustrates the variability in urinary incontinence across all of the studies.

In the ProtecT trial, erectile dysfunction at baseline was similar among men randomized to RT and AS (15.9% and 16.3% respectively); after 72 months of followup, the difference in erectile dysfunction between the two groups was not significant (39.8% of men randomized to AS vs. 36.2% of men randomized to RT; RR, 0.91 [95% CI, 0.77 to 1.08]).^144^ In contrast, in six of eight cohort studies, the prevalence of erectile dysfunction was statistically significantly more common in men treated with RT as compared to men who were conservatively managed (pooled RR, 1.31 (95% CI, 1.20 to 1.42; I^2^=22.1%) (Figure 5).^75,76,145,149,156,158,159,161^ As with urinary incontinence, the similar incidence of erectile dysfunction among patient randomized to RT and active monitoring in the ProtecT trial may be attributable to the substantial use of active treatments during the six years of median followup among men randomized to AS. Using pooled relative risks from the cohort studies, we estimate that 6.9 men need to be treated with RT for one man to develop erectile dysfunction (95% CI, 5.1 to 10.7). Two recent U.S.-based longitudinal studies that average adverse impacts of RT on sexual function are most pronounced during the initial treatment with a tendency to moderate during longer term followup.^75,76^ However, in a longitudinal cohort study set in Australia,^159^ initial decrements in sexual function associated EBRT persisted throughout the three year followup period.

In the ProtecT trial, fecal incontinence was more common among men randomized to AS at baseline (2.0% vs. 0.4% of men randomized to RT). However, over the course of followup men randomized to RT experienced an increase in the frequency of reporting fecal incontinence; after 72 months of followup, fecal incontinence was reported in 4.1 percent of men randomized to RT compared to 2.6 percent of men randomized to AS.^144^ Three years after treatment, 14.5 percent of men in one cohort who were treated with EBRT characterized their bowel function as a moderate or big problem compared with 6.3 percent of men managed with AS and 6.3 percent of non-cancer controls (OR, 0.58 versus non-cancer controls).^159^ In another cohort, men who were treated with RT reported frequent bowel urgency more often than men who were not treated (31.8% vs. 16.1%).^145^ Two recent U.S. longitudinal cohort studies suggest that the average intensity of adverse bowel symptoms with RT peak in the first year of treatment with a tendency to diminish during longer term followup.^75,76^ In contrast, within an Australian cohort,^159^ initial decrements in bowel function associated with RT persisted throughout a three-year followup period.

##### Generic and Disease-Specific Quality of Life

Across all time points up to 72 months, men in the ProtecT trial who were randomized to radiation or AS experienced similar levels of anxiety and depression (as measured by the HADS scale). After 5 years of followup, global health status scores, functional scale scores, and symptom scales were also similar between men randomized to both groups (as measured by the EORTC-QLQ-C30). Similarly, there were no clinically meaningful differences in scores on the SF-36 physical component or mental component summary scores (Appendix E Table 8).^144^ In the small Swedish trial, no statistically significant differences in quality of life (as measured by the EORTC-QLQ-C30 scale) between 4 and 10 years of followup were observed between men randomized to radiation or watchful waiting.^71^

Nine cohort studies that compared SF-36 measures among men who underwent RT and men who underwent conservative management generally found small or unclear differences on component and subscales (Table 26; Appendix E Table 8).^75,139,149,151,152,156,159^–^161^ Seven cohort studies evaluated urinary, sexual and bowel function using the UCLA PCI (Table 26; Appendix E Table 9).^139,150,152,156,159^–^161^ Results based on the PCI found worse outcomes following radiation therapy compared with conservative management for sexual function and bother, as well as bowel function and bother; no clear differences were seen in urinary function or bother.

#### ADT

We identified five cohort studies reporting on the harms and quality of life impacts among men who received androgen deprivation therapy (ADT) compared with men who were conservatively managed or who did not receive any treatment.^139,145,154,159,160^ One of the cohort studies only reported data stratified by age and is discussed only in the subsequent section addressing harms among patient subgroups.^160^

##### Urinary, Sexual, and Bowel Function

Two cohort studies reported on the prevalence of urinary incontinence among men who received ADT compared with men who were conservatively managed.^145,159^ Two to 3 years after treatment, both studies found no significant difference in urinary incontinence among men who received ADT compared with men who underwent either AS (RR, 1.1 [95% CI, 0.23 to 5.30])^159^ or were not treated (RR, 1.40 [95% CI, 0.74 to 2.50]).^145^ Three cohort studies found that the prevalence of erectile dysfunction was statistically significantly elevated among men who received ADT compared with men who were managed with AS or not treated (RR range, 1.6 to 2.9).^145,154,159^ Prevalence of bowel dysfunction after ADT was reported in two studies with unclear effects as neither provided direct statistical comparisons with the group of men who were conservatively managed.^145,159^

##### Generic and Disease-Specific Quality of Life

Three cohort studies found that physical role function, bodily pain, vitality, and emotional role function were generally worse among men who received ADT compared with those who were conservatively managed (Table 26; Appendix E Table 10).^139,154,160^ However, these cross-sectional analyses warrant careful interpretation, as they lack adjustment for baseline measures.

One study found that men who received ADT reported statistically significantly higher levels of physical discomfort compared to men who were not treated (p=0.02), yet more men receiving ADT reported satisfaction with their treatment choice (p=0.001).^154^

Three cohort studies evaluated urinary and sexual bother and function using the UCLA PCI; two of those studies reported on bowel function and bother (Table 26; Appendix E Table 11).^139,159,160^ These studies generally found that urinary, sexual, and bowel function and bother scores were lower among men who received ADT compared with those who were conservatively managed. However, given the small number of studies reporting UCLA PCI outcomes, it is unclear whether the differences are clinically meaningful.

##### Other Harms

One study found that among men receiving ADT, a significantly higher proportion reported gynecomastia (20.0%) or hot flashes (58.0%) compared with men who did not receive treatment (3.8% and 11.1%, respectively).^154^ In a recent longitudinal U.S. cohort study,^75^ men with localized prostate cancer who received EBRT had statistically significantly worse hormone function during the year following treatment (i.e., higher rates of hot flashes, gynecomastia, asthenia, or weight change), and these adverse hormonal impacts were isolated to the 45 percent of men treated with ADT in addition to EBRT.^75^ In men with advanced prostate cancer, ADT has been associated with osteoporosis and skeletal fractures, decreased lean body mass, insulin resistance, fatigue, decreased penile and testicular size, thinning of hair, depression, anemia, and cognitive impairment;^194^ however, we did not find studies documenting these potential adverse effects among men treated with ADT for localized prostate cancer.

#### Cryotherapy

We identified one cohort study comparing cryotherapy with conservative management. This study included a small (n=28) sample of men receiving this treatment with a median of 3.8 years of followup after treatment. This study only reported urinary and sexual function stratified by age so is discussed in a subsequent section addressing harms among patient subgroups.^160^

#### HIFU

We identified one uncontrolled observational study with a sample size exceeding 1,000 men that reported the harms and quality of life impacts among men who received high-intensity focused ultrasound (HIFU).^143^ Because only one study met sample size inclusion criteria, we included six smaller uncontrolled studies with sample sizes exceeding 100 men.^141,142,146,153,162,163^ None of the included studies reported SF-36 or UCLA PCI scores, or other measures of generic or disease-specific quality of life.

##### Urinary, Sexual, and Bowel Function

Seven uncontrolled observational studies reported the prevalence of urinary dysfunction associated with HIFU;^141^–^143,146,153,162,163^ five of those cohorts reported on erectile dysfunction. Our review did not identify any studies reporting on bowel dysfunction associated with HIFU. With followup ranging from 23 months to 6.4 years, between 0 percent and 7.3 percent of men undergoing HIFU for localized prostate cancer reported grade 2 urinary incontinence or worse (leakage with mild activity, such as walking or standing up).^141^–^143,153,162,163^ Three studies, with followup ranging from 6 months to 4.8 years, reported that erectile dysfunction occurred in 37.3 to 52.7 percent of men who were potent prior to HIFU treatment.^141,142,146^ Other reported urinary harms included urinary tract infections (6 studies; median, 5.6%; range, 3.9% to 26.5%),^142,143,146,153,162,163^ urethral stricture (2 studies; range, 6.8% to 20.3%),^142,143,153,162,163^ rectourethral fistulas (5 studies; median, 1.0%; range, 0.4% to 1.6%),^137,142,143,153,162,163^ and bladder outlet obstructions (3 studies; median, 16.6%; range, 11.7% to 24.5%).^141^–^143^

## KQ4a Do the Harms of These Treatment Approaches Vary Between a Priori Subgroups: Age, Race/Ethnicity, Family History, or Clinical Risk?

### Age

Five studies (two cohort studies and three uncontrolled observational studies) stratified the treatment harms or quality of life impacts by patient age.^137,140,158,160,164^

#### Urinary Function

Comparing men younger than age 70 years with those age 70 years or older, one cohort study found no difference in urinary incontinence at 18-months post-treatment with RP, RT, ADT or cryotherapy compared with observation. Older men who had RP or RT rather than observation were more likely than younger men to consider their urinary function a moderate or big problem.^160^

#### Sexual Function

Comparing men younger than age 70 years with those age 70 years or older, one cohort found that at 18 months posttreatment, older men reported lack of erections more often regardless of the treatment received; however, the magnitude of the difference was largest among men receiving cryotherapy (30% erectile dysfunction in younger men versus 100% in older men). Across all treatment groups except ADT and cryotherapy, older men considered their sexual function a moderate or big problem more often than younger men.^160^ Another cohort found statistically significant decreases in posttreatment potency across all age groups (<59 years, 60 to 70 years, ≥71 years) for men treated with radical prostatectomy and radiation therapy compared to conservative management or no treatment (p<0.0001).^158^

#### Bowel Function

We did not identify any studies reporting the differential impact of treatment on bowel function by age.

#### Other Harms

An uncontrolled observational study of 30-day prostatectomy-associated complications found that the incidence increased with age, from 17.5 percent among men younger than 60 years of age to 26.9 percent among men aged 70 to 79 years. Regardless of age, the most common complications were genitourinary. After adjusting for comorbidity, age was found to be associated with statistically significantly higher risks of cardiac (p<0.001) and respiratory complications (p=0.01).^137^

One uncontrolled observational study of 30-day mortality after prostatectomy found that the mortality rate increases from 0.2 percent among men younger than 60 years of age to 0.7 percent among men aged 70 to 79 years;^137^ another study found an increased risk in mortality among men aged 69 years or older compared with younger men (OR, 3.1; p<0.001).^164^ An uncontrolled study of 90-day perioperative mortality after RP also found a borderline statistically significant increase in risk associated with age (OR, 1.07 [95% CI, 1.00 to 1.13] per one-year increase in age).^140^

### Race/Ethnicity

2 studies (one cohort and one uncontrolled observational study) stratified the harms of prostate cancer treatment by race/ethnicity.^157,158^

#### Urinary Function

One observational study found that white men who received EBRT were more likely to have urinary incontinence compared to African American men (8.9% vs. 6.7%, respectively; p<0.001), but there was no significant difference in incontinence by race among men who were treated with brachytherapy (p=0.82).^157^

#### Sexual Function

One U.S. cohort study evaluating pre- and post-treatment potency, found that African American and white men experienced similar decreases in potency after RP (65.2% and 67.2% absolute reduction for African-American and white men, respectively, p=0.74 pairwise comparison). In contrast, the decline in potency associated with radiation therapy was significantly less severe among African American men than white men (37.5% and 51.2% absolute reduction for African-American and white men respectively; p=0.04 for pairwise comparison).^158^

#### Bowel Function

One observational study found no significant differences in the frequency of diarrhea, rectal pain, or rectal bleeding associated with radiation therapy among white as compared to African American men.^157^

#### Other Harms

An uncontrolled U.S. observational study of radical prostatectomy found that non-white race was associated with higher risk of medical or surgical complications (African American vs. white, HR=1.4 [95% CI, 1.0 to 2.0]; p=0.027; other/unknown vs. white, HR=1.6 [95% CI, 1.1 to 2.6]; p=0.028).^155^

### Family History

We did not identify any studies reporting the differential impact of the included treatment or monitoring approaches by family history.

### Clinical Risk Assessment

We assessed studies for evidence of differentially greater or less treatment harms by clinical risk assessment, considering pre-treatment factors such as tumor characteristics, clinical stage, baseline PSA, or a combination of these factors. Five studies (one cohort and four uncontrolled observational studies) stratified the harms of treatments by one or more of these factors.^137,140,155,158,164^

#### Urinary, Sexual, and Bowel Function

We did not identify any studies reporting the differential impact of treatment on urinary, sexual or bowel function by clinical risk assessment.

#### Other Harms

An observational study of radical prostatectomy found that more comorbidities (and some specific conditions, such as diabetes and cardiovascular disease) and higher Gleason score were associated with higher risk of medical or surgical complications.^155^ Another uncontrolled study of perioperative complications found that, after adjusting for age, increasing numbers of comorbidities was associated with increased risk of cardiac, respiratory, vascular, wound/bleeding, genitourinary and miscellaneous complications (p<0.001).^137^

One observational study of 30-day mortality after prostatectomy found an increased risk among men with comorbidities (defined as a Charlson comorbidity index score ≥1) compared with men without comorbidities (OR, 3.0; p=0.002).^164^ In contrast, a more recent large study of 90-day perioperative mortality after prostatectomy in Sweden (n=22,344) found that the presence of comorbidities (defined as a Charlson comorbidity index score ≥1) was not significantly associated with perioperative mortality, although perioperative mortality was significantly greater among men with high-risk cancers (OR, 2.89 [95% CI, 1.18 to 7.06]), defined as T3, Gleason>7, or PSA>20 ng/mL.^140^

## KQ4b Do the Harms Differ by Treatment Approach?

### Urinary, Sexual, and Bowel Function

Meta-analysis found that radical prostatectomy but not radiation therapy was associated with an increased risk of urinary incontinence (Figure 2) (RR, 2.9 [95% CI, 2.4 to 3.5]). Both radical prostatectomy and radiation therapy were found to be associated with an increased risk of erectile dysfunction (Figures 4 and 8) (RR, 1.6 [95% CI, 1.5 to 1.7] and RR, 1.2 [95% CI, 1.1 to 1.3]).

### Generic and Health-Related Quality of Life

Based on assessment of SF-36 scales, neither RP nor RT were associated with significantly greater decrements in generic quality of life compared to conservative management, while ADT may be associated with a relative decline in generic quality of life compared to conservative management.

Cohort studies reporting median differences in PCI scores (Table 26) found that urinary function was lower in men undergoing radical prostatectomy compared with those treated with radiation (median difference, −3.3 points) or ADT; however, this was not true for urinary bother (men treated with ADT reported the lowest median PCI scores). Cohort studies also found that sexual function and bother was lower among men treated with either EBRT or brachytherapy as compared with men who were conservatively managed; however, median sexual function scores were lowest for men treated with ADT. Bowel function and bother scores on the UCLA PCI tended to be worse among men treated with radiation, while there was no clear difference among men treated with radical prostatectomy. Only two studies reported on bowel function and bother among men treated with ADT; while both studies reported mean scores in men treated with ADT as compared with those conservatively managed, the magnitude of the difference may not be clinically meaningful.

In a recent U.S. longitudinal cohort study,^76^ adverse bowel symptoms were only associated with EBRT and not with brachytherapy (used by 30.4% of the men who received RT). Meanwhile, within this U.S. cohort and an Australian cohort, the incidence of adverse effects on sexual function was similar for EBRT and brachytherapy.^76,159^ However, within the Australian cohort, both EBRT and brachytherapy were associated with elevations in measures of bowel bother that persisted through the three year followup period.^159^

## KQ5 Is There Evidence That Use of a Prebiopsy Prostate Cancer Risk Calculator, in Combination With PSA-Based Screening, Accurately Identifies Men With Clinically Significant Prostate Cancer Compared to PSA-Based Screening Alone?

### Summary

The PCPT risk calculator has been externally validated for the identification of significant prostate cancer in 21 external cohorts.^78,79,167^–^177^ While the calculator improves discrimination between patients with and without clinically significant prostate cancer, its predictive accuracy has varied substantially across samples. Calibration of the risk calculator has also been variable. Ankerst et al. (2014) did not identify clear sources of variability across the ten cohorts in their study (including differences in number of prostate cores, screening versus referral cohorts, and European versus United States settings),^171^ so the heterogeneity in PCPT calculator performance remains unexplained.

Seven studies have externally validated the ERSPC risk calculator’s ability to identify men with clinically significant prostate cancer,^77,79,167^–^169,172,175^ in addition to the original ERSPC study which may more accurately be considered an internal validation. While the studies suggest that the calculator can improve discrimination of clinically significant cancer compared to PSA alone, calibration was mixed in the five cohorts in which it was assessed. The evidence base for use of the ERSPC calculator for the detection of clinically significant cancer is also limited by the use of TRUS to estimate prostate volume in all studies, while widespread use of the calculator for clinical decision-making would require use of digital rectal exam (DRE)-estimated prostate volume. The external validity of the calculator with strict use of DRE-based prostate volume estimates has not been established.

### Risk Calculator Characteristics

Both the PCPT and ERSPC risk calculators were originally developed to predict the presence or absence of any prostate cancer with the potential clinical goals of minimizing the harm of biopsy among men without prostate cancer.^51,195^ In clinical use, both calculators estimate a probability of prostate cancer prior to biopsy and have been adapted to estimate the probability of clinically significant cancer. Men may vary in their risk threshold for undergoing biopsy based on how they value the benefits of cancer detection with the harms of negative biopsy, especially at intermediate levels of risk. Pre-biopsy discussion between patients and urologists conceivably could assist in defining patients’ individual thresholds for undergoing biopsy. Men whose pre-biopsy risk falls below their personal threshold may elect to forego biopsy.

An adaptation of the PCPT calculator, termed “PCPT Calculator 2.0,” was designed to predict the presence of high-grade (Gleason score ≥7) versus low-grade cancer with the potential clinical goal of minimizing the harms of overtreatment of low-grade prostate cancer.^170^ The PCPT 2.0 calculator requires seven clinical variables: PSA level, DRE results, age, African American race/ethnicity, prior biopsy, and family history. A further adaptation enables the addition of free PSA to these variables with the potential to further improve prediction.

The ERSPC risk calculator was also developed to predict the presence of high versus low-grade prostate cancer; the initial development was based on 3,616 men referred for biopsy during early screening rounds of the Rotterdam ERSPC.^172^ The risk calculator uses four variables: PSA, DRE results, prior negative biopsy (if ever biopsied), and prostate volume as determined by TRUS. Because TRUS is an invasive procedure that is typically performed during biopsy, the authors converted TRUS volume measures to three categories that could be assigned by clinicians during office-based DRE. We discuss below a validation study of this risk calculator among men referred for biopsy for abnormal screening results whose prostate volume was estimated using DRE.

### Findings

#### External Validation of the PCPT Risk Calculator

Including both versions, the PCPT risk calculator has been validated in 21 external biopsy cohorts. Earlier evaluations assessed the validity of the original PCPT calculator, while more recent studies assessed the validity of PCPT 2.0 for predicting clinically significant prostate cancer. The largest external evaluation was based on over 25,000 biopsies from 10 external biopsy cohorts from Europe and the United States.^170,171^ Across the cohorts, the risk calculator had a median AUC of 0.75 for the detection of clinically significant prostate cancer (range, 0.62 to 0.88).^170^ However, calibration of the risk calculator was poor in some cohorts while adequate in others.^171^ Decision curve analyses also yielded mixed results, suggesting net benefit in six cohorts but little or no benefit in four. In the decision curve analyses, expected benefits are the number of patients with significant prostate cancer who are detected (true-positives), while expected harms correlated with number of patients without significant prostate cancer who undergo biopsy. A decision curve analysis implies net benefit when the benefits of true-positives exceed the harms of false-positives across the range of pre-biopsy risk thresholds in which the risk calculator is likely to be applied (or net harm if the harms of false-positives exceed the benefits).

We identified 11 other studies reporting validation of the PCPT calculator within external cohorts (range, 322 to 4,515 biopsies).^78,79,167^–^169,172^–^177^ Cohorts were composed of men from North America, Europe, or South Korea, and most consisted of men referred to tertiary or academic centers for biopsy consideration. Across these 11 cohorts, the median AUC for the detection of significant cancer was 0.70 (range, 0.51 to 0.79). For comparison, the median AUC of PSA alone (reported in six studies) was 0.65 (range, 0.56 to 0.71).^167,168,172,175^–^177^

Calibration was assessed in 8 of the 11 cohorts,^167^–^169,173,175,176^ yielding mixed results. Three of four studies that conducted decision curve analyses suggested small net benefits of risk calculator use,^168,169,173^ but analyses suggested net harm of calculator use in one high-risk referral population.^167^

In a systematic review of the predictive validity of risk prediction models for prostate cancer,^196^ the authors analyzed the discrimination of the PCPT risk calculator for the prediction of clinically significant prostate cancer based on studies published through mid-2012 including 14 of the 21 cohort studies reviewed in this report.^51^ In a meta-analysis of the AUCs from these 14 cohorts, the summary AUC for the detection of clinically significant cancer was 0.71 (95% CI, 0.67 to 0.75) with an I^2^ statistic of 94.7 percent, consistent with marked heterogeneity.

#### External Validation of the ERSPC Risk Calculator

We identified seven validation studies of the ERSPC risk calculator for the identification of high-grade prostate cancer.^77,79,167^–^169,172,175^ Roobol et al. (2012) described the development of the ERSPC calculator within a sample of 3,616 men referred for biopsy during early ERSPC screening rounds. Prostate volume in the development sample was estimated using TRUS rather than DRE. The calculator was validated among 322 men referred for biopsy during later screening rounds with prostate volume estimated during DRE conducted by urologists in training. Among these men, the ERSPC risk calculator had an AUC of 0.78 for the detection of clinically significant cancer (95% CI, 0.69 to 0.87) as compared to 0.68 for PSA alone (95% CI, 0.57 to 0.78). No data on calibration or clinical utility of the risk calculator were reported.^172^ These results warrant cautious interpretation for various reasons. First, an optimal external validation is performed on a completely separate population than that from which the risk tool was derived; the validation study here was performed on ERSPC trial participants so may be considered an internal rather than an external validation and may be optimistically biased.^57^ Second, the risk calculator was derived with TRUS-estimated prostate volume, while the prostate volume was estimated by DRE (prior to TRUS) in the validation phase. In the validation phase, DRE-estimated volume may not have been independent of TRUS, and accuracy may be less without TRUS volume estimates, which cannot be routinely obtained in ambulatory primary care or urology settings. Finally, while the authors provided evidence of correlation between urologist-estimated volume and TRUS-calculated prostate volume,^172^ it is uncertain whether primary care physicians can accurately estimate prostate volume using DRE.

We identified six external validation studies of the ERSPC calculator.^77,79,167^–^169,175^ These biopsy cohorts originated in Europe, Canada, or South Korea with biopsy sample sizes ranging from 556 to 2,313. Within these cohorts, the AUC of the ERSPC calculator for the detection of clinically significant cancer ranged from 0.69 to 0.83, as compared to the AUC of PSA alone which ranged from 0.61 to 0.65 (reported in three cohorts^167,168,175^). The risk calculator was well-calibrated in four studies^168,169^ but underestimated actual risk across the entire risk range in another.^167^ In four studies, decision curve analyses were conflicting, suggesting net benefit in two,^168^ little impact in another,^169^ and net harm in the third.^167^ Notably, all of the external validation studies used TRUS-estimated volume, rather than DRE-estimated volume, since the study participants were undergoing TRUS-guided biopsy regardless of calculator results.