# Chapter 2 Methods

## Scope and Purpose

This systematic review will provide updated evidence regarding the benefits and harms of PSA-based screening for prostate cancer, and subsequent treatments for screen-detected or localized prostate cancer. The USPSTF will use this review to update its 2012 recommendation on this topic.^47^ This review included studies from the previous review that met current inclusion and exclusion criteria, as well as newly identified studies.

## Key Questions and Analytic Framework

Using USPSTF methods,^48^ we developed an analytic framework (Figure 1) and five Key Questions (KQs) in consultation with members of the USPSTF. These KQs were adapted from questions addressed in the previous review;^49,50^ however, KQ5, related to the utility of pre-biopsy risk calculators, is new to this review.

Figure 1 Analytic Framework

Key Questions
1. Is there direct evidence that prostate cancer-specific antigen (PSA)-based screening for prostate cancer reduces short- or long-term prostate cancer morbidity and mortality and all-cause mortality?
  a. Does the effectiveness of PSA-based screening vary by subpopulation or risk factor (e.g., age, race/ethnicity, family history, or clinical risk assessment)?
2. What are the harms of PSA-based screening for prostate cancer and diagnostic follow-up?
  a. Do the harms of PSA-based screening for prostate cancer and diagnostic follow-up vary by subpopulation or risk factor (e.g., age, race/ethnicity, family history, or clinical risk assessment)?
3. Is there evidence that various treatment approaches for early-stage or screen-detected prostate cancer reduce morbidity and mortality?
  a. Does the effectiveness of these treatment approaches vary by subpopulation or risk factor (e.g., age, race/ethnicity, baseline PSA value, family history, comorbid conditions, or clinical risk assessment)?
4. What are the harms of the various treatment approaches for early-stage or screen-detected prostate cancer?
  a. Do the harms of these treatment approaches vary by subpopulation or risk factor (e.g., age, race/ethnicity, baseline PSA value, family history, comorbid conditions, or clinical risk assessment)?
  b. Do the harms differ by treatment approach?
5. Is there evidence that use of a prebiopsy prostate cancer risk calculator, in combination with PSA-based screening, accurately identifies men with clinically significant prostate cancer (i.e., cancer that is more likely to cause symptoms or lead to advanced disease) compared to PSA-based screening alone?

Figure 1 is the analytic framework that depicts the five Key Questions that guided the systematic evidence review. In general, the figure illustrates how PSA-based screening for prostate cancer in asymptomatic men may identify men with potentially early-stage prostate cancer who need to undergo additional diagnostic followup (i.e., needle biopsy of the prostate), the effectiveness and performance of prebiopsy risk calculators, and how screening may lead to improved outcomes or potential harms. In addition, the framework examines the efficacy of the range of treatments and any potential harms of those treatments.

### KQs

1. Is there direct evidence that prostate-specific antigen (PSA)-based screening for prostate cancer reduces short- or long-term prostate cancer morbidity and mortality and all-cause mortality?
  a. Does the effectiveness of PSA-based screening vary by subpopulation or risk factor (e.g., age, race/ethnicity, family history, or clinical risk assessment)?
2. What are the harms of PSA-based screening for prostate cancer and diagnostic followup?
  a. Do the harms of PSA-based screening for prostate cancer and diagnostic followup vary by subpopulation or risk factor (e.g., age, race/ethnicity, family history, or clinical risk assessment)?
3. Is there evidence that various treatment approaches for early-stage or screen-detected prostate cancer reduce morbidity and mortality?
  a. Does the effectiveness of these treatment approaches vary by subpopulation or risk factor (e.g., age, race/ethnicity, baseline PSA value, family history, comorbid conditions, or clinical risk assessment)?
4. What are the harms of the various treatment approaches for early-stage or screen-detected prostate cancer?
  a. Do the harms of these treatment approaches vary by subpopulation or risk factor (e.g., age, race/ethnicity, baseline PSA value, family history, comorbid conditions, or clinical risk assessment)?
  b. Do the harms differ by treatment approach?
5. Is there evidence that use of a pre-biopsy prostate cancer risk calculator, in combination with PSA-based screening, accurately identifies men with clinically significant prostate cancer (i.e., cancer that is more likely to cause symptoms or lead to advanced disease) compared to PSA-based screening alone?

## Data Sources and Searches

In addition to considering studies from the previous review for inclusion in the current review, we performed a comprehensive search of MEDLINE/PubMed, Embase, Web of Science, and the Cochrane Database of Systematic Reviews. We worked with a medical librarian to develop our search strategy (Appendix A). All searches were limited to articles published in the English language. For evidence related to the effect of screening and treatment on health outcomes, we searched for studies published between January 2011 and July 2017, building upon the literature published since the previous review. For evidence related to the use of risk calculators, we searched for studies published between January 2006 and July 2017. We limited the search for KQ5 to this time span based on a preliminary scan of the evidence, which revealed that the earliest publication on risk calculators was based on the Prostate Cancer Prevention Trial (published in 2006).^51^ All other relevant publications were published more recently.

To ensure comprehensiveness of our search strategy, we reviewed reference lists of included studies and relevant systematic reviews and meta-analyses to identify potentially relevant articles that were published before our search dates or were not identified in our literature searches. We also obtained references from outside experts, and searched federal agency trial registries for ongoing trials (Appendix C). We managed literature search results using EndNote version X7.5 (Thomson Reuters, New York, NY).

## Study Selection

Two reviewers independently reviewed titles and abstracts of identified articles to determine if studies met inclusion criteria for design, population, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated full-text articles of potentially relevant studies to assess whether they met inclusion or exclusion criteria. Disagreements in the abstract or full-text review were resolved by discussion and consultation with a third reviewer. A list of excluded studies after full-text review, including the reasons for exclusion, is available in Appendix B.

We developed an a priori set of criteria for inclusion and exclusion of studies based on criteria from the previous review and our understanding of the literature (Appendix A Table 1). We excluded studies where the majority of participants were from countries that are not designated as having a very high Human Development Index, as defined by the United Nations Development Programme.^52^ Studies conducted in other settings are less likely to offer evidence that would translate to U.S primary care settings.

For the screening questions (KQ1–2), we included studies of asymptomatic men, defined as men without symptoms that were suspicious for prostate cancer. For screening effectiveness (KQ1), we examined studies that compared PSA-based screening to either non-PSA-based methods of prostate cancer screening (e.g., DRE) or no screening. For KQ1, we included studies reporting all-cause and prostate cancer-specific mortality, and prostate cancer-related morbidity, such as bone pain from metastases, and progression to advanced-stage cancer. Although prostate cancer screening trials were not powered to detect a decrease in overall (all-cause) mortality, we included this outcome because screening may conceivably either decrease overall mortality (if the impact on prostate cancer-specific mortality is very large) or increase overall mortality (if screening increases rates of treatment harms). For screening harms (KQ2), which includes the harms of subsequent diagnostic followup, we included studies reporting false positives, physical harms of screening or biopsy (e.g., infection), psychological harms (e.g., anxiety), and deleterious effects on health-related quality of life. For studies of men undergoing biopsy, we required that men were undergoing prostate biopsy as a result of an elevated screening PSA; we excluded studies of men undergoing biopsy if the reason for prostate biopsy was not specified. We also assessed randomized trials of screening for evidence of overdiagnosis. We excluded ecological studies that examined the rising incidence of prostate cancers over time, the prevalence of subclinical prostate cancers, and autopsy studies as studies with these designs do not directly assess screened populations and often include many subjects whose cancers were identified without screening. For KQ1, we limited the study design to randomized, controlled trials (RCTS); for KQ2, we also included cohort studies of men undergoing screening PSA or biopsy.

For the questions of treatment-related benefits and harms (KQ3–4), we included studies of men with screen-detected or early-stage prostate cancer (defined as stages T1-T2). We did not consider studies of treatment benefits and harms for men with later-stage prostate cancer (stages III or IV), because large, population-based screening trials have primarily detected early-stage cancer (90–96% of cancers detected) and the treatment-related consequences of screening will chiefly derive from treatments of early-stage disease.^53,54^ We excluded studies that did not adequately report baseline tumor stage or that enrolled more than 10 percent of patients with stage T3 tumors or higher, unless results were stratified according to tumor stage at baseline. We also excluded studies that evaluated patients with recurrent or refractory prostate cancer. Studies that described the population as having localized prostate cancer were included even if they did not report specific tumor stage information, as this term typically refers to T1 and T2 cancer.^55^

We included studies that compared outcomes of active treatments with conservative management, defined as watchful waiting, active surveillance, observation, deferred treatment, or no treatment. Active treatment options for men with early-stage prostate cancer include radical prostatectomy (retropubic, perineal, and laparoscopic), radiation therapy (external beam radiation therapy, brachytherapy), androgen deprivation therapy (ADT), cryotherapy, or high-intensity focused ultrasound (HIFU). For treatment effectiveness (KQ3), we included studies reporting all-cause and prostate cancer-specific mortality, and prostate cancer-related morbidity, such as bone pain from metastases, and progression to metastatic cancer. For treatment harms (KQ4), we included studies reporting surgical complications and other physical harms of treatment (e.g., urinary, sexual, bowel function), psychological harms (e.g., depression), and impacts on generic- or health-related quality of life. For KQ3, we limited study designs to RCTs and comparative cohort studies. For KQ3, we excluded comparison studies of active treatments unless a conservative management group was included. For KQ4, we broadened our criteria to include uncontrolled observational studies of harms, in addition to RCTs and comparative cohort studies. We limited our inclusion of uncontrolled studies of harms to those studies with sample sizes of 100 men or greater. We prioritized uncontrolled studies with a sample size of at least 1,000 men, and included uncontrolled studies with smaller sample sizes only if RCTs, cohort studies, and larger uncontrolled studies (sample sizes greater than 1,000 men) were not available.

For KQ 5, we included external validation studies of multivariable risk calculators that used PSA in addition to patient variables routinely available prior to prostate biopsy to predict the presence of clinically significant prostate cancer. We defined prostate cancers as clinically significant if either high-grade (Gleason score ≥7) or clinical stage T2b or higher, as these tumor characteristics are associated with five-year, post-treatment recurrence risk of 25 to 50 percent.^56^ We defined external validation as evaluation of the discrimination and calibration of the risk calculator in a population other than the population from which it was derived. We excluded internal validation studies (e.g., using a random- or split-sample of the derivation population) as these are prone to bias and overfitting.^57^ We also excluded studies of tools designed to predict any prostate cancer, rather than clinically significant prostate cancer as defined above. For KQ5, we limited the included study designs to RCTs and cohort studies. We did not include studies of novel serum biomarkers, such as the 4Kscore^58^ or the Prostate Health Index (PHI),^59^ or imaging studies, such as multiparametric magnetic resonance imaging (MP-MRI),^60^ because results of these studies would not be routinely available prior to biopsy in most U.S. urology practices. Evidence on these modalities is summarized in Appendix F.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the methodological quality of each included study using predefined criteria developed by the USPSTF^48^ and supplemented with criteria from the Newcastle-Ottawa Scale,^61^ and the National Institute for Health and Care Excellence methodology checklists for observational studies.^62^ Each study was assigned a final quality rating of good, fair or poor. Disagreements in quality were resolved through discussion.

Good-quality studies included all or most of the following: adequate randomization procedures or cohort selection, allocation concealment, blinding of outcome assessors, reliable outcome measures, comparable groups at baseline (with specified eligibility criteria), low attrition, acceptable statistical methods, adjustment for potential confounders, adequate adherence to the intervention, and low rates of contamination. We rated studies as fair quality if they were unable to meet the majority of the good-quality criteria or one or two flaws were of sufficient magnitude to undermine confidence in the results. We rated studies as poor quality if they contained major flaws (i.e., attrition >40%, differential attrition of >20% between groups) or the cumulative effects of multiple minor flaws or the extent of missing information was significant enough to raise serious doubts about the validity of study results.

As there is no widely accepted quality rating tool for studies of risk prediction models, we critically appraised risk prediction studies (KQ5) using the checklists and principles articulated in the Checklist for Critical Appraisal and Data Extraction for Systematic Reviews for Prediction Modeling Studies (CHARMS)^57^ and the Transparent Reporting of a Multivariable Prediction Model for Individual Prognosis or Diagnosis (TRIPOD) Statement.^63^ For KQ5, we required that the study include biopsy results from all men as a key quality indicator, and excluded studies that did not meet this criterion. Studies of risk prediction models were not formally rated as good versus fair quality because of the absence of standardized rating methods for studies with this objective.

One reviewer extracted data from all included studies into a REDCap^64^ (Research Electronic Data Capture) electronic database (Vanderbilt University, Nashville, TN) and a second reviewer checked the data for accuracy. We abstracted study design characteristics, population demographics, screening and treatment details, prostate cancer outcomes (stage at diagnosis, incidence, mortality), health outcomes (quality of life, functioning, health status), and adverse events.

### Approach to Assessing Overdiagnosis

For this analysis, we define overdiagnosis as a screen-detected cancer that would not have been clinically detected during the patient’s lifetime in the absence of screening. Overdiagnosis is a harm of screening because men who are overdiagnosed by definition do not benefit from early detection yet may suffer the harms of diagnosis and treatment. In this report, we synthesize evidence on overdiagnosis from randomized trials of PSA screening.

Randomized trials can yield an estimate of the number of overdiagnosed cancers in the screening group by comparing the number of cancers diagnosed in the screening group with the number diagnosed in the control group after extended followup of both groups. Two different denominators have been used when reporting on the “frequency” or “extent” of overdiagnosis – all screen-detected prostate cancers during the screening phase of the trial and all prostate cancers detected during the screening phase.^65^ In a randomized trial, the numerator for both computations is the absolute excess number of cancer cases diagnosed in the screening arm during long-term followup. The first approach estimates that percentage of screen-detected cancers that are overdiagnosed. The second approach estimates the percentage of all cancer diagnosed during the screening phase that are overdiagnosed. If randomization is not 1:1, as in some ERSPC subsites and in the overall ERSPC trial, appropriate weights to incident cases can be applied to estimate excess incidence if randomization had been 1:1. This methodology has yielded estimates of overdiagnosis in randomized trials of breast and lung cancer screening.^65^–^68^

### Measures of Risk Prediction Model Performance

We abstracted study data on three metrics of risk model performance: discrimination, calibration, and clinical utility. Discrimination, usually expressed as the area under the receiver operator curve (AUC or c statistic), is a measure of the probability that the model will correctly distinguish a case from a non-case (ranging from 0.5 [no better than chance] to 1.0 [perfect discrimination]). We abstracted available data on AUCs both with the risk assessment tool and with PSA alone, allowing judgment of the extent to which the risk assessment tool may improve biopsy recommendations based on PSA alone.

Calibration refers to the extent to which the risk model accurately predicts observed risk. Statistical tests, such as the Hosmer-Lemeshow test, can quantify model fit, but calibration plots directly portray the extent to which model-predicted risk matches observed risk in a population.

Finally, we abstracted available qualitative data from decision curve analyses, which provide information on the expected benefits and harms of applying the risk assessment tools in biopsy decisions at varying pre-biopsy risk thresholds for undergoing biopsy.^69^ In the decision curve analyses, expected benefits are the number of patients with significant prostate cancer who are detected (true-positives), while expected harms are the number of patients without significant prostate cancer who undergo biopsy (weighted based on the probability threshold above which the patient would undergo treatment regardless of biopsy results). A decision curve analysis suggests that use of a risk calculator will yield net benefit at a given pre-biopsy risk threshold if the expected benefits exceed the expected harms (or net harm if expected harms exceed expected benefits).

## Data Synthesis and Analysis

We created separate tables for the results for each KQ and additional summary tables that included key study characteristics. We used these tables and forest plots of results to examine data for consistency, precision, and relationship of effect size with key potential modifiers, such as age or tumor stage.

For all outcomes, we synthesized data descriptively using medians and ranges. We did not perform pooled meta-analyses for outcomes of screening effectiveness (KQ1), screening harms (KQ2) or treatment effectiveness (KQ3) because data derived from relatively few trials, variability in populations and interventions, and varying measures of treatment effectiveness across cohort studies. For commonly reported treatment-related harms (i.e., urinary incontinence and erectile dysfunction), we used DerSimonian-Laird random-effects meta-analyses to estimate pooled relative risks (RRs) of these complications among patient receiving radical prostatectomy or radiation therapy as compared to conservative management. Heterogeneity was first assessed graphically, and if meta-analysis was performed, it was quantified using I^2^. As none of the cohort studies reported adjusted risk estimates, we used raw event rates. We performed sensitivity analyses assessing the potential impact of shorter versus longer followup times within studies and the potential impact of individual studies on observed heterogeneity. When multiple time points were reported within studies, we included the latest time point in meta-analyses. For one study that reported results from the same cohort at 30 to 41 months’ followup^70^ and 10 years’ followup,^71^ we used the earlier data, since it was more complete (n=108 vs. n=54) and pooled estimates using either results were similar in sensitivity analyses. We used pooled RRs to estimate the number of patient needed to be treated for one patient to be affected by harms (NNH); in these calculations, the absolute risk of the complication in actively treated patients was estimated as the product of the pooled RR and the median absolute risk in the conservatively managed control group.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach^72^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^73^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, non-reporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF Web site for public comment from October 29 to November 15, 2015. In response, we expanded the scope of KQs 1 through 4 to include assessment for evidence of differential impact of screening within high-risk subgroups, and a separate group was commissioned to summarize results of statistical modeling studies for the USPSTF. A final version of the research plan was posted on the USPSTF website in April 2016. A draft version of this report was reviewed by invited external experts and federal partners listed in the acknowledgements. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Additionally, a draft of the full report was posted on the USPSTF Web site from April 11 through May 8, 2017. In response to these comments, we included a summary of evidence on the psychological harms of screening. We also included results of studies identified during ongoing literature surveillance through February 2018, including extended followup from the PIVOT trial,^74^ two cohort studies reporting longitudinal outcomes among U.S. men receiving treatment for localized prostate cancer,^75,76^ and three studies of multivariable risk calculators.^77^–^79^

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the USPSTF. The authors consulted with USPSTF members at key points throughout the review process to develop and refine the scope, analytic framework, and KQs; to resolve issues around the review process; and to finalize the evidence synthesis. AHRQ had no role in study selection, quality assessment or synthesis. AHRQ staff provided oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review of content by outside experts, including representatives of professional societies and federal agencies.