# Chapter 1 Introduction

## Condition Definition

Adenocarcinoma accounts for over 95% of all cancers of the prostate gland.^1^ Prostate cancer is staged according to the criteria jointly established by the American Joint Committee on Cancer (AJCC) and the International Union for Cancer Control (IUCC).^2^ This system stages prostate cancer based on the extent of the primary tumor (T), lymph node involvement (N), presence of distant metastases (M), serum prostate specific antigen (PSA) level, and Gleason score (Table 1).^3^ Localized prostate cancer is classified as stages 1 (non-palpable) and 2 (palpable) and is confined within the prostate capsule. According to 2007 to 2013 data from the U.S. Surveillance, Epidemiology, and End Results (SEER) program, the majority of prostate cancer cases (79%) are localized, while 12% involve regional lymph nodes and 5% involve distant metastases (4% unknown stage).^4^ The likelihood of progression from localized to regional or metastatic disease is associated with the presence of more poorly differentiated cells and other histopathologic features, as reflected in the Gleason score (range, 6 [well-differentiated] to 10 [poorly-differentiated]). In addition to staging, risk assessment tools, such as the D’Amico risk classification or the Cancer of the Prostate Risk Assessment (CAPRA) score, are commonly used to categorize cancers as low-, intermediate-, or high-risk on the basis of clinical presentation and other risk factors (i.e., tumor size, Gleason score, PSA level, age).

Table 1 Prostate Cancer Tumor Staging

Stage | T^*^ | N^†^ | M^‡^ | PSA^§^ | Gleason\|\| | Description
I | T1a-c | N0 | M0 | <10 | ≤6 | Clinically unapparent tumor, not palpable or visible by imaging. No regional node involvement and no distant metastasis
I | T2a | N0 | M0 | <10 | ≤6 | Clinically unapparent tumor, not palpable or visible by imaging. No regional node involvement and no distant metastasis
IIa | T1a-c | N0 | M0 | <20 | 7 | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIa | T1a-c | N0 | M0 | ≥10<20 | ≤6 | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIa | T2a | N0 | M0 | ≥10<20 | ≤6 | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIa | T2a | N0 | M0 | <20 | 7 | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIa | T2b | N0 | M0 | <20 | ≤7 | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIb | T2c | N0 | M0 | Any | Any | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIb | T1-2 | N0 | M0 | ≥20 | Any | Tumor confined within the prostate. No regional node involvement and no distant metastasis
IIb | T1-2 | N0 | M0 | Any | ≥8 | Tumor confined within the prostate. No regional node involvement and no distant metastasis
M0 | T3a-b | N0 | M0 | Any | Any | Tumor extends through the prostate capsule. No regional node involvement and no distant metastasis
IV | T4 | N0 | M0 | Any | Any | Tumor is fixed or invades adjacent structures other than seminal vesicles (bladder neck, external sphincter, rectum, levator muscles, and/or pelvic wall)
IV | Any | N1 | M0 | Any | Any | Tumor is fixed or invades adjacent structures other than seminal vesicles (bladder neck, external sphincter, rectum, levator muscles, and/or pelvic wall)
IV | Any | Any | M1 | Any | Any | Tumor is fixed or invades adjacent structures other than seminal vesicles (bladder neck, external sphincter, rectum, levator muscles, and/or pelvic wall)

Source: American Joint Committee on Cancer (AJCC) Cancer Staging Manual, 7^th^ edition

* Primary Tumor (T)

T1a: Tumor incidental histologic finding in <5% of tissue resected

T1b: Tumor incidental histologic finding in >5% of tissue resected

T1c: Tumor identified by needle biopsy (e.g., because of elevated PSA)

T2a: Tumor involves one-half of one lobe or less

T2b: Tumor involves more than one-half of one lobe but not both lobes

T2c: Tumor involves both lobes

T3a: Extracapsular extension (unilateral or bilateral)

T3b: Tumor invades seminal vesicle(s)

T4: Tumor is fixed or invades adjacent structures other than seminal vesicles such as external sphincter, rectum, bladder, levator muscles, and/or pelvic wall

† Regional lymph nodes (N)

N0: No regional lymph node metastasis

N1: Metastasis in regional lymph node(s)

‡ Distant metastasis (M)

M0: No distant metastasis

M1: Distant metastasis

§ PSA serum levels

PSA < 10 ng/nL: low risk

PSA 10-20 ng/nL: intermediate risk

PSA > 20 ng/nL: high risk

|| Gleason score (tumor grading)

Gleason ≤6: Well differentiated

Gleason 7: Moderately differentiated

Gleason 8-10: Poorly differentiated

## Prevalence and Burden of Disease

Prostate cancer is the most commonly diagnosed cancer in American men, with an estimated lifetime risk of approximately 12.9 percent.^4^ Based on SEER data, an estimated 161,360 men will be newly diagnosed with prostate cancer in 2017 (annual incidence rate of 119.8 per 100,000 men),^4^ accounting for 19 percent of new cancer cases in males.^5^ Prostate cancer is diagnosed most often in men ages 55 to 74 years (71% of all new cases), with a median age at diagnosis of 66 years.^4^ The prostate cancer incidence rate is highest among African American men (188.7 cases per 100,000 men), followed by whites (112.8 cases per 100,000 men), Asian/Pacific Islanders (62.9 cases per 100,000 men), and American Indian/Alaska Natives (59.9 cases per 100,000 men). Prostate cancer incidence is higher among non-Hispanic men compared to Hispanics (123.3 vs. 98.3 per 100,000 men, respectively);^4^ however recent studies have shown that, when disaggregated, certain Latino groups (i.e., Cuban and Puerto Rican men) have comparable or slightly higher incidence rates than non-Hispanic whites.^6^

Prostate cancer is the second leading cause of cancer death among U.S. men, and the third leading cause of cancer death in the general population.^7^ The lifetime risk of dying from prostate cancer among U.S. men is 2.5 percent. While the 5-year survival rate among men with localized or regional prostate cancer is nearly 100 percent, the 5-year survival for prostate cancer with distant metastases is 29.8 percent.^4^ Nearly 68 percent of all prostate cancer deaths occur among U.S. men aged 75 years and older, with a median age at death of 80 years.^4^ The prostate cancer death rate is highest among African American men (42.0 deaths per 100,000 men), more than double the prostate cancer death rate of American Indian/Alaska Natives (19.4 per 100,000), whites (18.7 per 100,000), and Asian/Pacific Islanders (8.8 per 100,000).^4^ Because prostate cancer mortality rates are much lower than incidence rates, the large majority of men who are diagnosed with prostate cancer die of causes other than prostate cancer.^4^

## Etiology and Natural History

The etiology of prostate cancer is not completely understood. Men with 5-alpha-reductase deficiency do not develop prostate cancer, suggesting that androgenic hormones play a role in pathogenesis.^8^ The higher incidence in African American men points to genetic or other predispositions that vary by race/ethnicity.

Many prostate cancers never become clinically evident in the absence of screening. In addition, many prostate cancers progress slowly, such that clinically significant progression may not occur during a man’s lifetime. In autopsy studies of men dying of other causes, the prevalence of localized prostate cancer increases with age, from 5 percent in men aged 30 years and younger to 15 percent in men ages 40 to 50 years and 59 percent in men aged 79 years and older.^9^ Tumor grade, typically assessed using the Gleason score, is an important marker of tumor aggressiveness. Tumors that remain localized to the prostate are often asymptomatic but may cause symptoms of bladder outlet obstruction. Tumors that remain localized generally do not affect survival. In contrast, tumors that spread beyond the prostate to invade local structures or metastasize can have severe negative impacts on quality of life and may result in mortality.^10^

## Risk Factors

Prostate cancer risk is associated with both unmodifiable risk factors (e.g., age, race, and genetics)^4,11,12^ and modifiable risk factors (e.g., diet, tobacco use).^13^–^16^ Based on autopsy studies and epidemiological data, prostate cancer risk is strongly tied to both age and race/ethnicity. According to 2010 to 2014 SEER data, men aged 54 years and younger accounted for only an estimated 10 percent of all diagnosed prostate cancer, while men ages 55 to 74 accounted for 71 percent of all cases.^4^ After 75 years of age, the incidence of diagnosed prostate cancer begins to decline (approximately 19% of all new cases),^4^ which may be due in part to reduced PSA-based screening in older men.^17,18^ SEER data also show that the incidence of prostate cancer among African Americans is significantly higher than other racial/ethnic groups. Similarly, African American men have the highest prostate cancer mortality rates,^4^ consistent with earlier age of cancer onset, more advanced cancer stage at diagnosis, and other factors related to poor disease prognosis (i.e., worse Gleason scores, higher serum PSA levels).^19^–^22^ Differential access to care may contribute to lower adherence with diagnostic followup after abnormal PSA screening among African American men compared to white men, potentially contributing to relatively higher prostate cancer mortality among African American men.^23^ Prostate cancer risk is significantly greater among men with one or more first-degree relatives with prostate cancer.^11^ One Scandinavian study of twins estimated that hereditary factors may account for up to 42 percent of prostate cancer risk.^12^ Among modifiable risk factors, diets high in fat and low in vegetable consumption are associated with increased prostate cancer risk.^13^–^15^ While not consistently shown to increase risk of prostate cancer incidence, cigarette smoking is associated with higher risk of prostate cancer mortality.^16^

## Current Clinical Practice in the United States

### Screening Strategies

The purpose of screening for prostate cancer is to identify high-risk, localized prostate cancer that can be successfully treated, thereby preventing the morbidity and mortality associated with advanced or metastatic prostate cancer. Screening for prostate cancer can be done through prostate-specific antigen (PSA) screening, with or without digital rectal examination (DRE). Measuring PSA levels is done through multiple approaches, including single-threshold testing, adjusted threshold testing, velocity, and doubling time.

Single-threshold testing measures serum PSA levels against a single threshold for all men. Age-adjusted thresholds attempt to improve the sensitivity and specificity of PSA testing by raising the threshold in older men (with a goal of reducing the potential for overdiagnosis) and lowering the threshold in younger men (with a goal of increasing the likelihood of early detection).^24^ PSA velocity and PSA doubling time both measure the rate of change in PSA levels, with velocity measuring the change in PSA over time and doubling time measuring the time it takes (usually measured in months) for a certain PSA level to double.^25^

While elevated PSA levels may indicate prostate cancer, elevated PSA levels can also accompany benign conditions, such as benign prostatic hyperplasia and prostatitis.^26^ Also, PSA levels in men without evidence of prostate cancer vary by race/ethnicity,^27^ and race-specific PSA reference ranges have been proposed with the goal of improving sensitivity.^28^

Several adjunctive serum or urinary tests have been developed with the goal of improving the sensitivity or specificity of PSA screening. Appendix F summarizes evidence regarding adjunctive tests that are increasingly used in concert with PSA screening.

### Treatment Approaches

Common therapeutic options for men with localized prostate cancer include both active treatments and conservative approaches.

Active treatment approaches for prostate cancer include surgery (radical prostatectomy), radiation therapy, hormone therapy (i.e., androgen deprivation therapy), or ablation (i.e., cryotherapy and high-intensity focused ultrasound). Radical prostatectomy (RP) is a surgical technique intended to remove all prostate tissue. Radiation therapy (RT), either in the form of external beam radiation therapy (EBRT) or brachytherapy, is typically used for localized, low-risk prostate cancer. External beam radiation therapy uses an external source of radiation to treat the prostate gland and may affect adjacent, healthy tissue. Brachytherapy implants a radioactive source within the prostate gland with the goal of reducing radiation exposure to adjacent, healthy tissue.^29^ Androgen deprivation therapy (ADT), typically used in combination with other treatments rather than as monotherapy, reduces the levels of male hormones, or androgens (e.g., testosterone and dihydrosterone) in order to shrink the tumors or cause the tumor to grow more slowly.^30^ Neo-adjuvant ADT is provided prior to other active treatments, such as RP or EBRT, with the goal of improving the chances of complete tumor eradication. Cryotherapy is a form of ablation that is applied to the entire prostate gland or a specific portion affected by the tumor and destroys the prostate tissue through freezing. High-intensity focused ultrasound (HIFU) is another form of ablative therapy that destroys the prostate tissue by generating local thermal energy.^29^

Active surveillance and watchful waiting are both conservative approaches that involve postponing immediate treatment.^31^ Active surveillance (AS) involves deferring treatment indefinitely unless evidence of disease progression is uncovered during regular monitoring with physical examination, serial PSA, or repeat biopsy. The goal of active surveillance is to avert or postpone treatment-related harms among men with indolent cancers or with cancer that may not progress during their lifetimes. Optimal candidates for active surveillance are older men with low-risk tumors who have life expectancies exceeding 10 to 15 years.^32^ In contrast, watchful waiting involves no immediate treatment with the provision of palliative therapies if and when patients become symptomatic. Watchful waiting is typically recommended for men who are unlikely to benefit from active treatments due to limited life expectancy.^31^

Factors influencing treatment choice include the likelihood of cancer metastasis or recurrence (based on tumor characteristics) as well as patient age, comorbidities, life expectancy, patient preferences, and clinical practice. A study of U.S. veterans with screen-detected prostate cancer diagnosed in 2003 (n=5,220)^33^ found that men were more likely to receive curative treatments (58%) rather than hormone therapy (24%) or no treatment (18%). In an analysis of U.S. men with early-stage prostate cancer (n=11,892) diagnosed between 1990 and 2007, most men selected RP (49.9%) or RT (24.9% [EBRT, 11.6%, brachytherapy, 13.3%]), followed by primary ADT (14.4%) and cryotherapy (4.0%); comparatively, only 6.8 percent of men chose a surveillance-based treatment approach.^34^ HIFU is currently rarely employed in U.S. practice.

Although conservative, surveillance-based approaches (i.e., active surveillance or watchful waiting) are less common than active treatment for early-stage prostate cancer, several recent assessments indicate that initial use of conservative approaches is rapidly increasing.^34^–^39^ In a consortium of 45 U.S. urology practices, use of surveillance for men with low-risk prostate cancer has increased sharply (from ~10% in 2005–2009 to 40.4% in 2010–2013).^40^ Nevertheless, approximately half of men diagnosed with low-risk prostate cancer in 2010–2013 received RP.^40^ Among men aged 75 years and older, active surveillance or watchful waiting was used in over three-quarters of men with low-risk prostate cancer from 2010–2013 (76.2%).^40^

### Clinical Guidelines

Prostate cancer screening recommendations from other groups are summarized in Table 2. The American Academy of Family Physicians (AAFP),^41^ American College of Preventive Medicine (ACPM),^42^ and the Canadian Task Force on Preventive Health Care^43^ recommend against routine, population-based screening for prostate cancer. Strategies based on shared decision-making and individualized screening based on patient risk are recommended by the ACPM, the European Association of Urology (EAU),^44^ the American College of Physicians (ACP), the American Cancer Society (ACS)^45^ and the American Urological Association (AUA).^17^ The National Comprehensive Cancer Network (NCCN) recommends that clinicians perform screening PSA on men aged 45 to 75 years, and that the frequency of subsequent screening based on baseline PSA or DRE results (if performed).^46^ The ACS and ACPM include specific recommendations for African American men or those with a family history of prostate cancer; ACS recommends that these men should discuss screening with their doctor between ages 40 and 45 years, while ACPM emphasizes that clinicians provide information about the benefits and harms of screening and that the choice to screen should be individualized. A recent review of national survey data from 2013 found that PSA-based screening decreased from 31.8 percent in 2008 to 24.2 percent in 2013 among U.S. men. Additionally, between 2010 and 2013, decreases were observed among all screening-relevant age groups: PSA testing decreased from 33.2 percent to 24.8 among men ages 50 to 59 years, 51.2 percent to 43.6 percent for men 60 to 74 years, and 43.9 percent to 37.1 percent for men 75 years and older.^18^

Table 2 Recommendations From Other Groups

Organization, year | Population | Recommendation
American Academy of Family Physicians, 2012^41^ | Asymptomatic men | Adopts the U.S. Preventive Services Task Force 2012 recommendation, which recommended against prostate-specific antigen (PSA)-based screening for prostate cancer
American Cancer Society, 2016^45^ | Asymptomatic men | Recommends that men make an informed decision with their doctor about whether to be tested for prostate cancer. Recommends that men should not be tested without learning about the uncertainties, risks and potential benefits of screening. Starting at age 50 years, men with a life expectancy of more than 10 years should talk to their doctor about the pros and cons of testing so they can decide if testing is the right choice for them. African American men or men with a father or brother who had prostate cancer before age 65 years should have this talk with their doctor starting at age 45 years. Men with more than one first-degree relative (father, brother) who had prostate cancer before age 65 should have this talk with their doctor starting at age 40 years. Men who choose to be screened should be tested with the PSA blood test (a DRE may also be performed as part of screening). Men whose PSA test result is less than 2.5 ng/mL may only need to be retested every 2 years; screening should be done on an annual basis for men whose PSA levels is 2.5 ng/mL or higher.
American College of Physicians, 2013^217^ | Asymptomatic men | For men ages 50 to 69 years, the decision to be screened for prostate cancer should be made after discussions with their physicians about the benefits and harms of screening, the patient’s preferences, and their general health and life expectancy. Only recommends screening for men between the ages of 50 and 69 years with a life expectancy greater than 10 to 15 years.
American College of Preventive Medicine, 2008^42^ | Asymptomatic men | Insufficient evidence to recommend routine population screening with DRE or PSA. Clinicians caring for men, especially African American men and those with positive family histories should provide information about potential benefits and risks of prostate cancer screening, and the limitations of current evidence for screening, in order to maximize informed decision making.
American Urological Association, 2013^17^ | Asymptomatic men | Recommends that men ages 55 to 69 years should discuss the benefits and harms of screening with their physician and that the decision to screen be reached through shared decision-making, taking into account men’s values and preferences. For African American men or those with a positive family history who are also younger than 55 years of age, decisions about screening should be individualized.
Canadian Task Force on Preventive Health Care, 2014^43^ | Asymptomatic men | Recommends against screening for prostate cancer with the PSA test at any age.
European Association of Urology, 2017^43^ | Asymptomatic men | Recommends individualized screening strategy based on patient risk and shared decision making for men with at least 10 to 15 years life expectancy.
National Comprehensive Cancer Network, 2016^218^ | Asymptomatic men | Recommends discussing risks and benefits of baseline PSA and DRE in previously unscreened men aged 45 and older with subsequent screening or diagnostic evaluation based on the results of these tests. For men over age 75 years, screening can be cautiously considered among men with little or no comorbidity.,

## Previous USPSTF Recommendation

In 2012, the USPSTF concluded that there was sufficient evidence to recommend against PSA-based screening for prostate cancer in men in all age groups (D recommendation). The USPSTF found convincing evidence that PSA-based screening programs result in the detection of many cases of asymptomatic prostate cancer, and that a substantial percentage of men who have asymptomatic cancer detected by PSA screening have a tumor that either will not progress or will progress so slowly that it would have remained asymptomatic for the man’s lifetime.

The USPSTF found that the benefits of PSA-based screening for prostate cancer did not outweigh the harms. Clinical trials indicated that the reduction in prostate cancer mortality 10 years after PSA-based screening was, at most, very small, even for men aged 55 to 69 years. The harms of PSA screening include pain, fever, bleeding, infection, and transient urinary difficulties associated with prostate biopsy, psychological harm from false-positive test results, and harms related to overdiagnosis, such as treatment of prostate cancer that would not cause symptoms. Harms of treatment were noted to include erectile dysfunction, urinary incontinence, bowel dysfunction, and a small risk of premature death. Because of the inability to reliably distinguish tumors that remain indolent from those destined to be lethal, the harms of treatment would affect men with screen-detected cancers that would never have become symptomatic.