# Appendix F New Adjunctive Testing Strategies

## Adjunctive Testing Performed with PSA-Based Screening

National Comprehensive Cancer Network (NCCN) guidelines suggest one of the following tests as options to risk stratify men with PSA values from 3 to 10 ng/dL before biopsy with the potential benefit of reducing total biopsies and overtreatment of lower-risk cancers.^46^ The tests can also be employed after negative biopsy to assist in decision-making regarding repeat biopsy.

### Free PSA

The ratio of free PSA/total PSA is recommended by the NCCN as a reflex testing option for men with elevated PSA.^46^ Lower levels of free PSA are associated with higher risk for high-grade prostate cancer. The percent free PSA is also a component of the 4kScore and the Prostate Health Index (see below). The Prostate Cancer Prevention Trial (PCPT) risk calculator has also been adapted to include free PSA, if available.

### 4Kscore

The 4Kscore is generated by a prediction model original based on data from the ERSPC trial. It estimates the patient’s risk of biopsy detectable prostate cancer with a Gleason score ≥7. The score includes both clinical variables (age, prior biopsy, and digital rectal exam results) with total and free PSA, intact PSA and Human kallikrein 2 (hK2). A recent prospective U.S. study of 1,012 men suggested that, compared to the PCPT risk calculator, the 4Kscore improved the area under the curve (AUC) from 0.74 to 0.82.^58^

### Prostate Health Index (PHI)

The PHI is a blood test combining total PSA, free PSA and p2PSA (a precursor PSA isoform). It was approved by the FDA in 2012. A 2014 systematic review and meta-analysis of studies evaluating the diagnostic characteristics of PHI for detection of prostate cancer with a Gleason Score >= 7 found a pooled specificity of 0.45 and an AUC of 0.72.^221^ A subsequently published retrospective cohort of 250 men found an AUC of 0.78 for PHI compared with an AUC of 0.70 for total PSA for detection of prostate cancer with a Gleason score ≥ 7.^222^

## Adjunctive testing in conjunction with biopsy to decide on further treatment or follow up

These tests may be used to improve sensitivity of detection of prostate cancer in men with negative biopsies or biopsies showing high-grade prostatic intra-epithelial neoplasia. The free PSA, 4Kscore, and PHI are also sometimes used in this context. In addition, biomarkers are sometimes used to help inform decisions on treatment versus active surveillance for men with lower risk of prostate cancer.^223^

### PCA3

PCA3 is a noncoding mRNA overexpressed in prostate cancer tissue. It can be detected in the urine following vigorous digital rectal exam and is used for men with previous negative prostate biopsies when repeat biopsy is being considered. The ratio of PCA3 to PSA transcripts yields the PCA3 score, which is used to predict the presence of prostate cancer. PCA3 is FDA-approved for the determination of the need for repeat biopsy among men with a prior negative biopsy. In men who are considered to be at elevated risk but who have a negative biopsy, the NCCN recommends consideration of PCA3 testing (or free PSA, 4Kscore, or PHI).^46^

### ConfirmMDx

Confirm MDx, a methylation marker genetic test performed on cells from a prostate biopsy sample, has been found in initial studies to have a high negative predictive value, providing decision support to reduce repeated prostate biopsies.^224^

### Prolaris

A cell cycle suppression score, Prolaris is based on a 31-gene panel of cell cycle-related genes identified in prostate cancer tissue. It has been associated with the risk of subsequent metastatic disease. It has been approved by the FDA for use in treatment planning for low-risk men with a Gleason score of 6 on prostate biopsy, and for patients who are post-radical prostatectomy and are considered at high risk for prostate cancer recurrence.

### Oncotype Dx Genomic Prostate Score (GPS)

Oncotype Dx GPS is a 17-gene RT-PCR-based panel, including 12 prostate cancer-related genes and 5 control genes. Oncotype Dx GPS is used to provide treatment decision support for men with a low- to intermediate-risk prostate cancer Gleason score on biopsy, or after radical prostatectomy.^223^ While not FDA-approved, the test is covered by Medicare for men who meet specific criteria.

## Imaging testing performed in conjunction with biopsy

When a prostate biopsy is planned to evaluate an abnormal PSA test, the standard method is a transrectal ultrasound (TRUS) guided series of core needle biopsies.^46^ Multiparametric MRI is now used at some centers for evaluation of men with high clinical suspicion of prostate cancer and a negative biopsy. Multiparametric MRI of the prostate has been advocated as a preliminary test prior to initial biopsy to evaluate for suspicious lesions, with goals of improving both sensitivity (finding more prostate cancers with Gleason score ≥7) and improving specificity (reducing the rates of negative biopsies and biopsies identifying lower Gleason score cancers).^225^ Using software, MRI is also increasingly combined with TRUS (MRI-TRUS “fusion”) to allow targeted biopsy. Studies have yielded mixed results,^204^–^209^ with MRI detecting some higher grade cancers missed by TRUS, but some have expressed concerns that MRI alone can miss Gleason 6 cancers.^46^ An international multi-site randomized trial is currently in process,^226^ recruiting men with clinical suspicion of prostate cancer and no previous prostate biopsy. The trial compares multiparametric MRI targeted biopsy (with no biopsy in the absence of suspicious lesion) to standard 12-core TRUS-guided prostate biopsy. Recruitment began in early 2016 and the trial is planned to be complete in fall of 2017.