# Appendix E Additional Evidence Tables

Appendix E Table 1 Use of PSA by Study Arm During the Screening Phase of the PLCO Trial

Time period of latest test | Study Arm
Time period of latest test | Control^*^ | | Screening^†^
Time period of latest test | Routine Screening PSA, % | PSA for Any Purpose, % | Routine Screening, %
<1 year | 46 | 52 | 78
1-2 years | 14 | 16 | 8
2-3 years | 5 | 6 | 3
>3 years | 4 | 4 | 2
Never tested for any reason | 21 | | 9

Note: table adapted from Pinsky et al (2010)

* Based on annual surveys of control arm subjects during years 0 to 5 of the trial (N=2225; range per study year 181–435)

† Based on adherence to trial screening protocol

Appendix E Table 2 Initial Non-Metastatic Prostate Cancer Treatment by Study Arm and Clinical Risk Group at Diagnosis Among ERSPC Participants

Initial Treatment | Risk Group^*^ | | | | | | Overall (n=8,010)
Initial Treatment | Low Risk | | Intermediate Risk | | High Risk | | Overall (n=8,010)
Initial Treatment | Screening, % (n=2,766) | Control, % (n=873) | Screening, % (n=1,319) | Control, % (n=976) | Screening, % (n=1,027) | Control, % (n=1,049) | Screening, % (n=5,112) | Control, % (n=2,898)
Radical prostatectomy | 39.7 | 39.2 | 50.3 | 41.3 | 34.2 | 19.6 | 41.3 | 32.8
Radiation therapy | 25.1 | 28.2 | 31.8 | 37.4 | 47.0 | 45.9 | 31.1 | 37.7
Hormonal therapy | 2.0 | 3.9 | 6.4 | 8.0 | 14.7 | 29.5 | 5.7 | 14.5
Conservative management^†^ | 33.1 | 28.8 | 11.6 | 13.3 | 4.1 | 5.1 | 21.7 | 15.0

* Low risk prostate cancers were defined as stage<=T2a, PSA<10 ng/mL, and Gleason < 7. High-risk cancers were stage>=T2c, PSA>20 ng/mL, or Gleason>=8. All other cancers were intermediate risk (i.e., stage T2b, PSA 10-20 ng/mL, Gleason=7).

† Conservative management includes active surveillance, watchful waiting, or no treatment.

Appendix E Table 3 Definitions of Clinical Risk in Prostate Cancer Screening Trials

Trial Name | Location | Low Risk | Intermediate Risk | High Risk | Advanced/Metastatic
PLCO | United States | NA | NA | NA | NA
ERSPC | Europe (Netherlands, Belgium, Sweden, Finland, Italy, Spain, Switzerland, France, Portugal) | Clinical stage T1-2 and Gleason score <6 | Clinical stage T1-2 and Gleason score 7 OR clinical stage T3 and Gleason score ≤7 | Clinical stage T1-3 and Gleason score 8-10 OR clinical stage T4 and any Gleason score | M1 or PSA>100ng/mL
ERSPC | Goteborg (Sweden) | T1, not N1 or M1, Gleason score ≤6, and PSA <10 ng/mL | T1-2, not N1 or M1, and Gleason score ≤7 and/or PSA <20 ng/mL | T1-4, not N1 or M1, and Gleason score ≥8 and/or PSA < 100 ng/mL | N1 and/or M1 and/or PSA ≥100 ng/mL
ERSPC | Madrid (Spain) | NA | NA | NA | NA
ERSPC | Rotterdam (Netherlands) | Clinical stage T1 or T2 with Gleason score ≤6 | Clinical stage T1 or T2 with Gleason score 7, or T3 with Gleason score ≥7 | Clinical stage T1, T2 or T3 with Gleason score 8-10 or clinical stage T4 with any Gleason score | Any clinical stage or Gleason score with M1 found at imaging and/or PSA ≥ 100
ERSPC | Finland | T1 to T2 and Gleason score ≤6 | T1 to T2 and Gleason score 7 or T3 with a Gleason score ≤7 | T1 to T3 and Gleason score 8-10 or T4 or M1 or N1 (with any Gleason score) | T3 to T4, M1 or N1

Appendix E Table 4 Positive Predictive Value of Biopsy Based on Prostate Cancer Screening Trials

| ERSPC | PLCO
Randomized to screening | 72,891 men | 35,870
Positive PSA test | 23,574 men | 10,798
Underwent biopsy | 20,188 men | 4,836
Prostate cancer detected | 4,883 men | 1,562
Positive predictive value (PPV) | 24.2% | 32.3%

Appendix E Table 5 Prostate Cancer Mortality by ERSPC Site

Site/Group | Median Followup (years) | Prostate Cancer Mortality RR (95% CI)
Sweden, ERSPC core-age group (n=11,852, ages 55 to 69 years) | 13.0 | 0.62 (0.41 to 0.92)
Netherlands | 13.0 | 0.67 (0.51 to 0.88)
Finland | 13.0 | 0.91 (0.75 to 1.10)
Spain | 13.0 | 0.54 (0.10 to 2.94)
Belgium | 13.0 | 0.77 (0.41 to 1.42)
Italy | 13.0 | 0.81 (0.48 to 1.35)
Switerland | 13.0 | 1.14 (0.56 to 2.33)
All sites, core age group (ages 55 to 69 years) | 13.0 | 0.79 (0.69 to 0.91)

* p=0.43 for test of heterogeneity across all sites (core age group, 13 year followup for all sites)

Appendix E Table 6 Raw SF-36 Scores for Radical Prostatectomy Compared With Conservative Management^*^

| | Donovan, 2016^144^ RCT (6.0 years) | Barocas, 2017 Cohort (3.0 years)^75^ | Smith, 2009^159^ Cohort (3.8 years) | | Bacon, 2001^139^ Cohort (5.0 years) | Schapira, 2001^156^ Cohort (1.0 years) | Litwin, 2002^151^ Cohort (2.0 years) | Smith, 20001^60^ Cohort (3.8 years) | Lubeck, 1999^152^ Cohort (2.0 years) | Litwin, 1995^150^ Cohort (6.0 years) | Median Diff. (range)
| | Donovan, 2016^144^ RCT (6.0 years) | Barocas, 2017 Cohort (3.0 years)^75^ | Nerve Sparing | Non-nerve Sparing | Bacon, 2001^139^ Cohort (5.0 years) | Schapira, 2001^156^ Cohort (1.0 years) | Litwin, 2002^151^ Cohort (2.0 years) | Smith, 20001^60^ Cohort (3.8 years) | Lubeck, 1999^152^ Cohort (2.0 years) | Litwin, 1995^150^ Cohort (6.0 years) | Median Diff. (range)
Physical Component Summary Score | RP | 48.8 | NR | 50.1 | 48.7 | NR | 52.0 | NR | NR | NR | NR | 2.5 (1.8 to 3.2)
Physical Component Summary Score | CM | 46.9 | NR | 46.9 | 46.9 | NR | 49.0 | NR | NR | NR | NR | 2.5 (1.8 to 3.2)
Physical Component Summary Score | Diff | 1.9 | NR | 3.2 | 1.8 | NR | 3.0 | NR | NR | NR | NR | 2.5 (1.8 to 3.2)
Mental Component Summary Score | RP | 53.5 | NR | 53.3 | 53.7 | NR | 55.0 | NR | NR | NR | NR | 0.3 (0.0 to 0.6)
Mental Component Summary Score | CM | 53.0 | NR | 53.1 | 53.1 | NR | 55.0 | NR | NR | NR | NR | 0.3 (0.0 to 0.6)
Mental Component Summary Score | Diff | 0.5 | NR | 0.2 | 0.6 | NR | 0.0 | NR | NR | NR | NR | 0.3 (0.0 to 0.6)
Physical Function | RP | NR | 86.7 | NR | NR | NR | 90.0 | 87.0 | 84.4 | 85.8 | 74.9 | 8.6 (2.0 to 16.8)
Physical Function | CM | NR | 84.0 | NR | NR | NR | 79.0 | 85.0 | 67.6 | 70.8 | 70.8 | 8.6 (2.0 to 16.8)
Physical Function | Diff | NR | 2.7 | NR | NR | NR | 11.0 | 2.0 | 16.8 | 15.0 | 4.1 | 8.6 (2.0 to 16.8)
Physical Role Function | RP | NR | NR | NR | NR | NR | 86.0 | 78.0 | 72.2 | 72.3 | 60.5 | 5.3 (−2.0 to 9.5)
Physical Role Function | CM | NR | NR | NR | NR | NR | 85.0 | 80.0 | 64.0 | 62.8 | 55.2 | 5.3 (−2.0 to 9.5)
Physical Role Function | Diff | NR | NR | NR | NR | NR | 1.0 | −2.0 | 8.2 | 9.5 | 5.3 | 5.3 (−2.0 to 9.5)
Bodily Pain | RP | NR | NR | NR | NR | NR | 85.0 | 82.0 | 78.3 | 84.4 | 77.0 | 4.0 (−5.0 to 10.2)
Bodily Pain | CM | NR | NR | NR | NR | NR | 81.0 | 87.0 | 68.1 | 76.1 | 73.5 | 4.0 (−5.0 to 10.2)
Bodily Pain | Diff | NR | NR | NR | NR | NR | 4.0 | −5.0 | 10.2 | 8.3 | 3.5 | 4.0 (−5.0 to 10.2)
General Health | RP | NR | NR | NR | NR | NR | 80.0 | 76.0 | 70.9 | 74.6 | 65.2 | 5.0 (2.2 to 20.8)
General Health | CM | NR | NR | NR | NR | NR | 71.0 | 71.0 | 68.4 | 53.8 | 63.0 | 5.0 (2.2 to 20.8)
General Health | Diff | NR | NR | NR | NR | NR | 9.0 | 5.0 | 2.5 | 20.8 | 2.2 | 5.0 (2.2 to 20.8)
Vitality | RP | NR | 70.9 | NR | NR | 73.0 | 71.0 | 67.0 | 68.7 | 70.9 | 60.0 | 4.5 (−2.0 to 13.8)
Vitality | CM | NR | 70.2 | NR | NR | 66.0 | 68.0 | 69.0 | 59.6 | 57.1 | 60.0 | 4.5 (−2.0 to 13.8)
Vitality | Diff | NR | 0.7 | NR | NR | 7.0 | 3.0 | −2.0 | 9.1 | 13.8 | 0.0 | 4.5 (−2.0 to 13.8)
Social Function | RP | NR | NR | NR | NR | 100.0 | 92.0 | 90.0 | 88.0 | 88.8 | 80.3 | 2.0 (−2.0 to 11.0)
Social Function | CM | NR | NR | NR | NR | 89.0 | 87.0 | 92.0 | 86.0 | 77.9 | 80.1 | 2.0 (−2.0 to 11.0)
Social Function | Diff | NR | NR | NR | NR | 11.0 | 5.0 | −2.0 | 2.0 | 10.9 | 0.2 | 2.0 (−2.0 to 11.0)
Emotional Role Function | RP | NR | 81.7 | NR | NR | 94.0 | 90.0 | 86.0 | 82.7 | 84.4 | 70.2 | 4.7 (−5.0 to 12.8)
Emotional Role Function | CM | NR | 82.1 | NR | NR | 86.0 | 90.0 | 91.0 | 77.3 | 72.5 | 57.4 | 4.7 (−5.0 to 12.8)
Emotional Role Function | Diff | NR | −0.4 | NR | NR | 8.0 | 0.0 | −5.0 | 5.4 | 11.9 | 12.8 | 4.7 (−5.0 to 12.8)
Mental Health | RP | NR | NR | NR | NR | 85.0 | 84.0 | 81.0 | 77.1 | 86.0 | 75.7 | 0.0 (−4.0 to 10.1)
Mental Health | CM | NR | NR | NR | NR | 83.0 | 81.0 | 81.0 | 82.0 | 75.9 | 77.2 | 0.0 (−4.0 to 10.1)
Mental Health | Diff | NR | NR | NR | NR | 1.0 | −4.0 | 4.0 | −1.0 | 10.1 | −1.5 | 0.0 (−4.0 to 10.1)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: CM=conservative management; Diff=difference; RP=radical prostatectomy; NR=not reported

Appendix E Table 7 Raw PCI Scores for Radical Prostatectomy Compared With Conservative Management^*^

| | Smith, 2009^159^ (nerve sparing) Cohort (3.8 years) | Smith, 2009^159^ (non-nerve sparing) Cohort (3.8 years) | Bacon, 2001^139^ Cohort (5.0 years) | Schapira, 2001^156^ Cohort (1.0 years) | Smith, 2000^160^ Cohort (3.8 years) | Lubeck, 1999^152^ Cohort (2.0 years) | Litwin, 1995^150^ Cohort (6.0 years) | Median Difference (range)
Urinary Function | RP | 85.5 | 83.3 | 76.0 | 62.0 | 75.0 | 70.7 | 65.0 | -17.0 (-30 to -6.0)
Urinary Function | CM | 91.6 | 91.6 | 93.0 | 92.0 | 94.0 | 87.4 | 86.0 | -17.0 (-30 to -6.0)
Urinary Function | Diff | -6.1 | -8.3 | -17.0 | -30.0 | -19.0 | -16.7 | -21.0 | -17.0 (-30 to -6.0)
Urinary Bother | RP | 84.8 | 83.1 | 82.0 | 67.0 | 78.0 | 80.7 | 68.0 | -7.0 (-17.0 to 0.7)
Urinary Bother | CM | 84.1 | 84.1 | 89.0 | 84.0 | 88.0 | 83.6 | 80.0 | -7.0 (-17.0 to 0.7)
Urinary Bother | Diff | 0.7 | -1.0 | -7.0 | -17.0 | -10.0 | -2.9 | -12.0 | -7.0 (-17.0 to 0.7)
Sexual Function | RP | 34.7 | 22.0 | 26.0 | 20.0 | 26.0 | 26.8 | 19.0 | -22.0 (-34.0 to -2.0)
Sexual Function | CM | 44.1 | 44.1 | 54.0 | 36.0 | 60.0 | 29.1 | 41.0 | -22.0 (-34.0 to -2.0)
Sexual Function | Diff | -9.4 | -22.1 | -28.0 | -16.0 | -34.0 | -2.3 | -22.0 | -22.0 (-34.0 to -2.0)
Sexual Bother | RP | 52.2 | 53.6 | 43.0 | 29.0 | 34.0 | 46.7 | 13.0 | -24.0 (-35.0 to 21.8)
Sexual Bother | CM | 65.9 | 65.9 | 74.0 | 62.0 | 69.0 | 24.9 | 37.0 | -24.0 (-35.0 to 21.8)
Sexual Bother | Diff | -13.7 | -12.3 | -31.0 | -33.0 | -35.0 | 21.8 | -24.0 | -24.0 (-35.0 to 21.8)
Bowel Function | RP | 88.1 | 88.5 | 86.0 | 88.0 | NR | 88.1 | 82.0 | 0.2 (0.5 to 2.0)
Bowel Function | CM | 86.7 | 86.7 | 91.0 | 86.0 | NR | 89.1 | 84.0 | 0.2 (0.5 to 2.0)
Bowel Function | Diff | 1.4 | 1.8 | -5.0 | 2.0 | NR | -1.0 | -2.0 | 0.2 (0.5 to 2.0)
Bowel Bother | RP | 90.0 | 90.5 | 86.0 | 86.0 | NR | 90.2 | 80.0 | 1.1 (-5.0 to 5.0)
Bowel Bother | CM | 88.1 | 88.1 | 89.0 | 81.0 | NR | 90.0 | 85.0 | 1.1 (-5.0 to 5.0)
Bowel Bother | Diff | 1.9 | 2.4 | -3.0 | 5.0 | NR | 0.2 | -5.0 | 1.1 (-5.0 to 5.0)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: CM=conservative management; Diff=difference; RP=radical prostatectomy; NR=not reported

Appendix E Table 8 Raw SF-36 Scores for Radiation Therapy Compared With Conservative Management^*^

| | Barocas, 2017 Cohort (3.0 years)^75^ | Donovan, 2016^144^ RCT (6.0 years) | Thong, 2010^161^ Cohort (5-10 years) | Smith, 2009^159^ (EBRT) Cohort (3.8 years) | Smith, 2009^159^ (LD brachy) Cohort (3.8 years) | Smith, 2009^159^ (HD brachy) Cohort (3.8 years) | Litwin, 2002^151^ Cohort (2.0 years) | Bacon, 2001^139^ (EBRT) Cohort (5.0 years) | Bacon, 2001^139^ (brachy) Cohort (5.0 years) | Schapira, 2001^156^ Cohort (1.0 years) | Smith, 2000^160^ Cohort (3.8 years) | Lubeck, 1999^152^ Cohort (2.0 years) | Litwin, 1995^150^ Cohort (6.0 years) | Median Diff (range)
Physical Component Summary Score | RP | NR | 48.4 | 42.0 | 46.5 | 49.0 | 48.5 | NR | 49.0 | 51.0 | NR | NR | NR | NR | 1.5 (−3.0 to 2.1)
Physical Component Summary Score | CM | NR | 46.9 | 45.0 | 46.9 | 46.9 | 46.9 | NR | 49.0 | 49.0 | NR | NR | NR | NR | 1.5 (−3.0 to 2.1)
Physical Component Summary Score | Diff | NR | 1.5 | −3.0 | −0.4 | 2.1 | 1.6 | NR | 0.0 | 2.0 | NR | NR | NR | NR | 1.5 (−3.0 to 2.1)
Mental Component Summary Score | RP | NR | 53.8 | 50.0 | 52.9 | 54.0 | 51.5 | NR | 53.0 | 54.0 | NR | NR | NR | NR | −0.2 (−1.6 to 0.9)
Mental Component Summary Score | CM | NR | 53.0 | 47.9 | 53.1 | 53.1 | 53.1 | NR | 55.0 | 55.0 | NR | NR | NR | NR | −0.2 (−1.6 to 0.9)
Mental Component Summary Score | Diff | NR | 0.8 | 2.1 | −0.2 | 0.9 | −1.6 | NR | −2.0 | −1.0 | NR | NR | NR | NR | −0.2 (−1.6 to 0.9)
Physical Function | RP | 74.5 | NR | 62.0 | NR | NR | NR | NR | 83.0 | 90.0 | 57.6 | 80.0 | 65.1 | 74.0 | −3.7 (−18.0 to 11.0)
Physical Function | CM | 84.0 | NR | 80.0 | NR | NR | NR | NR | 79.0 | 79.0 | 67.6 | 85.0 | 70.8 | 70.8 | −3.7 (−18.0 to 11.0)
Physical Function | Diff | −9.5 | NR | −18.0 | NR | NR | NR | NR | 4.0 | 11.0 | −10.0 | −5.0 | −5.7 | 3.2 | −3.7 (−18.0 to 11.0)
Physical Role Function | RP | NR | NR | 56.0 | NR | NR | NR | NR | 72.0 | 79.0 | 42.0 | 71.0 | 55.4 | 55.6 | −7.4 (−22.0 to 0.4)
Physical Role Function | CM | NR | NR | 57.0 | NR | NR | NR | NR | 85.0 | 85.0 | 64.0 | 80.0 | 62.8 | 55.2 | −7.4 (−22.0 to 0.4)
Physical Role Function | Diff | NR | NR | −1.0 | NR | NR | NR | NR | −13.0 | −6.0 | −22.0 | −9.0 | −7.4 | 0.4 | −7.4 (−22.0 to 0.4)
Bodily Pain | RP | NR | NR | 70.0 | NR | NR | NR | NR | 79.0 | 81.0 | 61.2 | 82.0 | 73.8 | 74.0 | −2.3 (−7.0 to 0.5)
Bodily Pain | CM | NR | NR | 77.0 | NR | NR | NR | NR | 81.0 | 81.0 | 68.1 | 87.0 | 76.1 | 73.5 | −2.3 (−7.0 to 0.5)
Bodily Pain | Diff | NR | NR | −7.0 | NR | NR | NR | NR | −2.0 | 0.0 | −6.9 | −5.0 | −2.3 | 0.5 | −2.3 (−7.0 to 0.5)
General Health | RP | NR | NR | 60.0 | NR | NR | NR | NR | 74.0 | 78.0 | 59.2 | 70.0 | 53.9 | 66.5 | 1.0 (−9.2 to 7.0)
General Health | CM | NR | NR | 59.0 | NR | NR | NR | NR | 71.0 | 71.0 | 68.4 | 71.0 | 53.8 | 63.0 | 1.0 (−9.2 to 7.0)
General Health | Diff | NR | NR | 1.0 | NR | NR | NR | NR | 3.0 | 7.0 | −9.2 | −1.0 | 0.1 | 3.5 | 1.0 (−9.2 to 7.0)
Vitality | RP | 65.2 | NR | 62.0 | NR | NR | NR | 73.0 | 64.0 | 66.0 | 54.6 | 65.0 | 54.1 | 61.4 | −2.0 (−5.0 to 7.0)
Vitality | CM | 70.2 | NR | 65.0 | NR | NR | NR | 66.0 | 68.0 | 68.0 | 59.6 | 69.0 | 57.1 | 60.0 | −2.0 (−5.0 to 7.0)
Vitality | Diff | −5.0 | NR | −3.0 | NR | NR | NR | 7.0 | −4.0 | −2.0 | −5.0 | −4.0 | −3.0 | 1.4 | −2.0 (−5.0 to 7.0)
Social Function | RP | NR | NR | 81.0 | NR | NR | NR | 86.0 | 87.0 | 92.0 | 58.9 | 88.0 | 76.9 | 81.3 | −0.5 (−27.1 to 5.0)
Social Function | CM | NR | NR | 79.0 | NR | NR | NR | 89.0 | 87.0 | 87.0 | 86.0 | 92.0 | 77.9 | 80.1 | −0.5 (−27.1 to 5.0)
Social Function | Diff | NR | NR | 2.0 | NR | NR | NR | −3.0 | 0.0 | 5.0 | −27.1 | −4.0 | −1.0 | 1.2 | −0.5 (−27.1 to 5.0)
Emotional Role Function | RP | 80.3 | NR | 78.0 | NR | NR | NR | 81.0 | 82.0 | 86.0 | 70.2 | 85.0 | 75.8 | 75.6 | −0.4 (−8.0 to 18.2)
Emotional Role Function | CM | 82.1 | NR | 71.0 | NR | NR | NR | 86.0 | 90.0 | 90.0 | 77.3 | 91.0 | 72.5 | 57.4 | −0.4 (−8.0 to 18.2)
Emotional Role Function | Diff | −1.8 | NR | 7.0 | NR | NR | NR | −5.0 | −8.0 | −4.0 | −7.1 | −6.0 | 3.3 | 18.2 | −0.4 (−8.0 to 18.2)
Mental Health | RP | NR | NR | 73.0 | NR | NR | NR | 75.0 | 81.0 | 84.0 | 76.4 | 82.0 | 77.6 | 78.7 | 0.5 (−6.0 to 1.7)
Mental Health | CM | NR | NR | 77.0 | NR | NR | NR | 81.0 | 83.0 | 83.0 | 81.3 | 82.0 | 75.9 | 77.2 | 0.5 (−6.0 to 1.7)
Mental Health | Diff | NR | NR | −4.0 | NR | NR | NR | −6.0 | −2.0 | 1.0 | −4.9 | 0.0 | 1.7 | 1.5 | 0.5 (−6.0 to 1.7)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: Brachy=brachytherapy; CM=conservative management; Diff=difference; EBRT=external beam radiation therapy; HD=high dose; LD=low dose; RT=radiation therapy; NR=not reported

Appendix E Table 9 Raw PCI Scores for Radiation Therapy Compared With Conservative Management^*^

| | Thong, 2010^161^ Cohort (5-10 years) | Smith, 2009^159^ (EBRT) Cohort (3.8 years) | Smith, 2009^159^ (LD brachy) Cohort (3.8 years) | Smith, 2009^159^ (HD brachy) Cohort (3.8 years) | Bacon, 2001^139^ (EBRT) Cohort (5.0 years) | Bacon, 2001^139^ (brachy) Cohort (5.0 years) | Schapira, 2001^156^ Cohort (1.0 years | Smith, 2000^160^ Cohort (3.8 years) | Lubeck, 1999^152^ Cohort (2.0 years) | Litwin, 1995^150^ Cohort (6.0 years) | Median Difference (range)
Urinary Function | RT | 82.0 | 92.6 | 93.5 | 89.8 | 89.0 | 87.0 | 89.4 | 89.0 | 84.9 | 82.0 | -3 3 (-6.0 to 7.2)
Urinary Function | CM | 86.0 | 91.6 | 91.6 | 91.6 | 93.0 | 93.0 | 82.2 | 94.0 | 87.4 | 86.0 | -3 3 (-6.0 to 7.2)
Urinary Function | Diff | -4.0 | 1.0 | 1.9 | -1.8 | -4.0 | -6.0 | 7.2 | -5.0 | -2.5 | -4.0 | -3 3 (-6.0 to 7.2)
Urinary Bother | RT | 75.0 | 81.4 | 84.4 | 76.7 | 83.0 | 75.0 | 81.3 | 81.0 | 65.1 | 77.0 | -4.5 (-18.5 to 0.3)
Urinary Bother | CM | 78.0 | 84.1 | 84.1 | 84.1 | 89.0 | 89.0 | 84.0 | 88.0 | 83.6 | 80.0 | -4.5 (-18.5 to 0.3)
Urinary Bother | Diff | -3.0 | -2.7 | 0.3 | -7.4 | -6.0 | -14.0 | -2.7 | -7.0 | -18.5 | -3.0 | -4.5 (-18.5 to 0.3)
Sexual Function | RT | NR | 32.0 | 54.0 | 30.3 | 34.0 | 36.0 | 25.1 | 40.0 | 25.4 | 35.0 | -12.1 (-20.0 to 9.9)
Sexual Function | CM | NR | 44.1 | 44.1 | 44.1 | 54.0 | 54.0 | 36.1 | 60.0 | 29.1 | 41.0 | -12.1 (-20.0 to 9.9)
Sexual Function | Diff | NR | -12.1 | 9.9 | -13.8 | -20.0 | -18.0 | -11.0 | -20.0 | -3.7 | -6.0 | -12.1 (-20.0 to 9.9)
Sexual Bother | RT | NR | 57.6 | 66.8 | 60.5 | 51.0 | 54.0 | 60.1 | 51.0 | 32.4 | 29.0 | -8.0 (-23.0 to 7.5)
Sexual Bother | CM | NR | 65.9 | 65.9 | 65.9 | 74.0 | 74.0 | 62.0 | 69.0 | 24.9 | 37.0 | -8.0 (-23.0 to 7.5)
Sexual Bother | Diff | NR | -8.3 | 0.9 | -5.4 | -23.0 | -20.0 | -1.9 | -18.0 | 7.5 | -8.0 | -8.0 (-23.0 to 7.5)
Bowel Function | RT | 87.0 | 84.5 | 88.8 | 87.8 | 81.0 | 80.0 | 79.4 | NR | 83.1 | 81.0 | -6.0 (-11.0 to 2.1)
Bowel Function | CM | 93.0 | 86.7 | 86.7 | 86.7 | 91.0 | 91.0 | 86.1 | NR | 89.1 | 84.0 | -6.0 (-11.0 to 2.1)
Bowel Function | Diff | -6.0 | -2.2 | 2.1 | 1.1 | -10.0 | -11.0 | -6.7 | NR | -6.0 | -3.0 | -6.0 (-11.0 to 2.1)
Bowel Bother | RT | 85.0 | 79.8 | 91.1 | 84.3 | 78.0 | 72.0 | 76.6 | NR | 74.8 | 77.0 | -8.3 (-17.0 to 3.0)
Bowel Bother | CM | 94.0 | 88.1 | 88.1 | 88.1 | 89.0 | 89.0 | 80.8 | NR | 90.0 | 85.0 | -8.3 (-17.0 to 3.0)
Bowel Bother | Diff | -9.0 | -8.3 | 3.0 | -3.8 | -11.0 | -17.0 | -4.2 | NR | -15.2 | -8.0 | -8.3 (-17.0 to 3.0)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: Brachy=brachytherapy; CM=conservative management; Diff=difference; HD=high dose; LD=low dose; RT=radiation therapy; NR-not reported

Appendix E Table 10 Raw SF-36 Scores for Androgen Deprivation Therapy Compared With Conservative Management^*^

| | Smith, 2009^159^ Cohort (3.8 years) | Potosky, 2002^154^ Cohort (1.0 years) | Bacon, 2001^139^ Cohort (5.0 years) | Smith, 2000^160^ Cohort (3.8 years) | Median Difference (range)
Physical Component Summary Score | ADT | 38.80 | NR | 46.0 | NR | NA (−8.1 to −3.0)
Physical Component Summary Score | CM | 46.90 | NR | 49.0 | NR | NA (−8.1 to −3.0)
Physical Component Summary Score | Diff | −8.10 | NR | −3.00 | NR | NA (−8.1 to −3.0)
Mental Component Summary Score | ADT | 53.20 | NR | 52.0 | NR | NA (−3.0 to 0.1)
Mental Component Summary Score | CM | 53.10 | NR | 55.0 | NR | NA (−3.0 to 0.1)
Mental Component Summary Score | Diff | 0.10 | NR | −3.00 | NR | NA (−3.0 to 0.1)
Physical Function | ADT | NR | NR | 76.0 | 72.0 | NA (−13.0 to −3.0)
Physical Function | CM | NR | NR | 79.0 | 85.0 | NA (−13.0 to −3.0)
Physical Function | Diff | NR | NR | −3.0 | −13.0 | NA (−13.0 to −3.0)
Physical Role Function | ADT | NR | 50 | 62.0 | 69.0 | −11.0 (−23.0 to −11.0)
Physical Role Function | CM | NR | 61 | 85.0 | 80.0 | −11.0 (−23.0 to −11.0)
Physical Role Function | Diff | NR | −11.0 | −23.0 | −11.0 | −11.0 (−23.0 to −11.0)
Bodily Pain | ADT | NR | 73 | 75.0 | 79.0 | −6.0 (-8.0 to −1.0)
Bodily Pain | CM | NR | 74 | 81.0 | 87.0 | −6.0 (-8.0 to −1.0)
Bodily Pain | Diff | NR | −1.0 | −6.0 | −8.0 | −6.0 (-8.0 to −1.0)
General Health | ADT | NR | NR | 66.0 | 69.0 | NA (−5.0 to −2.0)
General Health | CM | NR | NR | 71.0 | 71.0 | NA (−5.0 to −2.0)
General Health | Diff | NR | NR | −5.0 | −2.0 | NA (−5.0 to −2.0)
Vitality | ADT | NR | 53 | 61.0 | 62.0 | −7.0 (−7.0 to −7.0)
Vitality | CM | NR | 60 | 68.0 | 69.0 | −7.0 (−7.0 to −7.0)
Vitality | Diff | NR | −7.0 | −7.0 | −7.0 | −7.0 (−7.0 to −7.0)
Social Function | ADT | NR | NR | 83.0 | 82.0 | NA (−10.0 to−4.0)
Social Function | CM | NR | NR | 87.0 | 92.0 | NA (−10.0 to−4.0)
Social Function | Diff | NR | NR | −4.0 | −10.0 | NA (−10.0 to−4.0)
Emotional Role Function | ADT | NR | 74 | 74.0 | 76.0 | −15.0 (−16.0 to−3.0)
Emotional Role Function | CM | NR | 77 | 90.0 | 91.0 | −15.0 (−16.0 to−3.0)
Emotional Role Function | Diff | NR | −3.0 | −16.0 | −15.0 | −15.0 (−16.0 to−3.0)
Mental Health | ADT | NR | 78 | 79.0 | 76.0 | −4.0 (−6.0 to 0.0)
Mental Health | CM | NR | 78 | 83.0 | 82.0 | −4.0 (−6.0 to 0.0)
Mental Health | Diff | NR | 0.0 | −4.0 | −6.0 | −4.0 (−6.0 to 0.0)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: ADT=androgen deprivation therapy; CM=conservative management; Diff=difference; NA=not applicable; NR=not reported

Appendix E Table 11 Raw PCI Scores for Androgen Deprivation Therapy Compared With Conservative Management^*^

| | Smith, 2009^159^ Cohort (3.8 years) | Bacon, 2001^139^ Cohort (5.0 years) | Smith, 2000^160^ Cohort (3.8 years) | Median Difference (range)
Urinary Function | ADT | 92.80 | 84.0 | 90.0 | −4.0 (−9.0 to 1.2)
Urinary Function | CM | 91.60 | 93.0 | 94.0 | −4.0 (−9.0 to 1.2)
Urinary Function | Diff | 1.2 | −9.0 | −4.0 | −4.0 (−9.0 to 1.2)
Urinary Bother | ADT | 73.40 | 72.0 | 83.0 | −10.7 (−17.0 to −5.0)
Urinary Bother | CM | 84.10 | 89.0 | 88.0 | −10.7 (−17.0 to −5.0)
Urinary Bother | Diff | −10.7 | −17.0 | −5.0 | −10.7 (−17.0 to −5.0)
Sexual Function | ADT | 8.30 | 25.0 | 29.0 | −31.0 (−35.8 to −29.0)
Sexual Function | CM | 44.1 | 54.0 | 60.0 | −31.0 (−35.8 to −29.0)
Sexual Function | Diff | −35.8 | −29.0 | −31.0 | −31.0 (−35.8 to −29.0)
Sexual Bother | ADT | 66.50 | 59.0 | 49.0 | −15.0 (−20.0 to 0.6)
Sexual Bother | CM | 65.90 | 74.0 | 69.0 | −15.0 (−20.0 to 0.6)
Sexual Bother | Diff | 0.6 | −15.0 | −20.0 | −15.0 (−20.0 to 0.6)
Bowel Function | ADT | 82.10 | 81.0 | NR | NA (−10.0 to −4.6)
Bowel Function | CM | 86.70 | 91.0 | NR | NA (−10.0 to −4.6)
Bowel Function | Diff | −4.6 | −10.0 | NR | NA (−10.0 to −4.6)
Bowel Bother | ADT | 87.20 | 83.0 | NR | NA (−6.0 to −0.9)
Bowel Bother | CM | 88.10 | 89.0 | NR | NA (−6.0 to −0.9)
Bowel Bother | Diff | −0.90 | −6.0 | NR | NA (−6.0 to −0.9)

* Conservative management is a general term used to describe management strategies (active surveillance, watchful waiting). Studies including men in observation, deferred treatment or no treatment groups were considered watchful waiting.

Abbreviations: ADT=androgen deprivation therapy; CM=conservative management; Diff=difference; NA=not applicable; NR=not reported