# Appendix D Poor-Quality Studies Excluded From Previous USPSTF Evidence Syntheses

## Quebec Trial

This trial randomized 46,486 men to PSA-based screening versus usual care and showed no statistically significant difference in prostate cancer mortality between screening-invited and control groups when data were analyzed via intention-to-treat (relative risk [RR], 1.09 [95% CI, 0.82 – 1.43]).^220^ The trial was rated as poor-quality due to low adherence to the intervention in the screening arm (23.6%), uncertain levels of contamination due to out-of-trial screening, uncertainty about potential treatment differences across study arms, and outcome assessments that may not have been blinded to study arm allocation.

## Norrkoping Trial

This study selected a cohort of men aged 50 to 69 years living in Norrkoping, Sweden from the National Population Register. Every sixth man (n=1,494) was invited to participate in a multiyear screening program; the remaining men who were not contacted served as controls (n=7,532). The first two rounds of screening (in 1987 and 1990) consisted only of DRE; the screening protocol changed during the third and fourth rounds (1993 and 1996) to include DRE plus PSA testing. The study used a PSA cut-off point of >4.0 ng/mL; a positive screening result led to a biopsy and confirmed prostate cancer was treated according to a standardized management program common to that region of Sweden. After 20 years of followup, the authors found no statistically significant difference in prostate cancer mortality between the screened and control groups (RR, 1.16 [95% CI, 0.78 to 1.73).^178^ This study was rated as poor quality for several reasons, including non-ideal method of randomization, lack of information on the baseline comparability of the two groups, uncertain levels of contamination in the control group, and insufficient information regarding the method of outcome assessment. Finally, the sample size was originally calculated to assess the acceptance and feasibility of a prostate cancer screening program, rather than mortality outcomes.

## Stockholm Trial

This study selected a cohort of men aged 55 to 70 years living in Stockholm, Sweden (n=2,400) from census records and invited them to a single prostate cancer screening (which included a PSA test, DRE, and TRUS) in 1988; the remaining 27,804 men in the source population served as the control group. Of the men invited, 75 percent attended the screening. A PSA exceeding 10.0 ng/mL led to a prostate biopsy and a lower PSA of 7.0 to 10.0 ng/mL led to a repeat TRUS. The cohort was followed for 15 years. Neither the relative risk of prostate cancer-specific mortality (RR, 1.10 [95% CI, 0.83 to 1.46]) or all-cause mortality (RR, 0.98 [95% CI, 0.92 to 1.05]) was statistically significantly different in the screening group compared with the controls. Only three of the 65 cases of prostate cancer (4.6%) found during screening were detected by an elevated PSA alone.^179^ This study was rated as poor quality because of there was no reporting of baseline differences between the screening and comparison groups, and it was unclear whether the review committee was blinded to group allocation, potentially leading to attribution bias in outcomes assessment. The trial also has internal discrepancies about the total number of participants because the file containing the registration numbers of the original cohort could not be retrieved. In addition to the study’s risk of bias, the study’s findings are not generalizable to the United States due to the high PSA cut-off points.