# Appendix C Ongoing Studies

Study | Aim | Population Country | Intervention | Comparator | Relevant Outcomes | Status
KQ1 & KQ2 (PSA screening effectiveness and harms)
No ongoing trials of PSA screening versus no PSA screening were identified. No trials or cohort studies of harms related to PSA screening and diagnostic testing were identified
KQs 3& 4 (prostate cancer treatment effectiveness and harms)
SPCG17: Prostate Cancer Active Surveillance Trigger Trial (PCASTT) NCT02914873 | Determine whether an active surveillance protocol with specified triggers for repeat biopsies and initiation of subsequent treatment can reduce overtreatment and subsequent side effects, without increasing risk of disease progression or death | Males with diagnosed with early-stage prostate cancer Sweden | Active surveillance w/trigger protocol | Active surveillance w/standard protocol | Disease progression; quality of life | Recruiting Estimated completion date: December 2030
Active Surveillance of Two Groups of Patients with Localized Prostate Cancer NCT01795365 | Validate the treatment option active surveillance in men with localized, well differentiated prostate cancer, in order to limit the amount of overtreatment | Males ages 18 to 75 years with localized prostate cancer (Gleason score of 3+3 or 3+4) Switzerland | Active surveillance | NA | Time on AS before active treatment; mortality rates; time to metastatic disease; quality of life | Ongoing but not recruiting Estimated completion date: October 2017
Focal Therapy Using High Intensity Focused Ultrasound for Localized Prostate Cancer NCT02016040 | Evaluate the impact of HIFU treatment on continence, sexuality and quality of life at one year | Males >50 years diagnosed with stage T1c prostate cancer Canada | HIFU | NA | Incidence of harms (erectile and sexual function, quality of life) | Ongoing but not recruiting Estimated completion date: November 2017
Intervention Trial Evaluating Focal Therapy Using High Intensity Focused Ultrasound for the Treatment of Prostate Cancer NCT02265159 | Evaluate cancer control, genitourinary, rectal and overall health-related quality of life outcomes for localized prostate cancer using HIFU | Men with stage T1 -T2c prostate cancer Switzerland | HIFU | NA | Incidence of harms (erectile, sexual and bowel function, quality of life) | Ongoing but not recruiting Estimated completion date: May 2020
Initial Experience in Brazilian Single Center With High Intensity Focalized Ultrasound (HIFU) Prostate Cancer Therapy: Morbidity, Oncological and Functional Outcomes NCT03255135 | Evaluate prospectively the initial experience with 50 patients submitted to HIFU therapy for low risk prostate cancer in Brazilian single center | Men with low or intermediate prostate cancer staging Brazil | HIFU | NA | Patient-reported quality of life using IEFF-5, EPIC, IPSS, and SF-36 | Not yet open for recruitment Estimated completion date: December 2017
Effectiveness of Three Primary Treatments for Localized Prostate Cancer: Radical Prostatectomy, External-beam Radiotherapy, and Prostate Brachytherapy NCT01492751 | Assess the quality of life impacts of treatments’ side effects on patients with localized prostate cancer at short, mid, and long-range followup | Males with stage T1 or T2 prostate cancer Spain | Radical prostatectomy; external-beam radiation therapy; brachytherapy | NA | Quality of life; harms (urinary, sexual function); survival | Ongoing but not recruiting Estimated completion date: December 2017
Active Surveillance for Cancer of the Prostate (ASCaP) NCT00949819 | Establish a structured program of non-interventional follow-up for localized prostate cancer | Males ages 30 to 85 years with stage T1 or T2 (NX, N0, MX or M0) prostate cancer United States | Active surveillance | NA | Clinical parameters to predict aggressive disease; clinical predictors of disease progression | Recruiting Estimated completion date: December 2019
Active Surveillance in Prostate Cancer: A Prospective Cohort Study NCT00490763 | Determine whether men classified as having “low risk” prostate cancer can safely not be treated for the disease | Males with low-risk prostate cancer who choose active surveillance United States | Active surveillance | NA | Time to disease progression; quality of life | Ongoing but not recruiting Estimated completion date: February 2020