# Appendix B Excluded Studies

Reason for Exclusion
E1. Study relevance
E2. Setting; a. Non-HDI country
E3. Intervention; a. Screening study of DRE alone; b. Treatment study of chemotherapy
E4. Comparator
E5. Population; a. Screening studies in men with elevated PSA or who have undergone prostate biopsy, or other high risk screening populations; b. Treatment studies with more than 10% of men having later-stage (stage III-IV) prostate cancer
E6. Outcomes; a. No additional relevant data (primary article is included) or duplicate data
E7. Study design; a. Uncontrolled observational study of radical prostatectomy, radiation therapy, or androgen deprivation therapy with sample size of 1,000 men or less; b. Uncontrolled observational study of high-intensity focused ultrasound with sample size of 100 men or less
E8. Non-English
E9. Poor quality
E10. Unable to locate article

1 PSA-based screening for prostate cancer Too many adverse effects. Prescrire Int. 2012;21(130):215–7. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E823016259
2 Ahmad S, O’Kelly F, Manecksha RP, Survival after incidental prostate cancer diagnosis at transurethral resection of prostate: 10-year outcomes. Irish Journal of Medical Science. 2012;181(1):27–31. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E121910023
3 Aizer AA, Chen MH, Hattangadi J, D’Amico AV. Initial management of prostate-specific antigen-detected, low-risk prostate cancer and the risk of death from prostate cancer. BJU International. 2014;113(1):43–50. KQ1E1, KQ2E1, KQ3E9, KQ4E6, KQ5E123473327
4 Alicikus ZA, Yamada Y, Zhang Z, Ten-year outcomes of high-dose, intensity-modulated radiotherapy for localized prostate cancer. Cancer. 2011;117(7):1429–37. KQ1E1, KQ2E1, KQ3E7, KQ4E5, KQ5E121425143
5 Ankerst DP, Boeck A, Freedland SJ, Evaluating the PCPT risk calculator in ten international biopsy cohorts: Results from the Prostate Biopsy Collaborative Group. World Journal of Urology. 2012;30(2):181–7. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E6a22210512
6 Ankerst DP, Boeck A, Thompson IM, Internationalmulti-validation of the Prostate Cancer Prevention Trial Risk Calculator (PCPTRC): Results from the Prostate Biopsy Collaborative Group (PBCG). Tumor Biology. 2011;32:S42. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
7 Ankerst DP, Till C, Boeck A, The impact of prostate volume, number of biopsy cores and American Urological Association symptom score on the sensitivity of cancer detection using the Prostate Cancer Prevention Trial risk calculator. Journal of Urology. 2013;190(1):70–6. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E123313212
8 Auprich M, Augustin H, Budaus L, A comparative performance analysis of total prostate-specific antigen, percentage free prostate-specific antigen, prostate-specific antigen velocity and urinary prostate cancer gene 3 in the first, second and third repeat prostate biopsy. BJU International. 2012;109(11):1627–35. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X921939492
9 Auprich M, Bjartell A, Chun FK, Contemporary role of prostate cancer antigen 3 in the management of prostate cancer. European Urology. 2011;60(5):1045–54. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E7, X921871709
10 Auvinen A, Moss S, Tammela TL, Absolute Effect of Prostate Cancer Screening: Balance of benefits and harms by center within the European Randomized Study of Prostate Cancer Screening. Clin Cancer Res. 2015. KQ1E6a, KQ2E6, KQ3E1, KQ4E1, KQ5E1
11 Axén E, Hugosson J, Khatami A, Lodding P, Stranne J. PSA doubling time predicts outcome after active surveillance in screening detected prostate cancer. European Urology, Supplements. 2011;10(2):236. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
12 Azevedo N, Roobol MJ. The Rotterdam prostate cancer risk calculator: improved prediction with more relevant pre-biopsy information, now in the palm of your hand. European Urology, Supplements. 2014;13(5):110–1. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
13 Bancroft EK, Page EC, Castro E, Targeted prostate cancer screening in BRCA1 and BRCA2 mutation carriers: results from the initial screening round of the IMPACT study. ***[Erratum appears in Eur Urol. 2015 Jun;67(6):e126; PMID: 25944041]. European Urology. 2014;66(3):489–99. KQ1E7, KQ2E5, KQ3E1, KQ4E1, KQ5E125944041
14 Barret E, Ahallal Y, Sanchez-Salas R, Morbidity of focal therapy in the treatment of localized prostate cancer. European Urology. 2013;63(4):618–22. KQ1E1, KQ2E1, KQ3E5, KQ4E6, KQ5E123265382
15 Begg CB, Riedel ER, Bach PB, Variations in morbidity after radical prostatectomy. N Engl J Med. 2002;346(15):1138–44. KQ1E1, KQ2E1, KQ3E7, KQ4E5b, KQ5E111948274
16 Birkhahn M, Penson DF, Cai J, Long-term outcome in patients with a Gleason score <6 prostate cancer treated by radical prostatectomy. BJU International. 2011;108(5):660–4. KQ1E1, KQ2E1, KQ3E7, KQ4E6, KQ5E121223479
17 Blanker MH, Noordzij MA. [Prostate cancer screening benefit very low, even after 13 years]. Ned Tijdschr Geneeskd. 2014;158:A8349. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, X1025492737
18 Bokhorst LP, Kranse R, Venderbos LD, Differences in treatment and outcome after treatment with curative intent in the screening and control arms of the ERSPC Rotterdam. Eur Urol. 2015;68(2):179–82. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E125457496
19 Bokhorst LP, Zappa M, Carlsson SV, Correlation between stage shift and differences in mortality in the European Randomised study of Screening for Prostate Cancer (ERSPC). BJU Int. 2016;118(5):677–80. KQ1E5, KQ2E5, KQ3E1, KQ4E1, KQ5E127104278
20 Bolla M, van Poppel H, Collette L, Postoperative radiotherapy after radical prostatectomy: a randomised controlled trial (EORTC trial 22911). Lancet. 2005;366(9485):572–8. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E116099293
21 Bolla M, van Poppel H, Tombal B, Postoperative radiotherapy after radical prostatectomy for high-risk prostate cancer: long-term results of a randomised controlled trial (EORTC trial 22911). Lancet. 2012;380(9858):2018–27. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E123084481
22 Bollito E, De Luca S, Cicilano M, Prostate cancer gene 3 urine assay cutoff in diagnosis of prostate cancer: a validation study on an Italian patient population undergoing first and repeat biopsy. Analytical & Quantitative Cytology & Histology. 2012;34(2):96–104. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X922611765
23 Bul M, van den Bergh RC, Zhu X, Outcomes of initially expectantly managed patients with low or intermediate risk screen-detected localized prostate cancer. BJU International. 2012;110(11):1672–7. KQ1E1, KQ2E1, KQ3E7, KQ4E6, KQ5E122928973
24 Bul M, Van Leeuwen PJ, Zhu X, Schröder FH, Roobol MJ. Prostate cancer incidence and disease-specific survival of men with initial prostate-specific antigen less than 3.0 ng/ml who are participating in ERSPC Rotterdam. European Urology. 2011;59(4):498–505. KQ1E5, KQ2E5, KQ3E1, KQ4E1, KQ5E121334136
25 Bul M, Van Leeuwen PJ, Zhu X, Schröder FH, Roobol MJ. Prostate cancer incidence and disease-specific survival in men participating in the ERSPC with an initial PSA less than 3.0 ng/mL. Journal of Clinical Oncology. 2011;29(7). KQ1E5, KQ2E5, KQ3E1, KQ4E1, KQ5E1
26 Bul M, Zhu X, Rannikko A, Radical prostatectomy for low-risk prostate cancer following initial active surveillance: results from a prospective observational study. European Urology. 2012;62(2):195–200. KQ1E1, KQ2E1, KQ3E6, KQ4E7, KQ5E122342775
27 Busch J, Magheli A, Leva N, Higher rates of upgrading and upstaging in older patients undergoing radical prostatectomy and qualifying for active surveillance. BJU International. 2014;114(4):517–21. KQ1E1, KQ2E1, KQ3E5, KQ4E6, KQ5E1, X824112652
28 Byar DP, Corle DK. VACURG randomised trial of radical prostatectomy for stages I and II prostatic cancer. Veterans Administration Cooperative Urological Research Group. Urology. 1981;17(4 Suppl):7–11. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E107010763
29 Carlsson S, Assel M, Sjoberg D, Influence of blood prostate specific antigen levels at age 60 on benefits and harms of prostate cancer screening: population based cohort study. BMJ. 2014;348:g2296. KQ1E7, KQ2E6, KQ3E1, KQ4E1, KQ5E1, X1524682399
30 Carlsson S, Assel M, Sjoberg D, Influence of blood levels of prostate-specific antigen at age 60 on the benefits and harms of prostate cancer screening. Journal of Urology. 2014;191(4):e818. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
31 Carlsson S, Aus G, Bergdahl S, The excess burden of side-effects from treatment in men allocated to screening for prostate cancer. The Goteborg randomised population-based prostate cancer screening trial. European Journal of Cancer. 2011;47(4):545–53. KQ1E1, KQ2E1, KQ3E6, KQ4E7, KQ5E121087857
32 Carlsson S, Maschino A, Schroder F, Predictive value of four kallikrein markers for pathologically insignificant compared with aggressive prostate cancer in radical prostatectomy specimens: results from the European Randomized Study of Screening for Prostate Cancer section Rotterdam. European Urology. 2013;64(5):693–9. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E5, X1023683475
33 Chamie K, Williams SB, Hershman DL, Wright JD, Nguyen PL, Hu JC. Population-based assessment of determining predictors for quality of prostate cancer surveillance. Cancer. 2015;121(23):4150–7. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E1, X326307939
34 Chang P, Regan MM, Ferrer M, Relief of urinary symptom burden after primary prostate cancer treatment. J Urol. 2017;197(2):376–84. KQ1E1, KQ2E1, KQ3E6, KQ4E4, KQ5E127593476
35 Chen H, Sun J, Ankerst D, Added value of genetic risk score to the prostate cancer prevention trial (PCPT) risk calculator: findings from the PCPT study. Journal of Urology. 2014;191(4):e818–e9. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7, X9
36 Chen WC, Tokita KM, Ravera J, Four-year outcomes of hypofractionated high-dose-rate prostate brachytherapy and external beam radiotherapy. Brachytherapy. 2013;12(5):422–7. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E123380382
37 Choo R, Klotz L, Danjoux C, Feasibility study: watchful waiting for localized low to intermediate grade prostate carcinoma with selective delayed intervention based on prostate specific antigen, histological and/or clinical progression. J Urol. 2002;167(4):1664–9. KQ1E1, KQ2E1, KQ3E7, KQ4E6, KQ5E111912384
38 Choo R, Long J, Gray R, Morton G, Gardner S, Danjoux C. Prospective survey of sexual function among patients with clinically localized prostate cancer referred for definitive radiotherapy and the impact of radiotherapy on sexual function. Support Care Cancer. 2010;18(6):715–22. KQ1E1, KQ2E1, KQ3E6, KQ4E5, KQ5E119506916
39 Chua M, Tanseco P, Mendoza J, Castillo J, Morales Jr M, Luna Jr S. Configuration and validation of a novel prostate disease nomogram predicting prostate biopsy outcome: a prospective study correlating clinical indicators among filipino adult males with elevated psa level. Journal of Urology. 2015;193(4):e740. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
40 Clark JA, Talcott JA. Symptom indexes to assess outcomes of treatment for early prostate cancer. Med Care. 2001;39(10):1118–30. KQ1E1, KQ2E1, KQ3E7, KQ4E5, KQ5E111567174
41 Cordeiro ER, Cathelineau X, Thuroff S, Marberger M, Crouzet S, de la Rosette JJ. High-intensity focused ultrasound (HIFU) for definitive treatment of prostate cancer. BJU Int. 2012;110(9):1228–42. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E122672199
42 Crawford ED, Grubb R ***3rd, Black A, Comorbidity and mortality results from a randomized prostate cancer screening trial. Journal of Clinical Oncology. 2011;29(4):355–61. KQ1E6a, KQ2E6, KQ3E1, KQ4E1, KQ5E1, X321041707
43 Crawford ED, Rove KO, Trabulsi EJ, Diagnostic performance of PCA3 to detect prostate cancer in men with increased prostate specific antigen: a prospective study of 1,962 cases. Journal of Urology. 2012;188(5):1726–31. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X922998901
44 Dahabreh IJ, Chung M, Balk EM, Active surveillance in men with localized prostate cancer: a systematic review. Annals of Internal Medicine. 2012;156(8):582–90. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E122351515
45 Dall’Era MA, Albertsen PC, Bangma C, Active surveillance for prostate cancer: a systematic review of the literature. European Urology. 2012;62(6):976–83. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E122698574
46 Daskivich TJ, Lai J, Dick AW, Comparative effectiveness of aggressive versus nonaggressive treatment among men with early-stage prostate cancer and differing comorbid disease burdens at diagnosis. Cancer. 2014;120(16):2432–9. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E124824511
47 Dell’Oglio P, Stabile A, Gandaglia G, Inclusion of mpMRI into the european randomized study of screening for prostate cancer (ERSPC) risk calculator: a new proposal to improve the accuracy of prostate cancer detection. Journal of Urology. 2017;197(4):e1027. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E6
48 Djulbegovic M, Beyth RJ, Neuberger MM, Screening for prostate cancer: systematic review and meta-analysis of randomised controlled trials. BMJ. 2010;341:c4543. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E120843937
49 El Fegoun AB, Barret E, Prapotnich D, Focal therapy with high-intensity focused ultrasound for prostate cancer in the elderly. A feasibility study with 10 years follow-up. International Braz J Urol. 2011;37(2):213–9; discussion 20–2. KQ1E1, KQ2E1, KQ3E6, KQ4E7, KQ5E121557838
50 Elterman DS, Barkin J, Radomski SB, Results of high intensity focused ultrasound treatment of prostate cancer: early Canadian experience at a single center. Canadian Journal of Urology. 2011;18(6):6037–42. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E722166332
51 Franlund M, Carlsson S, Lilja H, Hugosson J. Men with total PSA levels between 1-2.99 ng/mL at initial screening have an elevated risk of future prostate cancer diagnosis: results from the Gothenburg randomized screening trial. European Urology, Supplements. 2013;12(1):e4. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
52 Gadia R, Leite ET, Gabrielli FG, Outcomes of high-dose intensity-modulated radiotherapy alone with 1 cm planning target volume posterior margin for localized prostate cancer. Radiation Oncology. 2013;8:285. KQ1E1, KQ2E1, KQ3E7, KQ4E5, KQ5E124314072
53 Galbraith ME, Ramirez JM, Pedro LW. Quality of life, health outcomes, and identity for patients with prostate cancer in five different treatment groups. Oncol Nurs Forum. 2001;28(3):551–60. KQ1E1, KQ2E1, KQ3E6, KQ4E9, KQ5E111338762
54 Gayet M, Mannaerts CK, Nieboer D, Prediction of prostate cancer: external validation of the ERSPC risk calculator in a contemporary Dutch clinical cohort. European Urology Focus. 2016. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10
55 Gershman B, Van Houten HK, Herrin J, Impact of prostate-specific antigen (PSA) screening trials and revised PSA screening guidelines on rates of prostate biopsy and postbiopsy complications. European Urology. 2017;71(1):55–65. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E126995328
56 Godtman RA, Holmberg E, Khatami A, Stranne J, Hugosson J. Outcome following active surveillance of men with screen-detected prostate cancer. Results from the Goteborg randomised population-based prostate cancer screening trial. European Urology. 2013;63(1):101–7. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E1, X322980443
57 Graefen M, Schlomm T, Steuber T, Sauter G. Current results on PSA-based prostate cancer detection. Bundesgesundheitsblatt, Gesundheitsforschung, Gesundheitsschutz. 2014;57(3):312–7. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, X1024562706
58 Graversen PH, Nielsen KT, Gasser TC, Corle DK, Madsen PO. Radical prostatectomy versus expectant primary treatment in stages I and II prostatic cancer. A fifteen-year follow-up. Urology. 1990;36(6):493–8. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102247914
59 Grenabo Bergdahl A, Holmberg E, Moss S, Hugosson J. Incidence of prostate cancer after termination of screening in a population-based randomised screening trial. European Urology. 2013;64(5):703–9. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E123721957
60 Grill S, Fallah M, Leach RJ, Incorporation of detailed family history from the Swedish family cancer database into the PCPT risk calculator. Journal of Urology. 2015;193(2):460–5. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E125242395
61 Gulati R, Gore JL, Etzioni R. Comparative effectiveness of alternative prostate-specific antigen--based prostate cancer screening strategies: model estimates of potential benefits and harms. Ann Intern Med. 2013;158(3):145–53. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7, X1, X623381039
62 Haines IE, Gabor Miklos GL. Prostate-specific antigen screening trials and prostate cancer deaths: the androgen deprivation connection. Journal of the National Cancer Institute. 2013;105(20):1534–9. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E1, X1924092918
63 Hakimi AA, Agalliu I, Ho GY, Detection of prostate cancer in an ethnically diverse, disadvantaged population with multiple prostate specific antigen measurements before biopsy. Journal of Urology. 2012;187(4):1234–40. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X8, X1522335862
64 Haythorn MR, Ablin RJ. Prostate-specific antigen testing across the spectrum of prostate cancer. Biomarkers in Medicine. 2011;5(4):515–26. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E821861672
65 Hilton JF, Blaschko SD, Whitson JM, Cowan JE, Carroll PR. The impact of serial prostate biopsies on sexual function in men on active surveillance for prostate cancer. Journal of Urology. 2012;188(4):1252–8. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E122902015
66 Hoffman RM. Periodic PSA-based screening in men 55 to 69 years of age reduced prostate cancer mortality. Annals of Internal Medicine. 2012;157(2):JC2–4. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
67 Ilic D, Neuberger MM, Djulbegovic M, Dahm P. Screening for prostate cancer. Cochrane Database of Systematic Reviews. 2013(1):78. KQ1E6, KQ2E6A, KQ3E1, KQ4E1, KQ5E1
68 Ilic D, O’Connor D, Green S, Wilt TJ. Screening for prostate cancer: an updated Cochrane systematic review. BJU Int. 2011;107(6):882–91. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E121392207
69 Ip S, Dahabreh IJ, Chung M, An evidence review of active surveillance in men with localized prostate cancer. Evidence Report/Technology Assessment. 2011(204):1–341. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E1
70 Iremashvili V, Manoharan M, Lokeshwar SD, Rosenberg DL, Pan D, Soloway MS. Comprehensive analysis of post-diagnostic prostate-specific antigen kinetics as predictor of a prostate cancer progression in active surveillance patients. BJU International. 2013;111(3):396–403. KQ1E1, KQ2E1, KQ3E5, KQ4E5, KQ5E122703025
71 Iremashvili V, Pelaez L, Manoharan M, Jorda M, Rosenberg DL, Soloway MS. Pathologic prostate cancer characteristics in patients eligible for active surveillance: a head-to-head comparison of contemporary protocols. European Urology. 2012;62(3):462–8. KQ1E1, KQ2E1, KQ3E5, KQ4E5, KQ5E122445138
72 Iremashvili V, Soloway MS, Rosenberg DL, Manoharan M. Clinical and demographic characteristics associated with prostate cancer progression in patients on active surveillance. Journal of Urology. 2012;187(5):1594–9. KQ1E1, KQ2E1, KQ3E7, KQ4E6, KQ5E122425088
73 Iversen P, Madsen PO, Corle DK. Radical prostatectomy versus expectant treatment for early carcinoma of the prostate. Twenty-three year follow-up of a prospective randomized study. Scand J Urol Nephrol Suppl. 1995;172:65–72. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E108578259
74 Izard MA, Morris LM, Wan WY, Martin J. Long-term outcome for prostate cancer using pseudo pulse-dosed rate brachytherapy, external beam radiotherapy, and hormones. Brachytherapy. 2013;12(6):608–14. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E123664646
75 Jacobs BL, Zhang Y, Schroeck FR, Use of advanced treatment technologies among men at low risk of dying from prostate cancer. JAMA. 2013;309(24):2587–95. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E1, X323800935
76 Janu J, Lakomy T, Tuma J. Age specific PSA and PSA velocity-comparison on the basis of prostate biopsies. European Urology, Supplements. 2013;12(4):e1196. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
77 Jeong CW, Lee S, Jung JW, Mobile application-based Seoul National University prostate cancer risk calculator: Development, validation, and comparative analysis with two western risk calculators in Korean men. PLoS ONE. 2014;9(4). KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1
78 Kasperzyk JL, Shappley WV 3rd, Kenfield SA, Watchful waiting and quality of life among prostate cancer survivors in the Physicians’ Health Study. Journal of Urology. 2011;186(5):1862–7. KQ1E1, KQ2E1, KQ3E7, KQ4E5, KQ5E121944095
79 Keto CJ, Aronson WJ, Terris MK, Detectable prostate-specific antigen Nadir during androgen-deprivation therapy predicts adverse prostate cancer-specific outcomes: results from the SEARCH database. European Urology. 2014;65(3):620–7. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E623245686
80 Kilpelainen TP, Tammela TL, Malila N, The Finnish prostate cancer screening trial: analyses on the screening failures. International Journal of Cancer. 2015;136(10):2437–43. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E125359457
81 Kim J, Ebertowski J, Janiga M, Many young men with prostate-specific antigen (PSA) screen-detected prostate cancers may be candidates for active surveillance. BJU Int. 2013;111(6):934–40. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E723350937
82 Kjellman A, Akre O, Norming U, Tornblom M, Gustafsson O. 15-year followup of a population based prostate cancer screening study. J Urol. 2009;181(4):1615–21; discussion 21. KQ1E9, KQ2E6, KQ3E1, KQ4E1, KQ5E119233435
83 Klotz L, Vesprini D, Sethukavalan P, Long-term follow-up of a large active surveillance cohort of patients with prostate cancer. J Clin Oncol. 2015;33(3):272–7. KQ1E1, KQ2E1, KQ3E7, KQ4E5, KQ5E125512465
84 Klotz L, Zhang L, Lam A, Nam R, Mamedov A, Loblaw A. Clinical results of long-term follow-up of a large, active surveillance cohort with localized prostate cancer. J Clin Oncol. 2010;28(1):126–31. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E119917860
85 Komura K, Inamoto T, Masuda H, Watsuji T, Azuma H. Experience with high-intensity focused ultrasound therapy for management of organ-confined prostate cancer: critical evaluation of oncologic outcomes. Acta Bio-Medica de l Ateneo Parmense. 2012;83(3):189–96. KQ1E1, KQ2E1, KQ3E7, KQ4E6, KQ5E1
86 Komura K, Inamoto T, Takai T, Single session of high-intensity focused ultrasound for localized prostate cancer: treatment outcomes and potential effect as a primary therapy. World Journal of Urology. 2014;32(5):1339–45. KQ1E1, KQ2E1, KQ3E7, KQ4E1, KQ5E124270943
87 Kotecha R, Yamada Y, Pei X, Clinical outcomes of high-dose-rate brachytherapy and external beam radiotherapy in the management of clinically localized prostate cancer. Brachytherapy. 2013;12(1):44–9. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E122831750
88 Koukourakis MI, Kyrgias G, Papadopoulou A, Treatment of low-risk prostate cancer with radical hypofractionated accelerated radiotherapy with cytoprotection (HypoARC): an interim analysis of toxicity and efficacy. Anticancer Research. 2011;31(5):1745–51. KQ1E1, KQ2E1, KQ3E6, KQ4E5, KQ5E121617234
89 Kukielka AM, Dabrowski T, Walasek T, Olchawa A, Kudzia R, Dybek D. High-dose-rate brachytherapy as a monotherapy for prostate cancer--Single-institution results of the extreme fractionation regimen. Brachytherapy. 2015;14(3):359–65. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E125736733
90 Labrie F, Candas B, Cusan L, Screening decreases prostate cancer mortality: 11-year follow-up of the 1988 Quebec prospective randomized controlled trial. Prostate. 2004;59(3):311–8. KQ1E9, KQ2E9, KQ3E1, KQ4E1, KQ5E115042607
91 Lavallée LT, Binette A, Witiuk K, Reducing the harm of prostate cancer screening: repeated prostate-specific antigen testing. Mayo Clinic Proceedings. 2016;91(1):17–22. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E126688045
92 Lazzeri M, Haese A, Abrate A, Clinical performance of serum prostate-specific antigen isoform [-2]proPSA (p2PSA) and its derivatives, %p2PSA and the prostate health index (PHI), in men with a family history of prostate cancer: results from a multicentre European study, the PROMEtheuS project. BJU International. 2013;112(3):313–21. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X923826841
93 Lee DH, Jung HB, Park JW, Can Western based online prostate cancer risk calculators be used to predict prostate cancer after prostate biopsy for the Korean population? Yonsei Medical Journal. 2013;54(3):665–71. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E523549812
94 Lee YJ, Park JE, Jeon BR, Lee SM, Kim SY, Lee YK. Is prostate-specific antigen effective for population screening of prostate cancer? A systematic review. Annals of Laboratory Medicine. 2013;33(4):233–41. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E123826558
95 Leidinger P, Keller A, Milchram L, Combination of autoantibody signature with PSA level enables a highly accurate blood-based differentiation of prostate cancer patients from patients with benign prostatic hyperplasia. PLoS ONE. 2015;10(6). KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X9
96 Liang Y, Ankerst DP, Feng Z, Fu R, Stanford JL, Thompson IM. The risk of biopsy-detectable prostate cancer using the prostate cancer prevention trial risk calculator in a community setting. Urologic Oncology. 2013;31(8):1464–9. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E622552047
97 Lilleby W, Tafjord G, Raabe NK. Implementation of high-dose-rate brachytherapy and androgen deprivation in patients with prostate cancer. International Journal of Radiation Oncology, Biology, Physics. 2012;83(3):933–9. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E1
98 Lippi G, Aloe R, Mattiuzzi C. Prostate-specific antigen (PSA) isoform p2PSA in prostate cancer screening: systematic review of current evidence and further perspectives. Rivista Italiana della Medicina di Laboratorio. 2012;8(4):231–8. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X9, X10
99 Liss M, Xu J, Chen H, Kader AK. The prostate genetic score (PGS) stratifies baseline risk of prostate cancer and improves PSA performance in the PLCO trial. Journal of Urology. 2015;193(4):e896–e7. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
100 Loeb S, Berglund A, Stattin P. Population based study of use and determinants of active surveillance and watchful waiting for low and intermediate risk prostate cancer. Journal of Urology. 2013;190(5):1742–9. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E1, X323727309
101 Loeb S, Carter HB, Berndt SI, Ricker W, Schaeffer EM. Complications after prostate biopsy: data from SEER-Medicare. J Urol. 2011;186(5):1830–4. KQ1E6, KQ2E5, KQ3E1, KQ4E1, KQ5E121944136
102 Louie KS, Seigneurin A, Cathcart P, Sasieni P. Do prostate cancer risk models improve the predictive accuracy of PSA screening? A meta-analysis. Annals of Oncology. 2015;26(5):848–64. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E7, X1025403590
103 Lujan M, Paez A, Berenguer A, Rodriguez JA. [Mortality due to prostate cancer in the Spanish arm of the European Randomized Study of Screening for Prostate Cancer (ERSPC). Results after a 15-year follow-up]. Actas Urol Esp. 2012;36(7):403–9. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E822269382
104 Lukka H, Waldron T, Chin J, High-intensity focused ultrasound for prostate cancer: a systematic review. Clinical Oncology (Royal College of Radiologists). 2011;23(2):117–27. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E1
105 Lumen N, Fonteyne V, de Meerleert G, Population screening for prostate cancer: an overview of available studies and meta-analysis. International Journal of Urology. 2012;19(2):100–8. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E1, X10, X1122103653
106 Luo Y, Gou X, Huang P, Mou C. Prostate cancer antigen 3 test for prostate biopsy decision: a systematic review and meta analysis. Chinese Medical Journal. 2014;127(9):1768–74. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X9, X1024791889
107 Mearini L, Ferri C, Lazzeri M, Evaluation of prostate-specific antigen isoform p2PSA and its derivates, %p2PSA, prostate health index and prostate dimension-adjusted related index in the detection of prostate cancer at first biopsy: an exploratory, prospective study. Urologia Internationalis. 2014;93(2):135–45. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X924732975
108 Mendhiratta N, Lee T, Prabhu V, Llukani E, Lepor H. 10-Year mortality after radical prostatectomy for localized prostate cancer in the prostate-specific antigen screening era. Urology. 2015;86(4):783–8. KQ1E1, KQ2E1, KQ3E5b, KQ4E6, KQ5E126163812
109 Merglen A, Schmidlin F, Fioretta G, Short- and long-term mortality with localized prostate cancer. Arch Intern Med. 2007;167(18):1944–50. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E117923593
110 Mitra AV, Bancroft EK, Barbachano Y, Targeted prostate cancer screening in men with mutations in BRCA1 and BRCA2 detects aggressive prostate cancer: preliminary analysis of the results of the IMPACT study. BJU International. 2011;107(1):28–39. KQ1E7, KQ2E5, KQ3E1, KQ4E1, KQ5E120840664
111 Murray NP, Reyes E, Tapia P, A performance analysis of the presence of malignant circulating prostate cells as a predictive factor for the detection of prostate cancer in the first, second and third prostate biopsy. Arch Esp Urol. 2013;66(4):335–41. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E823676536
112 Murray NP, Reyes E, Tapia P, Diagnostic performance of malignant prostatic cells detection in blood for early detection of prostate cancer: comparison to prostatic biopsy. Arch Esp Urol. 2011;64(10):961–71. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E822228894
113 Muto S, Yoshii T, Saito K, Kamiyama Y, Ide H, Horie S. Focal therapy with high-intensity-focused ultrasound in the treatment of localized prostate cancer. Jpn J Clin Oncol. 2008;38(3):192–9. KQ1E1, KQ2E1, KQ3E7, KQ4E7a, KQ5E118281309
114 Myers MA, Hagan MP, Todor D, Phase I/II trial of single-fraction high-dose-rate brachytherapy-boosted hypofractionated intensity-modulated radiation therapy for localized adenocarcinoma of the prostate. Brachytherapy. 2012;11(4):292–8. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E122464911
115 Na R, Zhang N, Wu Y, The evaluation of prostate cancer prevention trial (PCPT) risk calculator and logistic regression based models for predicting prostate cancer in Chinese population. Urology. 2014;84(4):S306. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
116 Newcomb LF, Thompson IM, Boyer HD, Outcomes of active surveillance for clinically localized prostate cancer in the prospective, multi-institutional Canary PASS Cohort. Journal of Urology. 2016;195(2):313–20. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E726327354
117 Ochiai A, Okihara K, Kamoi K, Clinical utility of the prostate cancer gene 3 (PCA3) urine assay in Japanese men undergoing prostate biopsy. BJU International. 2013;111(6):928–33. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X923331404
118 Odom BD, Mir MC, Hughes S, Active surveillance for low-risk prostate cancer in African American men: a multi-institutional experience. Urology. 2014;83(2):364–8. KQ1E1, KQ2E1, KQ3E7, KQ4E6, KQ5E124286600
119 Parekh DJ, Ankerst DP, Higgins BA, External validation of the Prostate Cancer Prevention Trial risk calculator in a screened population. Urology. 2006;68(6):1152–5. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E617169636
120 Park JJ, Chen MH, Loffredo M, D’Amico AV. Prostate-specific antigen velocity before and after elimination of factors that can confound the prostate-specific antigen level. Int J Radiat Oncol Biol Phys. 2012;82(3):1217–21. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E121640512
121 Park JY, Yoon S, Park MS, Initial biopsy outcome prediction in Korean patients-comparison of a novel web-based Korean prostate cancer risk calculator versus prostate-specific antigen testing. Journal of Korean Medical Science. 2011;26(1):85–91. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E521218035
122 Park JY, Yoon S, Park MS, Can the Prostate Risk Calculator based on Western population be applied to Asian population? European Urology, Supplements. 2012;11(1):e147. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
123 Perdona S, Cavadas V, Di Lorenzo G, Prostate cancer detection in the “grey area” of prostate-specific antigen below 10 ng/ml: head-to-head comparison of the updated PCPT calculator and Chun’s nomogram, two risk estimators incorporating prostate cancer antigen 3. European Urology. 2011;59(1):81–7. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X920947244
124 Pinsky PF, Black A, Parnes HL, Prostate cancer specific survival in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. Cancer Epidemiology. 2012;36(6):e401–6. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E1, X123000116
125 Pohle M, Magheli A, Fischer T, The effect of evolving strategies in the surgical management of organ-confined prostate cancer: comparison of data from 2005 to 2014 in a multicenter setting. Advances in Therapy. 2017;34(2):576–85. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E228054309
126 Pollack A, Walker G, Horwitz EM, Randomized trial of hypofractionated external-beam radiotherapy for prostate cancer. Journal of Clinical Oncology. 2013;31(31):3860–8. KQ1E1, KQ2E1, KQ3E4, KQ4E4, KQ5E124101042
127 Poyet C, Nieboer D, Wiederkehr C, Sulser T, Hermanns T. The ERSPC risk calculator outperforms the PCPC-2.0 risk calculator in prostate cancer risk prediction in a contemporary tertiary center in Europe. European Urology, Supplements. 2015;14(2):e22. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
128 Poyet C, Umbehr M, Wiederkehr C, Largo R, Sulser T, Hermanns T. Comparison of three different risk calculator to predict prostate cancer before biopsy - Results from a retrospective study in Zürich. Journal of Urology. 2014;191(4):e712. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
129 Poyet C, Wettstein MS, Lundon DJ, External evaluation of a novel prostate cancer risk calculator (ProstateCheck) based on data from the Swiss arm of the ERSPC. Journal of Urology. 2016;196(5):1402–7. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E727188476
130 Prada PJ, Gonzalez H, Fernandez J, Jimenez I, Iglesias A, Romo I. Biochemical outcome after high-dose-rate intensity modulated brachytherapy with external beam radiotherapy: 12 years of experience. BJU International. 2012;109(12):1787–93. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E121981583
131 Pron G. Prostate-specific antigen (PSA)–based population screening for prostate cancer: an evidence-based analysis. Ontario Health Technology Assessment Series. 2015;15(10). KQ1E6. KQ2E6. KQ3E6, KQ4E6, KQ5E1, X1, X3, X11, X17
132 Rahal AK, Badgett RG, Hoffman RM. Screening coverage needed to reduce mortality from prostate cancer: a living systematic review. PLoS One. 2016;11(4):11. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E6
133 Randazzo M, Beatrice J, Huber A, Future risk for intermediate or high risk prostate cancer in men with baseline PSA of 1-3 ng/ml and low free-to-total PSA-ratio in a prospective population-based screening trial (ERSPC AARAU). Journal of Urology. 2014;191(4):e815. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
134 Randazzo M, Müller A, Carlsson S, A positive family history as a risk factor for prostate cancer in a population-based study with organised prostate-specific antigen screening: results of the Swiss European Randomised Study of Screening for Prostate Cancer (ERSPC, Aarau). BJU International. 2016;117(4):576–83. KQ1E7, KQ2E6, KQ3E1, KQ4E1, KQ5E126332304
135 Randazzo M, Seiler D, Beatrice J, Prostate specific antigen (PSA)-pyramid in men with low range PSA: prostate cancer incidence and mortality-a plea for risk-based prostate cancer screening strategy in the European randomized study of screening for prostate cancer (ERSPC), AARAU. Journal of Urology. 2013;189(4):e793. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
136 Recker F, Randazzo M, Wyler SF, Risk-adapted PSA screening-a way to reduce the harms of prostate cancer screening. Oncology Research and Treatment. 2015;38:109–10. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
137 Resnick MJ, Koyama T, Fan KH, Long-term functional outcomes after treatment for localized prostate cancer. New England Journal of Medicine. 2013;368(5):436–45. KQ1E1, KQ2E1, KQ3E6, KQ4E4, KQ5E123363497
138 Rider JR, Sandin F, Andren O, Wiklund P, Hugosson J, Stattin P. Long-term outcomes among noncuratively treated men according to prostate cancer risk category in a nationwide, population-based study. European Urology. 2013;63(1):88–96. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E122902040
139 Roobol M, Verbeek J, Kweldam C, Van Leenders A. Updating of the ERSPC Rotterdam Prostate Cancer Risk Calculator for initial prostate biopsy to contemporary practice including the 2014 ISUP Gleason grading and cribriform growth patterns. European Urology, Supplements. 2016;15(13):e1622–e4. KQ1E1, KQ2E1KQ3E1, KQ4E1, KQ5E6
140 Roobol MJ, Kirkels WJ, Schroder FH. Features and preliminary results of the Dutch centre of the ERSPC (Rotterdam, the Netherlands). BJU Int. 2003;92 Suppl 2:48–54. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E1
141 Roobol MJ, Nieboer D, Houlgatte A, Reducing unnecessary biopsies for suspicion of prostate cancer: Extension and validation of an ERSPC based risk calculator with phi and comparison with the PCPT risk calculator including %free and -2propsa. Journal of Urology. 2013;189(4):e843. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
142 Roobol MJ, Nieboer D, Houlgatte A, Reducing unnecessary biopsies for suspicion of prostate cancer: extension and validation of an ERSPC based risk calculator with Phi. European Urology, Supplements. 2013;12(1):e139–e40. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
143 Roobol MJ, Nieboer D, Semnojow A, The DRE based ERSPC prostate cancer risk calculator and the additional value of Phi. Tumor Biology. 2012;33:S48–S9. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
144 Roobol MJ, Schroder FH, Hugosson J, Importance of prostate volume in the European Randomised Study of Screening for Prostate Cancer (ERSPC) risk calculators: results from the prostate biopsy collaborative group. World Journal of Urology. 2012;30(2):149–55. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E122203238
145 Roobol MJ, Schröder FH, Trottier G, Fernandes KA, Kranse R, Fleshner NE. Development of the European Randomized study of Screening for Prostate Cancer (ERSPC) risk calculator for high grade PCa and assessing and comparing its performance with the PCPT risk calculator in a Canadian cohort. European Urology, Supplements. 2011;10(2):33. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
146 Roobol MJ, Schröder H, Bangma H, Steyerberg W. A risk calculator for prostate cancer risk 4 years after negative screening findings: ERSPC Rotterdam. European Urology, Supplements. 2012;11(1):e145–ea. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E6
147 Roobol MJ, Semjonow A, Bangma CH. Performance of the european randomized study of screening for prostate cancer (ERSPC) risk calculator for high grade PC in a clinical setting and the additional value of the prostate health index (PHI). Clinical Chemistry and Laboratory Medicine. 2011;49:S268. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
148 Roobol MJ, Van Vugt HA, Loeb S, The development and validation of a prostate cancer risk calculator including information on prostate volume from digital rectal examination: ERSPC Rotterdam. Tumor Biology. 2011;32:S42. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
149 Roobol MJ, Verbeek JFM, van der Kwast T, Kümmerlin IP, Kweldam CF, Van Leenders GJ. Improving the Rotterdam European randomized study of screening for prostate cancer risk calculator for initial prostate biopsy by incorporating the 2014 International Society of Urological Pathology Gleason grading and cribriform growth. European Urology. 2017;72(1):45–51. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E628162815
150 Roobol MJ, Zhu X, Schroder FH, A Calculator for prostate cancer risk 4 years after an initially negative screen: findings from ERSPC Rotterdam. European Urology. 2013;63(4):627–33. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E522841675
151 Rubio-Briones J, Casanova J, Dumont R, Prospective randomized controlled study of the role of PSA and PCA3 testing in a sequential manner in an opportunistic screening program for early diagnosis of prostate cancer. European Urology, Supplements. 2015;14(2):e315. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
152 Salami S, Fakhoury M, Ryniker L, Comparison of the prostate cancer prevention trial (PCPT) risk calculator and magnetic resonance imaging in selecting men for prostate biopsies. Journal of Urology. 2014;191(4):e549. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
153 Salami SS, Schmidt F, Laxman B, Combining urinary detection of TMPRSS2:ERG and PCA3 with serum PSA to predict diagnosis of prostate cancer. Urologic Oncology. 2013;31(5):566–71. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X921600800
154 Salami SS, Vira MA, Turkbey B, Multiparametric magnetic resonance imaging outperforms the Prostate Cancer Prevention Trial risk calculator in predicting clinically significant prostate cancer. Cancer. 2014;120(18):2876–82. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X924917122
155 Sandblom G, Varenhorst E, Rosell J, Lofman O, Carlsson P. Randomised prostate cancer screening trial: 20 year follow-up. BMJ. 2011;342:d1539. KQ1E9, KQ2E6, KQ3E1, KQ4E1, KQ5E121454449
156 Sasaki M, Ishidoya S, Ito A, Low percentage of free prostate-specific antigen is a strong predictor of later detection of prostate cancer among men with serum levels of total PSA 4.0 ng/ml or under. Urology. 2013;82(3):S69–S70. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
157 Sasaki M, Ishidoya S, Ito A, Low percentage of free prostate-specific antigen (PSA) is a strong predictor of later detection of prostate cancer among Japanese men with serum levels of total PSA of 4.0 ng/mL or less. Urology. 2014;84(5):1163–7. KQ1E1, KQ2E1, KQ3E5, KQ4E5, KQ5E125443923
158 Schoots IG, Petrides N, Giganti F, Magnetic resonance imaging in active surveillance of prostate cancer: a systematic review. Eur Urol. 2015;67(4):627–36. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E125511988
159 Seiler D, Randazzo M, Switzerland A, Long-term risk assessment of prostate cancer diagnosis in men with initial psa-values <1.0 ng/ml; results from the swiss arm of the european randomized study of screening for prostate cancer (ERSPC). Journal of Urology. 2012;187(4):e402. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
160 Shoag J, Mittal S, Halpern JA, Scherr D, Hu JC, Barbieri CE. Lethal prostate cancer in the PLCO Cancer Screening Trial. European Urology. 2016;70(1):2–5. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E627166670
161 Spratt DE, Zumsteg ZS, Ghadjar P, Comparison of high-dose (86.4 Gy) IMRT vs combined brachytherapy plus IMRT for intermediate-risk prostate cancer. BJU International. 2014;114(3):360–7. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E124447404
162 Steineck G, Helgesen F, Adolfsson J, Quality of life after radical prostatectomy or watchful waiting. N Engl J Med. 2002;347(11):790–6. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E112226149
163 Stephan C, Jung K, Semjonow A, Comparative assessment of urinary prostate cancer antigen 3 and TMPRSS2:ERG gene fusion with the serum [-2]proprostate-specific antigen-based prostate health index for detection of prostate cancer. Clinical Chemistry. 2013;59(1):280–8. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X923213079
164 Stone NN, Stone MM, Rosenstein BS, Unger P, Stock RG. Influence of pretreatment and treatment factors on intermediate to long-term outcome after prostate brachytherapy. Journal of Urology. 2011;185(2):495–500. KQ1E1, KQ2E1, KQ3E7, KQ4E6 KQ5E121167528
165 Stovsky M, Ponsky L, Vourganti S, Prostate-specific antigen/solvent interaction analysis: a preliminary evaluation of a new assay concept for detecting prostate cancer using urinary samples. Urology. 2011;78(3):601–5. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X921783231
166 Strobl AN, Thompson IM, Vickers AJ, Ankerst DP. The next generation of clinical decision making tools: development of a real-time prediction tool for outcome of prostate biopsy in response to a continuously evolving prostate cancer landscape. Journal of Urology. 2015;194(1):58–64. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E6a25636656
167 Taira AV, Merrick GS, Butler WM, Long-term outcome for clinically localized prostate cancer treated with permanent interstitial brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2011;79(5):1336–42. KQ1E1, KQ2E1, KQ3E7, KQ4E6 KQ5E1
168 Takeda K, Takai Y, Narazaki K, Treatment outcome of high-dose image-guided intensity-modulated radiotherapy using intra-prostate fiducial markers for localized prostate cancer at a single institute in Japan. Radiation Oncology. 2012;7:105. KQ1E1, KQ2E1, KQ3E5b, KQ4E5b, KQ5E122770471
169 Talcott JA, Manola J, Clark JA, Time course and predictors of symptoms after primary prostate cancer therapy. J Clin Oncol. 2003;21(21):3979–86. KQ1E1, KQ2E1, KQ3E6, KQ4E5, KQ5E114581420
170 Taylor KL, Luta G, Miller AB, Long-term disease-specific functioning among prostate cancer survivors and noncancer controls in the prostate, lung, colorectal, and ovarian cancer screening trial. Journal of Clinical Oncology. 2012;30(22):2768–75. KQ1E1, KQ2E1, KQ3E6, KQ4E7, KQ5E1, X322734029
171 Tewari A, Divine G, Chang P, Long-term survival in men with high grade prostate cancer: a comparison between conservative treatment, radiation therapy and radical prostatectomy--a propensity scoring approach. J Urol. 2007;177(3):911–5. KQ1E1, KQ2E1, KQ3E5b, KQ4E6, KQ5E117296374
172 Tyson MD 2nd, Castle EP. Racial disparities in survival for patients with clinically localized prostate cancer adjusted for treatment effects. Mayo Clinic Proceedings. 2014;89(3):300–7. KQ1E1, KQ2E1, KQ3E9, KQ4E6, KQ5E1, X824582189
173 Uchida T, Ohkusa H, Nagata Y, Hyodo T, Satoh T, Irie A. Treatment of localized prostate cancer using high-intensity focused ultrasound. BJU Int. 2006;97(1):56–61. KQ1E1, KQ2E1, KQ3E7, KQ4E6a, KQ5E116336329
174 van den Bergh RC, de Blok W, Van Muilekom E, Tillier C, Venderbos LD, van der Poel HG. Impact on quality of life of radical prostatectomy after initial active surveillance: more to lose? Scandinavian Journal of Urology. 2014;48(4):367–73. KQ1E1, KQ2E1, KQ3E6, KQ4E7, KQ5E124506062
175 Van Den Ende A, Rietbergen JB, Wildhagen MF, Bangma CH. Use of a risk calculator in a prostate unit to reduce overdiagnosis of prostate cancer. European Journal of Cancer. 2013;49:S709–S10. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
176 Van Leeuwen PJ, van den Bergh RC, Wolters T, Critical assessment of prebiopsy parameters for predicting prostate cancer metastasis and mortality. Canadian Journal of Urology. 2011;18(6):6018–24. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E3, X4, X8, X1022166329
177 Van Vugt H, Kranse R, Van Leeuwen P, Bangma C, Roobol M. Validation of the prostate cancer risk calculator in a clinical setting. Journal of Urology. 2011;185(4):e768–e9. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
178 Van Vugt HA, Kranse R, Steyerberg EW, Prospective validation of a risk calculator which calculates the probability of a positive prostate biopsy in a contemporary clinical cohort. European Journal of Cancer. 2012;48(12):1809–15. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E122406050
179 Van Vugt HA, Kranse R, Van Leeuwen PJ, Bangma CH, Roobol MJ. Validation of the ERSPC risk calculator in a clinical setting. European Urology, Supplements. 2011;10(2):34. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
180 Van Vugt HA, Roobol MJ, Kranse R, Prediction of prostate cancer in unscreened men: external validation of a risk calculator. European Journal of Cancer. 2011;47(6):903–9. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E121163642
181 Van Vugt HA, Roobol MJ, Van Leeuwen PJ, Steyerberg EW, Korfage I. Compliance with biopsy recommendations by a prostate cancer risk calculator. European Urology, Supplements. 2011;10(2):35. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1
182 Vickers AJ, Sjoberg D, Ankerst DP, Tangen CM, Goodman PJ, Thompson IM. The prostate cancer prevention trial (PCPT) risk calculator and the relationship between PSA and biopsy outcome. Journal of Urology. 2012;187(4):e492–e3. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1
183 Vora SA, Wong WW, Schild SE, Outcome and toxicity for patients treated with intensity modulated radiation therapy for localized prostate cancer. Journal of Urology. 2013;190(2):521–6. KQ1E1, KQ2E1, KQ3E7, KQ4E5, KQ5E123415964
184 Wallner LP, Jacobsen SJ. Prostate-specific antigen and prostate cancer mortality: a systematic review. Am J Prev Med. 2013;45(3):318–26. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E1, X10, X1123953359
185 Wei JT, Feng Z, Partin AW, Can urinary PCA3 supplement PSA in the early detection of prostate cancer? Journal of Clinical Oncology. 2014;32(36):4066–72. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X925385735
186 Weißbach L. “PSA screening - pros and cons”. Onkologie. 2012;35:1–2. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7
187 Welty CJ, Cowan JE, Nguyen H, Extended followup and risk factors for disease reclassification in a large active surveillance cohort for localized prostate cancer. Journal of Urology. 2015;193(3):807–11. KQ1E1, KQ2E1, KQ3E7a, KQ4E6, KQ5E125261803
188 Wiegel T, Bartkowiak D, Bottke D, Prostate-specific antigen persistence after radical prostatectomy as a predictive factor of clinical relapse-free survival and overall survival: 10-year data of the ARO 96-02 trial. International Journal of Radiation Oncology, Biology, Physics. 2015;91(2):288–94. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E1
189 Wilt TJ. Management of low risk and low PSA prostate cancer: long term results from the prostate cancer intervention versus observation trial. Minneapolis VA Center for Chronic Diseases Outcomes Research, Minneapolis MN. 2014;202:149–69. KQ1E1, KQ2E1, KQ3E6a, KQ4E6a, KQ5E1
190 Womble PR, Montie JE, Ye Z, Linsell SM, Lane BR, Miller DC. Contemporary use of initial active surveillance among men in Michigan with low-risk prostate cancer. Eur Urol. 2015;67(1):44–50. KQ1E1, KQ2E1, KQ3E6, KQ4E5, KQ5E125159890
191 Xia J, Gulati R, Au M, Gore JL, Lin DW, Etzioni R. Effects of screening on radical prostatectomy efficacy: the prostate cancer intervention versus observation trial. Journal of the National Cancer Institute. 2013;105(8):546–50. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E1, X3, X623411592
192 Xue WJ, Ying XL, Jiang JH, Xu YH. Prostate cancer antigen 3 as a biomarker in the urine for prostate cancer diagnosis: a meta-analysis. Journal of Cancer Research and Therapeutics. 2014;10:C218–C21. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, X9, X1025450286
193 Yaxley JW, Coughlin GD, Chambers SK, Robot-assisted laparoscopic prostatectomy versus open radical retropubic prostatectomy: early outcomes from a randomised controlled phase 3 study. Lancet. 2016;388(10049):1057–66. KQ1E1, KQ2E1, KQ3E6, KQ4E6, KQ5E127474375
194 Yorozu A, Kuroiwa N, Takahashi A, Permanent prostate brachytherapy with or without supplemental external beam radiotherapy as practiced in Japan: outcomes of 1300 patients. Brachytherapy. 2015;14(2):111–7. KQ1E1, KQ2E1, KQ3E7, KQ4E7, KQ5E125127123
195 Zavaski ME, Meyer CP, Sammon JD, Differences in prostate-specific antigen testing among urologists and primary care physicians following the 2012 USPSTF recommendations. JAMA Intern Med. 2016;176(4):546–7. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E1, X3, X1726857148
196 Zhu X, Van Leeuwen PJ, Bul M, Disease-specific survival of men with prostate cancer detected during the screening interval: results of the European randomized study of screening for prostate cancer-Rotterdam after 11 years of follow-up. European Urology. 2011;60(2):330–6. KQ1E6, KQ2E6, KQ3E1, KQ4E1, KQ5E121601352
197 Zhu Y, Wang JY, Shen YJ, External validation of the Prostate Cancer Prevention Trial and the European Randomized Study of Screening for Prostate Cancer risk calculators in a Chinese cohort. Asian Journal of Andrology. 2012;14(5):738–44. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E2a22561907