# Appendix A Detailed Methods

## Literature Search Strategy

### Cochrane

- #1 MeSH descriptor: [Mass Screening] explode all trees
- #2 screening
- #3 MeSH descriptor: [Prostatic Neoplasms] explode all trees
- #4 prostate
- #5 (#1 or #2) and #4
- #6 MeSH descriptor: [Early Detection of Cancer] explode all trees #7 MeSH descriptor: [Early Diagnosis] explode all trees
- #8 early stage
- #9 #6 or #7 or #8
- #10 #5 and #9
- #11 MeSH descriptor: [Prostate-Specific Antigen] explode all trees
- #12 #10 and #11 Publication Year from 2011 to 2016

### Ovid MEDLINE

1. exp “Prostatic Neoplasms”/ or prostate cancer.ti. or prostatic neoplasm*.ti. (115794)
2. “Risk Assessment”/ (209015)
3. “Survival Analysis”/ (113137)
4. “Treatment Outcome”/ (764101)
5. screening.mp. or Mass Screening/ (467821)
6. “Prostate-Specific Antigen”/ or PSA.mp. or prostate specific antigen.mp. (41541)
7. early diagnosis/ or early stage.mp. (89074)
8. “Watchful Waiting”/ or watchful waiting.ti,ab. (3945)
9. 2 or 3 or 4 or 8 (1002677)
10. 6 or 7 (129868)
11. 1 and 9 and 10 (5667)
12. limit 11 to (yr=“2007 -Current” and english) (3355)
13. exp “sensitivity and specificity”/ (489386)
14. (sensitivity or specificity).tw. (851972)
15. ((pre-test or pretest) adj probability).tw. (1699)
16. ((post-test or post test) adj probability).tw. (450)
17. likelihood ratio*.tw. (11693)
18. test performance.mp. (6762)
19. “predictive value of tests”/ or negative predictive value.mp. or positive predictive value.mp. (193939)
20. diagnostic accuracy.mp. (31481)
21. pca 3.mp. (86)
22. dd3.mp. (99)
23. 4k score.mp. (1)
24. prostate health index.mp. (133)
25. four-kallikrein panel.mp. (9)
26. kallikreins/ (8482)
27. “early detection of cancer”.mp. or “Early Detection of Cancer”/ (15663)
28. “Kallikreins”/ and (“Prostate-Specific Antigen”/ or (“Tumor Markers, Biological”/ and prostat*.mp.)) [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (873)
29. or/13-20,27 (1227873)
30. prostate cancer gene 3.mp. (76)
31. or/21-26,28,30 (8848)
32. 29 and 31 (902)
33. limit 32 to (yr=“2007 -Current” and english) (468)
34. 12 or 33 (3753)
35. Minority Groups/ (11981)
36. ethnology.fs. (141458)
37. exp Continental Population Groups/ (188428)
38. 35 or 36 or 37 (279407)
39. risk.mp. or exp Risk/ (2010071)
40. 1 and 38 and 39 (1447)
41. limit 40 to (english language and yr=“2007 -Current”) (888)
42. 34 or 41 (4570)
43. treatment outcome.mp. or exp Treatment Outcome/ (801440)
44. prognosis/ or disease-free survival/ or prognos*.ti. or disease free.tw. (503696)
45. 43 or 44 (1232919)
46. 1 and 7 and 45 (351)
47. limit 46 to (english language and yr=“2007 -Current”) (156)
48. 42 or 47 (4630)
49. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (319580)
50. side effect$.ti,ab. (204402)
51. (unintended adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (1111)
52. (unintentional adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (175)
53. (unwanted adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (4963)
54. (unexpected adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (5142)
55. (undesirable adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (6613)
56. Harm Reduction/ (2016)
57. (ae or co).fs. (3083573)
58. or/48-57 (3392846)
59. 1 and (5 or 6) and 58 (7541)
60. 27 and 59 (411)
61. limit 60 to (english language and yr=“2007 -Current”) (397)
62. 48 or 61 (4710)
63. remove duplicates from 62 (4459)
64. limit 63 to (english language and yr=“2011 -Current”) (2859)
65. from 64 keep 1-2492 (2492)
66. quality of life.mp. or “Quality of Life”/ (252030)
67. 6 and 7 and 66 (60)
68. limit 67 to (english language and yr=“2011 -Current”) (22)
69. 1 and 68 (15)
70. 69 not 65 (9)
71. “Patient Acceptance of Health Care”/ (36136)
72. exp Attitude to Health/ (343442)
73. 1 and (5 or 6) and (71 or 72) (996)
74. (7 or 27) and 73 (244)
75. limit 74 to (english language and yr=“2011 -Current”) (173)
76. 76 75 not 65 (117)
77. remove duplicates from 76 (108)
78. limit 77 to (english language and yr=“2011 -Current”) (108)
79. 79 70 or 78 (116)
80. remove duplicates from 79 (116)
81. limit 80 to ed=20160201-20161005 (22)

### Embase

#16 OR #19

#19

‘prostate’/exp OR prostate AND (‘cancer’/exp OR cancer) AND (‘screening’/exp OR screening) AND (‘prostate specific antigen’/exp/dd_ct AND [humans]/lim OR (prostate AND specific AND antigen:ti) OR psa:ti) AND (‘risk benefit analysis’/exp OR ‘risk’ OR ‘risk reduction’/exp OR ‘attributable risk’/exp OR ‘low risk patient’/exp OR ‘risk management’/exp OR ‘genetic risk’/exp) AND [english]/lim AND [1-2-2016]/sd

#16

‘prostate specific antigen’/exp/dd_ct AND [humans]/lim OR (prostate AND specific AND antigen:ti) OR psa:ti AND (‘sensitivity and specificity’/exp OR ‘sensitivity and specificity’) AND (‘health care quality’/exp OR ‘health care quality’) NOT (‘psoriatic arthritis’/exp OR ‘psoriatic arthritis’) OR (‘prostate’/exp OR prostate AND (‘cancer’/exp OR cancer) AND (‘screening’/exp OR screening) AND (‘sensitivity and specificity’/exp OR ‘sensitivity and specificity’)) AND [english]/lim AND (‘early diagnosis’/exp OR ‘cancer classification’/exp) AND [1-2-2016]/sd

### Web of Science

# 14

469

For: A Comparative Effectiveness Trial of Alternate Formats for Presenting Benefits and Harms Information for Low-Value Screening Services A Randomized Clinical Trial

Refined by: TOPIC: (prostate) AND PUBLICATION YEARS: (2015 OR 2014 OR 2013 OR 2012 OR 2011) AND DOCUMENT TYPES: (ARTICLE OR REVIEW) AND LANGUAGES: (ENGLISH)

Indexes=BKCI-S, ESCI, SSCI, BKCI-SSH, SCI-EXPANDED, A&HCI, IC, CPCI-SSH, CPCIS, CCR-EXPANDED Timespan=All years

# 13

483

For: A Comparative Effectiveness Trial of Alternate Formats for Presenting Benefits and Harms Information for Low-Value Screening Services A Randomized Clinical Trial

Refined by: TOPIC: (prostate) AND PUBLICATION YEARS: (2015 OR 2014 OR 2013 OR 2012 OR 2011) AND DOCUMENT TYPES: (ARTICLE OR REVIEW)

Indexes=BKCI-S, ESCI, SSCI, BKCI-SSH, SCI-EXPANDED, A&HCI, IC, CPCI-SSH, CPCIS, CCR-EXPANDED Timespan=All years

# 12

580

For: A Comparative Effectiveness Trial of Alternate Formats for Presenting Benefits and Harms Information for Low-Value Screening Services A Randomized Clinical Trial

Refined by: TOPIC: (prostate) AND PUBLICATION YEARS: (2015 OR 2014 OR 2013 OR 2012 OR 2011)

Indexes=BKCI-S, ESCI, SSCI, BKCI-SSH, SCI-EXPANDED, A&HCI, IC, CPCI-SSH, CPCIS, CCR-EXPANDED Timespan=All years

# 11

715

For: A Comparative Effectiveness Trial of Alternate Formats for Presenting Benefits and Harms Information for Low-Value Screening Services A Randomized Clinical Trial

Refined by: TOPIC: (prostate)

Indexes=BKCI-S, ESCI, SSCI, BKCI-SSH, SCI-EXPANDED, A&HCI, IC, CPCI-SSH, CPCIS, CCR-EXPANDED Timespan=All years

# 10

7,537

For: A Comparative Effectiveness Trial of Alternate Formats for Presenting Benefits and Harms Information for Low-Value Screening Services A Randomized Clinical Trial

# 9

424

#8 AND #1

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 8

591,381

TOPIC: (effectiveness)

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 7

22

#6 AND #5

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 6

1,033

TOPIC: (risk) AND TOPIC: (calculator*)

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 5

1,384

#4 AND #3

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 4

368,489

TOPIC: (early stage) OR TOPIC: (screen detected)

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 3

4,282

#2 AND #1

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 2

27,989

TOPIC: (prostate cancer antigen)

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

# 1

11,025

TOPIC: (prostate cancer) AND TOPIC: (screening)

Indexes=SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH, BKCI-S, BKCI-SSH, ESCI, CCR-EXPANDED, IC Timespan=All years

Appendix A Figure 1 Literature Flow Diagram

Appendix A Figure 1 is a flow chart that summarizes the search and selection of articles. There were 4,498 citations identified through literature databases and an additional 150 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 4,148 unique citations were screened at the title/abstract stage. The full text of 302 citations were examined for inclusion for one or more of the five Key Questions. The following number of articles were included for Key Question 1 (n=23), Key Question 2 (n=14), Key Question 3 (n=23), Key Question 4 (n=38), and Key Question 5 (n=13). Reasons for excluding the other articles are available in Appendix B.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Population | KQs 1, 2, 5: Asymptomatic men^*^ KQs 3, 4: Men with screen-detected or early-stage prostate cancer (defined as stage I or II) | KQs 1, 2, 5: Symptomatic men KQs 3, 4: Men with later-stage prostate cancer^†^; men with refractory, hormone refractory, or recurrent prostate cancer
Setting | Primary care or specialty care settings in countries categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme) | Countries not categorized as “Very High” on the Human Development Index
Interventions | KQs 1, 2: PSA-based screening (single-threshold PSA test, age-specific thresholds, velocity, doubling time, variable screening intervals) KQs 3, 4:; - Surgery (radical prostatectomy, including different surgical techniques, such as nerve sparing, robotics); - Cryosurgery; - Hormone therapy (androgen deprivation therapy via luteinizing hormone-releasing hormone agonists, antiandrogen therapy, and/or orchiectomy); - Ultrasonography (high-intensity focused ultrasonography); - Radiation therapy (external-beam radiation therapy, proton beam therapy, brachytherapy); - Ablative therapy; - Watchful waiting; - Active surveillance; KQ 5: Risk prediction models to predict clinically important prostate cancer | KQs 1, 2: Non-PSA-based methods of screening for prostate cancer, performed alone (e.g., digital rectal examination) KQs 3, 4: Chemotherapy (typically used for the treatment of later-stage cancer) KQ 5: Risk prediction models for any prostate cancer
Comparisons | KQs 1, 2: Usual care; no screening KQs 3, 4: No treatment KQ 5: PSA-based screening only, usual care
Outcomes | KQ 1: Prostate cancer mortality; all-cause mortality; prostate cancer-specific morbidity (i.e., bone pain from metastases, urinary obstruction); incidence of advanced-stage cancer KQ 2: False positives; physical harms of screening or biopsy; psychological harms; overdiagnosis KQs 3, 4: Mortality (overall and disease-specific); quality of life (overall and disease-specific); functioning (overall and disease-specific); bowel, urinary, and sexual dysfunction; psychological effects (e.g., mental status, depression, cognitive dysfunction); endocrinological effects (e.g., bone health, hot flashes, gynecomastia); surgical complications KQ 5: Test performance (area under the curve, sensitivity, specificity); detection of clinically significant or high-grade prostate cancer; positive predictive value of biopsy
Duration | KQ 1: Long-term prostate cancer mortality, long-term all-cause mortality KQs 3, 4: 30 days for perioperative complications; >12 months for other harms
Study designs | KQ 1: Randomized, controlled trials; systematic reviews (of included study designs); meta-analyses KQs 2–5: Randomized, controlled trials; cohort studies; uncontrolled observational studies of harms^‡^ | Other study designs
Study quality | Good- and fair-quality studies | Poor-quality studies
Language | English | Non-English
Timeframe | KQs 1–4: January 1, 2011 to present^§^ KQ 5: January 2006 to present | KQs 1–4: Published before January 1, 2011 KQ 5: Published before January 2006

* We will consider asymptomatic men as those without symptoms that are highly suspicious for prostate cancer. Many older men have chronic, stable lower urinary tract symptoms (e.g., due to benign prostate hyperplasia) that are not generally associated with an increased risk for prostate cancer (1).

† Treatments for men with later-stage prostate cancer (stages III or IV) differ from those for men with early-stage prostate cancer (stages I or II); large, population-based PSA-based screening studies have primarily detected early-stage cancer (90% to 96% of cancers detected) (2, 3).

‡ Sample size of at least 1,000; smaller samples sizes are to be included only if randomized, controlled trials, cohort studies, and larger uncontrolled studies are not available.

§ Although the review’s search dates for trials of prostate cancer screening effectiveness will cover 2011 through the present, the USPSTF will consider evidence from older trials included in prior systematic reviews. That is, the evidence review will primarily search for new studies or updates of previous trials but the USPSTF, in making its recommendation, will consider the totality of evidence available, not just studies published since 2011.

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^48^ | Was there valid random assignment? Was allocation concealed? Was eligibility criteria specified? Were groups similar at baseline? Was a difference in attrition between the groups after randomization not present? Were outcome assessors blinded? Were measurements equal, valid and reliable? Was the risk of contamination very low or not present? Was there adequate adherence to the intervention? Were statistical methods acceptable? Was the handling of missing data appropriate?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottowa Scale and the NICE methodology checklists^61,62^ | Was there representativeness of the exposed cohort? Was the non-exposed cohort systematically selected? Was the ascertainment of exposure reported? Was eligibility criteria specified? Were groups similar at baseline? Was the outcome of interest not present at baseline? Were measurements equal, valid, and reliable? Were outcome assessors blinded? Was followup long enough for the outcome to occur? Was there acceptable followup? Was there adjustment for confounders?
Assessment of Multiple Systematic Reviews (AMSTAR)^219^ | Was an ‘a priori’ design provided? Was there dual study selection? Was there dual data extraction? Was a comprehensive literature search performed? Was a list of studies included provided? Was a list of studies excluded provided? Were the characteristics of the included studies provided? Was the scientific quality of the included studies assessed and documented? Was the scientific quality of the included studies used appropriately in formulating conclusions? Were the methods used to combine the findings of the studies (i.e., pooled results) appropriate? Was the likelihood of publication bias assessed? Were potential conflicts of interest/source(s) of support of the systematic review stated? Were potential conflicts of interest/source(s) of support of the included studies stated?