# References

1 Mehravaran S, Duarte PB, Brown SI, . The UCLA preschool vision program, 2012-2013. J AAPOS. 2016 Feb;20(1):63-7. doi: 10.1016/j.jaapos.2015.10.018. PMID: 26917075.26917075
2 Griffith JF, Wilson R, Cimino HC, . The use of a mobile van for school vision screening: Results of 63 841 evaluations. Am J Ophthalmol. 2016 Mar;163:108-14 e1. doi: 10.1016/j.ajo.2015.11.026. PMID: 26621684.26621684
3 Tarczy-Hornoch K, Cotter SA, Borchert M, . Prevalence and causes of visual impairment in Asian and non-Hispanic white preschool children: multi-ethnic pediatric eye disease study. Ophthalmology. 2013 Jun;120(6):1220-6. doi: 10.1016/j.ophtha.2012.12.029. PMID: 23561327.23561327
4 McKean-Cowdin R, Cotter SA, Tarczy-Hornoch K, . Prevalence of amblyopia or strabismus in asian and non-Hispanic white preschool children: multi-ethnic pediatric eye disease study. Ophthalmology. 2013 Oct;120(10):2117-24. doi: 10.1016/j.ophtha.2013.03.001. PMID: 23697956.23697956
5 Doshi NR, Rodriguez ML. Amblyopia. Am Fam Physician. 2007 Feb 1;75(3):361-7. PMID: 17304867.17304867
6 Pascual M, Huang J, Maguire MG, . Risk factors for amblyopia in the Vision In Preschoolers study. Ophthalmology. 2014 Mar;121(3):622-9.e1. doi: 10.1016/j.ophtha.2013.08.040. PMID: 24140117.24140117
7 Ying GS, Huang J, Maguire MG, . Associations of anisometropia with unilateral amblyopia, interocular acuity difference, and stereoacuity in preschoolers. Ophthalmology. 2013 Mar;120(3):495-503. doi: 10.1016/j.ophtha.2012.08.014. PMID: 23174398.23174398
8 Arnold RW. Amblyopia risk factor prevalence. J Pediatr Ophthalmol Strabismus. 2013 Jul-Aug;50(4):213-7. doi: 10.3928/01913913-20130326-01. PMID: 23556991.23556991
9 Pai AS, Rose KA, Leone JF, . Amblyopia prevalence and risk factors in Australian preschool children. Ophthalmology. 2012 Jan;119(1):138-44. doi: 10.1016/j.ophtha.2011.06.024. PMID: 21963268.21963268
10 Pai AS, Wang JJ, Samarawickrama C, . Prevalence and risk factors for visual impairment in preschool children the sydney paediatric eye disease study. Ophthalmology. 2011 Aug;118(8):1495-500. doi: 10.1016/j.ophtha.2011.01.027. PMID: 21529955.21529955
11 Ciner EB, Schmidt PP, Orel-Bixler D, . Vision screening of preschool children: evaluating the past, looking toward the future. Optom Vis Sci. 1998 Aug;75(8):571-84. PMID: 9734801.9734801
12 Pan Y, Tarczy-Hornoch K, Cotter SA, . Visual acuity norms in pre-school children: the multi-ethnic pediatric eye disease study. Optom Vis Sci. 2009 Jun;86(6):607-12. doi: 10.1097/OPX.0b013e3181a76e55. PMID: 19430325.19430325
13 Leat SJ, Yadav NK, Irving EL. Development of visual acuity and contrast sensitivity in children. J Optom. 2009;2(1):19-26. doi: 10.3921/joptom.2009.19.
14 Friedman DS, Repka MX, Katz J, . Prevalence of amblyopia and strabismus in white and African American children aged 6 through 71 months the Baltimore Pediatric Eye Disease Study. Ophthalmology. 2009 Nov;116(11):2128-34.e1-2. doi: 10.1016/j.ophtha.2009.04.034. PMID: 19762084.19762084
15 Multi-Ethnic Pediatric Eye Disease Study Group. Prevalence and causes of visual impairment in African-American and Hispanic preschool children: the multi-ethnic pediatric eye disease study. Ophthalmology. 2009 Oct;116(10):1990-2000 e1. doi: 10.1016/j.ophtha.2009.03.027. PMID: 19592106.19592106
16 Ying GS, Maguire MG, Cyert LA, . Prevalence of vision disorders by racial and ethnic group among children participating in head start. Ophthalmology. 2014 Mar;121(3):630-6. doi: 10.1016/j.ophtha.2013.09.036. PMID: 24183422.24183422
17 Donahue SP, Baker JD, Scott WE, . Lions Clubs International Foundation Core Four Photoscreening: results from 17 programs and 400,000 preschool children. J AAPOS. 2006 Feb;10(1):44-8. doi: 10.1016/j.jaapos.2005.08.007. PMID: 16527679.16527679
18 Birch EE, Holmes JM. The clinical profile of amblyopia in children younger than 3 years of age. J AAPOS. 2010 Dec;14(6):494-7. doi: 10.1016/j.jaapos.2010.10.004. PMID: 21168072.21168072
19 Multi-Ethnic Pediatric Eye Disease Study Group. Prevalence of myopia and hyperopia in 6- to 72-month-old African American and Hispanic children: the multi-ethnic pediatric eye disease study. Ophthalmology. 2010 Jan;117(1):140-7 e3. doi: 10.1016/j.ophtha.2009.06.009. PMID: 19926137.19926137
20 Wen G, Tarczy-Hornoch K, McKean-Cowdin R, . Prevalence of myopia, hyperopia, and astigmatism in non-Hispanic white and Asian children: multi-ethnic pediatric eye disease study. Ophthalmology. 2013 Oct;120(10):2109-16. doi: 10.1016/j.ophtha.2013.06.039. PMID: 23953098.23953098
21 Giordano L, Friedman DS, Repka MX, . Prevalence of refractive error among preschool children in an urban population: the Baltimore Pediatric Eye Disease Study. Ophthalmology. 2009 Apr;116(4):739-46, 46.e1-4. doi: 10.1016/j.ophtha.2008.12.030. PMID: 19243832.19243832
22 Gunnlaugsdottir E, Arnarsson A, Jonasson F. Prevalence and causes of visual impairment and blindness in Icelanders aged 50 years and older: the Reykjavik Eye Study. Acta Ophthalmol Scand. 2008;86(7):778-85. doi: 10.1111/j.1755-3768.2008.01191.x.
23 Rahi J, Logan S, Timms C, . Risk, causes, and outcomes of visual impairment after loss of vision in the non-amblyopic eye: a population-based study. Lancet. 2002 Aug 24;360(9333):597-602. PMID: 12241931.12241931
24 van Leeuwen R, Eijkemans MJ, Vingerling JR, . Risk of bilateral visual impairment in individuals with amblyopia: the Rotterdam study. Br J Ophthalmol. 2007 Nov;91(11):1450-1. doi: 10.1136/bjo.2006.113670. PMID: 17522151.17522151
25 van Hof-Van Duin J, Evenhuis-van Leunen A, Mohn G, . Effects of very low birth weight (VLBW) on visual development during the first year after term. Early Hum Dev. 1989 Dec;20(3-4):255-66. PMID: 2606061.2606061
26 Cotter SA, Varma R, Tarczy-Hornoch K, . Risk factors associated with childhood strabismus: the Multi-Ethnic Pediatric Eye Disease and Baltimore Pediatric Eye Disease Studies. Ophthalmology. 2011 Nov;118(11):2251-61. doi: 10.1016/j.ophtha.2011.06.032. PMID: 21856012.21856012
27 Tarczy-Hornoch K, Varma R, Cotter SA, . Risk factors for decreased visual acuity in preschool children: the multi-ethnic pediatric eye disease and Baltimore pediatric eye disease studies. Ophthalmology. 2011 Nov;118(11):2262-73. doi: 10.1016/j.ophtha.2011.06.033. PMID: 21856014.21856014
28 McKean-Cowdin R, Varma R, Cotter SA, . Risk factors for astigmatism in preschool children: the multi-ethnic pediatric eye disease and Baltimore pediatric eye disease studies. Ophthalmology. 2011 Oct;118(10):1974-81. doi: 10.1016/j.ophtha.2011.06.031. PMID: 21856010.21856010
29 Borchert MS, Varma R, Cotter SA, . Risk factors for hyperopia and myopia in preschool children the multi-ethnic pediatric eye disease and Baltimore pediatric eye disease studies. Ophthalmology. 2011 Oct;118(10):1966-73. doi: 10.1016/j.ophtha.2011.06.030. PMID: 21856013.21856013
30 Quinn GE, Dobson V, Davitt BV, . Progression of myopia and high myopia in the Early Treatment for Retinopathy of Prematurity study: findings at 4 to 6 years of age. J AAPOS. 2013 Apr;17(2):124-8. doi: 10.1016/j.jaapos.2012.10.025. PMID: 23622444.23622444
31 Prevalence of myopia and hyperopia in 6- to 72-month-old African American and Hispanic children: the multi-ethnic pediatric eye disease study. Ophthalmology. 2010 Jan;117(1):140-7.e3. doi: 10.1016/j.ophtha.2009.06.009. PMID: 19926137.19926137
32 Webber AL, Wood J. Amblyopia: prevalence, natural history, functional effects and treatment. Clin Exp Optom. 2005 Nov;88(6):365-75. PMID: 16329744.16329744
33 Pike MG, Holmstrom G, de Vries LS, . Patterns of visual impairment associated with lesions of the preterm infant brain. Dev Med Child Neurol. 1994 Oct;36(10):849-62. PMID: 7926317.7926317
34 Carlton J, Karnon J, Czoski-Murray C, . The clinical effectiveness and cost-effectiveness of screening programmes for amblyopia and strabismus in children up to the age of 4-5 years: a systematic review and economic evaluation. Health Technol Assess. 2008 Jun;12(25):iii, xi-194. PMID: 18513466.18513466
35 Epelbaum M, Milleret C, Buisseret P, . The sensitive period for strabismic amblyopia in humans. Ophthalmology. 1993 Mar;100(3):323-7. PMID: 8460000.8460000
36 Flynn JT, Schiffman J, Feuer W, . The therapy of amblyopia: an analysis of the results of amblyopia therapy utilizing the pooled data of published studies. Trans Am Ophthalmol Soc. 1998;96:431-50; discussion 50-3. PMID: 10360300.10360300
37 American Academy of Ophthalmology Pediatric Ophthalmology/Strabismus Panel. Preferred Practice Pattern Guidelines. Amblyopia. San Francisco, CA: American Academy of Ophthalmology; 2015. http://www.aao.org/preferred-practice-pattern/amblyopia-ppp--september-2012. Accessed May 27, 2015.
38 Horwood J, Waylen A, Herrick D, . Common visual defects and peer victimization in children. Invest Ophthalmol Vis Sci. 2005 Apr;46(4):1177-81. doi: 10.1167/iovs.04-0597. PMID: 15790876.15790876
39 Packwood EA, Cruz OA, Rychwalski PJ, . The psychosocial effects of amblyopia study. J AAPOS. 1999 Feb;3(1):15-7. PMID: 10071896.10071896
40 O'Connor AR, Birch EE, Anderson S, . Relationship between binocular vision, visual acuity, and fine motor skills. Optom Vis Sci. 2010 Dec;87(12):942-7. doi: 10.1097/OPX.0b013e3181fd132e. PMID: 21057348.21057348
41 Webber AL, Wood JM, Gole GA, . The effect of amblyopia on fine motor skills in children. Invest Ophthalmol Vis Sci. 2008 Feb;49(2):594-603. doi: 10.1167/iovs.07-0869. PMID: 18235004.18235004
42 Webber AL, Wood JM, Gole GA, . Effect of amblyopia on self-esteem in children. Optom Vis Sci. 2008 Nov;85(11):1074-81. doi: 10.1097/OPX.0b013e31818b9911. PMID: 18981922.18981922
43 Chua B, Mitchell P. Consequences of amblyopia on education, occupation, and long term vision loss. Br J Ophthalmol. 2004 Sep;88(9):1119-21. doi: 10.1136/bjo.2004.041863. PMID: 15317699.15317699
44 Rahi JS, Cumberland PM, Peckham CS. Does amblyopia affect educational, health, and social outcomes? Findings from 1958 British birth cohort. BMJ. 2006 Apr 8;332(7545):820-5. doi: 10.1136/bmj.38751.597963.AE. PMID: 16520328.16520328
45 Keech RV, Kutschke PJ. Upper age limit for the development of amblyopia. J Pediatr Ophthalmol Strabismus. 1995 Mar-Apr;32(2):89-93. PMID: 7629676.7629676
46 Miller JM, Lessin HR. Instrument-based pediatric vision screening policy statement. Pediatrics. 2012 Nov;130(5):983-6. doi: 10.1542/peds.2012-2548. PMID: 23109679.23109679
47 Choong YF, Chen AH, Goh PP. A comparison of autorefraction and subjective refraction with and without cycloplegia in primary school children. Am J Ophthalmol. 2006 Jul;142(1):68-74. doi: 10.1016/j.ajo.2006.01.084. PMID: 16815252.16815252
48 American Optometric Association. Optometric Clinical Practice Guideline: Care of the Patient with Amblyopia. St. Louis, MO: American Optometric Association; 1994. http://aoa.org/documents/CPG-4.pdf. Accessed 12 May, 2016.
49 Pediatric Eye Disease Investigator Group. Treatment of anisometropic amblyopia in children with refractive correction. Ophthalmol Eye Dis. 2006;113:895-903.
50 American Academy of Ophthalmology Pediatric Ophthalmology/Strabismus Panel. Preferred Practice Pattern Guidelines. Pediatric Eye Evaluations. San Francisco, CA: American Academy of Ophthalmology; 2012. http://www.aao.org/preferred-practice-pattern/pediatric-eye-evaluations-ppp--september-2012. Accessed 27 May, 2015.
51 American Association for Pediatric Ophthalmology and Strabismus. Amblyopia. San Francisco, CA: American Association for Pediatric Ophthalmology and Strabismus; 2015. http://www.aapos.org/terms/conditions/21. Accessed 22 May, 2015.
52 American Optometric Association. Fact Sheets on Optometric Vision Therapy. Reimbursement Packet American Optometric Association. St. Louis, MO: January 2011. http://www.aoa.org/documents/optometrists/qi/vision-therapy-reimbursement.pdf
53 Rawstron JA, Burley CD, Elder MJ. A systematic review of the applicability and efficacy of eye exercises. J Pediatr Ophthalmol Strabismus. 2005 Mar-Apr;42(2):82-8. PMID: 15825744.15825744
54 Williams C. Amblyopia. BMJ Clin Evid. 2009;2009PMID: 21726480.21726480
55 Benegas N, Okner G, Mohoney B. Vision therapy. Technology Assessment 68 Institute for Clinical Systems Improvement (ICSI). Bloomington, MN: 2003.
56 Kemper AR, Wallace DK, Patel N, . Preschool vision testing by health providers in the United States: findings from the 2006-2007 Medical Expenditure Panel Survey. J AAPOS. 2011 Oct;15(5):480-3. doi: 10.1016/j.jaapos.2011.07.007. PMID: 22108361.22108361
57 Marsh-Tootle WL, Funkhouser E, Frazier MG, . Knowledge, attitudes, and environment: what primary care providers say about pre-school vision screening. Optom Vis Sci. 2010 Feb;87(2):104-11. doi: 10.1097/OPX.0b013e3181cc8d7c. PMID: 20061988.20061988
58 Kemper AR, Helfrich A, Talbot J, . Improving the rate of preschool vision screening: an interrupted time-series analysis. Pediatrics. 2011 Nov;128(5):e1279-84. doi: 10.1542/peds.2010-3679. PMID: 21987706.21987706
59 Kemper AR, Clark SJ. Preschool vision screening in pediatric practices. Clin Pediatr (Phila). 2006 Apr;45(3):263-6. PMID: 16708140.16708140
60 Marsh-Tootle WL, Wall TC, Tootle JS, . Quantitative pediatric vision screening in primary care settings in Alabama. Optom Vis Sci. 2008 Sep;85(9):849-56. doi: 10.1097/OPX.0b013e318185282a. PMID: 18772721.18772721
61 Couser NL, Esmail FQ, Hutchinson AK. Vision screening in the pediatrician's office. Open J Ophthalmol. 2012;2:9-13.
62 Kemper AR, Clark SJ. Preschool vision screening by family physicians. J Pediatr Ophthalmol Strabismus. 2007 Jan-Feb;44(1):24-7; quiz 43-4. PMID: 17274331.17274331
63 Kemper AR, Crews JE, Strickland B, . Vision screening among children aged 6 years--Medical Expenditure Panel Survey, United States, 2009-2010. MMWR Suppl. 2014 Sep 12;63(2):43-6. PMID: 25208257.25208257
64 Department of Health and Human Services, Office of the Inspector General. Most Medicaid children in nine states are not receiving all required preventive screening services, OEI-05-08-00520. Washington, DC: U.S. Department of Health and Human Services, Office of the Inspector General; 2010.
65 Schmidt P, Maguire M, Dobson V, . Comparison of preschool vision screening tests as administered by licensed eye care professionals in the Vision In Preschoolers Study. Ophthalmology. 2004 Apr;111(4):637-50. doi: 10.1016/j.ophtha.2004.01.022. PMID: 15051194.15051194
66 Lowry EA, Wang W, Nyong'o O. Objective vision screening in 3-year-old children at a multispecialty practice. J AAPOS. 2015 Feb;19(1):16-20. doi: 10.1016/j.jaapos.2014.09.008. PMID: 25727580.25727580
67 Chou R, Dana T, Bougatsos C. Screening for Visual Impairment in Children Ages 1-5 Years. Systematic Review to Update the 2004 U.S. Preventive Services Task Force Recommendation Evidence Syntheses No. 81. Report No.: 11-05151-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; February 2011.
68 Owens DK, Lohr KN, Atkins D, . AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010 May;63(5):513-23. doi: 10.1016/j.jclinepi.2009.03.009. PMID: 19595577.19595577
69 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312-24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
70 Holladay JT. Visual acuity measurements. J Cataract Refract Surg. 2004 Feb;30(2):287-90. doi: 10.1016/j.jcrs.2004.01.014. PMID: 15030802.15030802
71 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21-35. PMID: 11306229.11306229
72 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ. 2004 Jul 17;329(7458):168-9. doi: 10.1136/bmj.329.7458.168. PMID: 15258077.15258077
73 Guyatt G, Rennie D, Jaeschke R, . Diagnostic tests. In: Guyatt G, Rennie D, eds. Users' guides to the medical literature. Chicago: AMA Press; 2002:121-40.
74 Williams C, Harrad RA, Harvey I, . Screening for amblyopia in preschool children: results of a population-based, randomised controlled trial. ALSPAC Study Team. Avon Longitudinal Study of Pregnancy and Childhood. Ophthalmic Epidemiol. 2001 Dec;8(5):279-95. PMID: 11922382.11922382
75 Williams C, Northstone K, Harrad RA, . Amblyopia treatment outcomes after screening before or at age 3 years: follow up from randomised trial. BMJ (Clinical research ed.); 2002. p. 1549.
76 Williams C, Northstone K, Harrad RA, . Amblyopia treatment outcomes after preschool screening v school entry screening: observational data from a prospective cohort study. Br J Ophthalmol. 2003 Aug;87(8):988-93. PMID: 12881342.12881342
77 Afsari S, Rose KA, Pai AS, . Diagnostic reliability and normative values of stereoacuity tests in preschool-aged children. Br J Ophthalmol. 2013 Mar;97(3):308-13. doi: 10.1136/bjophthalmol-2012-302192. PMID: 23292927.23292927
78 Arthur BW, Riyaz R, Rodriguez S, . Field testing of the plusoptiX S04 photoscreener. J AAPOS. 2009 Feb;13(1):51-7. doi: 10.1016/j.jaapos.2008.08.016. PMID: 19121596.19121596
79 Barry JC, Konig HH. Non-cycloplegic screening for amblyopia via refractive findings with the Nikon Retinomax hand held autorefractor in 3 year old kindergarten children. Br J Ophthalmol. 2001 Oct;85(10):1179-82. PMID: 11567961.11567961
80 Barry JC, Konig HH. Test characteristics of orthoptic screening examination in 3 year old kindergarten children. Br J Ophthalmol. 2003 Jul;87(7):909-16. PMID: 12812897.12812897
81 Bertuzzi F, Orsoni JG, Porta MR, . Sensitivity and specificity of a visual acuity screening protocol performed with the LEA Symbols 15-line folding distance chart in preschool children. Acta Ophthalmol Scand. 2006 Dec;84(6):807-11. doi: 10.1111/j.1600-0420.2006.00668.x. PMID: 17083543.17083543
82 Chui L, Fraser T, Hoar K, . Negative predictive value of a vision screening program aimed at children aged 3 to 4 years old. J AAPOS. 2004 Dec;8(6):566-70. doi: 10.1016/j.jaapos.2004.08.011. PMID: 15616505.15616505
83 Cogen MS, Ottemiller DE. Photorefractor for detection of treatable eye disorders in preverbal children. Ala Med. 1992 Sep;62(3):16-20. PMID: 1442456.1442456
84 Dahlmann-Noor AH, Comyn O, Kostakis V, . Plusoptix Vision Screener: the accuracy and repeatability of refractive measurements using a new autorefractor. Br J Ophthalmol. 2009 Mar;93(3):346-9. doi: 10.1136/bjo.2008.138123. PMID: 19001013.19001013
85 Dahlmann-Noor AH, Vrotsou K, Kostakis V, . Vision screening in children by Plusoptix Vision Screener compared with gold-standard orthoptic assessment. Br J Ophthalmol. 2009 Mar;93(3):342-5. doi: 10.1136/bjo.2008.138115. PMID: 19019940.19019940
86 Harvey EM, Dobson V, Miller JM, . Accuracy of the Welch Allyn SureSight for measurement of magnitude of astigmatism in 3- to 7-year-old children. J AAPOS. 2009 Oct;13(5):466-71. doi: 10.1016/j.jaapos.2009.08.013. PMID: 19840726.19840726
87 Hope C, Maslin K. Random dot stereogram E in vision screening of children. Aust N Z J Ophthalmol. 1990 Aug;18(3):319-24. PMID: 2261180.2261180
88 Huang J, Maguire MG, Ciner E, . Intertester agreement in refractive error measurements. Optom Vis Sci. 2013 Oct;90(10):1128-37. doi: 10.1097/opx.0000000000000025. PMID: 23974664.23974664
89 Jost RM, Stager D, Jr., Dao L, . High specificity of the Pediatric Vision Scanner in a private pediatric primary care setting. J AAPOS. 2015 Dec;19(6):521-5. doi: 10.1016/j.jaapos.2015.09.004. PMID: 26691030.26691030
90 Kemper AR, Keating LM, Jackson JL, . Comparison of monocular autorefraction to comprehensive eye examinations in preschool-aged and younger children. Arch Pediatr Adolesc Med. 2005 May;159(5):435-9. doi: 10.1001/archpedi.159.5.435. PMID: 15867116.15867116
91 Kennedy RA, Sheps SB. A comparison of photoscreening techniques for amblyogenic factors in children. Can J Ophthalmol. 1989 Oct;24(6):259-64. PMID: 2692792.2692792
92 Kennedy R, Sheps SB, Bagaric D. Field trial of the Otago photoscreener. Can J Ophthalmol. 1995 Jun;30(4):193-7. PMID: 7585311.7585311
93 Kennedy RA, Thomas DE. Evaluation of the iScreen digital screening system for amblyogenic factors. Can J Ophthalmol. 2000 Aug;35(5):258-62. PMID: 10959465.10959465
94 Kulp MT, Ying GS, Huang J, . Accuracy of noncycloplegic retinoscopy, retinomax autorefractor, and SureSight vision screener for detecting significant refractive errors. Invest Ophthalmol Vis Sci. 2014 Mar;55(3):1378-85. doi: 10.1167/iovs.13-13433. PMID: 24481262.24481262
95 Leone JF, Gole GA, Mitchell P, . Visual acuity testability and comparability in Australian preschool children: the Sydney Paediatric Eye Disease Study. Eye (Lond). 2012 Jul;26(7):925-32. doi: 10.1038/eye.2012.60. PMID: 22498798.22498798
96 Matta NS, Singman EL, Silbert DI. Performance of the Plusoptix vision screener for the detection of amblyopia risk factors in children. J AAPOS. 2008 Oct;12(5):490-2. doi: 10.1016/j.jaapos.2008.04.004. PMID: 18534881.18534881
97 Miller JM, Harvey EM, Dobson V. Visual acuity screening versus noncycloplegic autorefraction screening for astigmatism in Native American preschool children. J AAPOS. 1999 Jun;3(3):160-5. PMID: 10428590.10428590
98 Miller JM, Dobson V, Harvey EM, . Comparison of preschool vision screening methods in a population with a high prevalence of astigmatism. Invest Ophthalmol Vis Sci. 2001 Apr;42(5):917-24. PMID: 11274067.11274067
99 Morgan KS, Johnson WD. Clinical evaluation of a commercial photorefractor. Arch Ophthalmol. 1987 Nov;105(11):1528-31. PMID: 3675285.3675285
100 Ottar WL, Scott WE, Holgado SI. Photoscreening for amblyogenic factors. J Pediatr Ophthalmol Strabismus. 1995 Sep-Oct;32(5):289-95. PMID: 8531032.8531032
101 Donahue SP, Johnson TM, Ottar W, . Sensitivity of photoscreening to detect high-magnitude amblyogenic factors. J AAPOS. 2002 Apr;6(2):86-91. PMID: 11997804.11997804
102 Rogers DL, Neely DE, Chapman JB, . Comparison of the MTI Photoscreener and the Welch-Allyn SureSight autorefractor in a tertiary care center. J AAPOS. 2008 Feb;12(1):77-82. doi: 10.1016/j.jaapos.2007.09.004. PMID: 18314072.18314072
103 Shallo-Hoffmann J, Coulter R, Oliver P, . A study of pre-school vision screening tests' testability, validity and duration: do group differences matter? Strabismus. 2004 Jun;12(2):65-73. PMID: 15672929.15672929
104 Freedman H. Vision screening. Ophthalmology. 2006 Jul;113(7):1248-9; discussion 9. doi: 10.1016/j.ophtha.2006.04.007. PMID: 16815414.16815414
105 Tong PY, Bassin RE, Enke-Miyazaki E, . Screening for amblyopia in preverbal children with photoscreening photographs: II. Sensitivity and specificity of the MTI photoscreener. Ophthalmology. 2000 Sep;107(9):1623-9. PMID: 10964818.10964818
106 Ciner E, Carter A, Ying GS, . Comparison of the Retinomax and Palm-AR Auto-Refractors: a pilot study. Optom Vis Sci. 2011 Jul;88(7):830-6. doi: 10.1097/OPX.0b013e3182192658. PMID: 21516050.21516050
107 Vision in Preschoolers (VIP) Study Group. Effect of age using LEA Symbols or HOTV for preschool vision screening. Optom Vis Sci. 2010 Feb;87(2):87-95. doi: 10.1097/OPX.0b013e3181c750b1. PMID: 19996814.19996814
108 Vision in Preschoolers Study Group. Preschool vision screening tests administered by nurse screeners compared with lay screeners in the Vision In Preschoolers Study. Invest Ophthalmol Vis Sci. 2005 Aug;46(8):2639-48. doi: 10.1167/iovs.05-0141. PMID: 16043831.16043831
109 Weinand F, Graf M, Demming K. Sensitivity of the MTI photoscreener for amblyogenic factors in infancy and early childhood. Graefes Arch Clin Exp Ophthalmol. 1998 Nov;236(11):801-5. PMID: 9825254.9825254
110 Williams C, Lumb R, Harvey I, . Screening for refractive errors with the Topcon PR2000 Pediatric Refractometer. Invest Ophthalmol Vis Sci. 2000 Apr;41(5):1031-7. PMID: 10752938.10752938
111 Ying GS, Maguire M, Quinn G, . ROC analysis of the accuracy of noncycloplegic retinoscopy, Retinomax Autorefractor, and SureSight Vision Screener for preschool vision screening. Invest Ophthalmol Vis Sci. 2011 Dec;52(13):9658-64. doi: 10.1167/iovs.11-8559. PMID: 22125281.22125281
112 Vision in Preschoolers Study Group. Preschool visual acuity screening with HOTV and Lea symbols: testability and between-test agreement. Optom Vis Sci. 2004 Sep;81(9):678-83.15365387
113 Schmidt P, Maguire M, Kulp M, . Random Dot E stereotest: testability and reliability in 3- to 5-year-old children. J AAPOS. 2006 Dec;10(6):507-14. doi: 10.1016/j.jaapos.2006.08.019.17189143
114 Williams C, Horwood J, Northstone K, . The timing of patching treatment and a child's wellbeing. Br J Ophthalmol. 2006 Jun;90(6):670-1. doi: 10.1136/bjo.2006.091082. PMID: 16714262.16714262
115 Clarke MP, Wright CM, Hrisos S, . Randomised controlled trial of treatment of unilateral visual impairment detected at preschool vision screening. BMJ (Clinical research ed.); 2003. p. 1251.
116 Wallace DK, Edwards AR, Cotter SA, . A randomized trial to evaluate 2 hours of daily patching for strabismic and anisometropic amblyopia in children. Ophthalmology; 2006. p. 904-12.16751033
117 Awan M, Proudlock FA, Gottlob I. A randomized controlled trial of unilateral strabismic and mixed amblyopia using occlusion dose monitors to record compliance. Invest Ophthalmol Vis Sci; 2005. p. 1435-9.15790912
118 Hrisos S, Clarke MP, Wright CM. The emotional impact of amblyopia treatment in preschool children: randomized controlled trial. Ophthalmology; 2004. p. 1550-6.15288987
119 Due P, Holstein BE, Lynch J, . Bullying and symptoms among school-aged children: international comparative cross sectional study in 28 countries. Eur J Public Health. 2005 Apr;15(2):128-32. doi: 10.1093/eurpub/cki105. PMID: 15755782.15755782
120 Wolke D, Woods S, Bloomfield L, . Bullying involvement in primary school and common health problems. Arch Dis Child. 2001 Sep;85(3):197-201. PMID: 11517098.11517098
121 Chou R, Dana T, Bougatsos C. Screening for visual impairment in children ages 1-5 years: update for the USPSTF. Pediatrics. 2011 Feb;127(2):e442-79. doi: 10.1542/peds.2010-0462. PMID: 21282269.21282269
122 Donahue SP. How often are spectacles prescribed to “normal” preschool children? J AAPOS. 2004 Jun;8(3):224-9. doi: 10.1016/S1091853104000965. PMID: 15226721.15226721
123 Donahue SP, Johnson TM, Leonard-Martin TC. Screening for amblyogenic factors using a volunteer lay network and the MTI photoscreener. Initial results from 15,000 preschool children in a statewide effort. Ophthalmology. 2000 Sep;107(9):1637-44; discussion 45-6. PMID: 10964820.10964820
124 Sunness JS, El Annan J. Improvement of visual acuity by refraction in a low-vision population. Ophthalmology. 2010 Jul;117(7):1442-6. doi: 10.1016/j.ophtha.2009.11.017. PMID: 20231036.20231036
125 Stewart CE, Moseley MJ, Fielder AR. Defining and measuring treatment outcome in unilateral amblyopia. Br J Ophthalmol. 2003 Oct;87(10):1229-31. PMID: 14507754.14507754
126 Holmes JM, Beck RW, Repka MX, . The amblyopia treatment study visual acuity testing protocol. Arch Ophthalmol. 2001 Sep;119(9):1345-53. PMID: 11545641.11545641
127 Rosser DA, Cousens SN, Murdoch IE, . How sensitive to clinical change are ETDRS logMAR visual acuity measurements? Invest Ophthalmol Vis Sci. 2003 Aug;44(8):3278-81. PMID: 12882770.12882770
128 Rosser DA, Murdoch IE, Fitzke FW, . Improving on ETDRS acuities: design and results for a computerised thresholding device. Eye (Lond). 2003 Aug;17(6):701-6. doi: 10.1038/sj.eye.6700496. PMID: 12928680.12928680
129 McGraw PV, Winn B, Gray LS, . Improving the reliability of visual acuity measures in young children. Ophthalmic Physiol Opt. 2000 May;20(3):173-84. PMID: 10897339.10897339
130 Manny RE, Hussein M, Gwiazda J, . Repeatability of ETDRS visual acuity in children. Invest Ophthalmol Vis Sci. 2003 Aug;44(8):3294-300. PMID: 12882773.12882773
131 Tommila V, Tarkkanen A. Incidence of loss of vision in the healthy eye in amblyopia. Br J Ophthalmol. 1981 Aug;65(8):575-7. PMID: 7295619.7295619
132 Birch EE, Strauber SF, Beck RW, . Comparison of the amblyopia treatment study HOTV and the electronic-early treatment of diabetic retinopathy study visual acuity protocols in amblyopic children aged 5 to 11 years. J AAPOS. 2009 Feb;13(1):75-8. doi: 10.1016/j.jaapos.2008.07.007. PMID: 18848480.18848480
133 Rice ML, Leske DA, Holmes JM. Comparison of the amblyopia treatment study HOTV and electronic-early treatment of diabetic retinopathy study visual acuity protocols in children aged 5 to 12 years. Am J Ophthalmol. 2004 Feb;137(2):278-82. doi: 10.1016/j.ajo.2003.08.016. PMID: 14962417.14962417
134 Kaiser PK. Prospective evaluation of visual acuity assessment: a comparison of snellen versus ETDRS charts in clinical practice (An AOS Thesis). Trans Am Ophthalmol Soc. 2009 Dec;107:311-24. PMID: 20126505.20126505
135 Kheterpal S, Jones HS, Auld R, . Reliability of visual acuity in children with reduced vision. Ophthalmic Physiol Opt. 1996 Sep;16(5):447-9. PMID: 8944189.8944189
136 Stewart CE. Comparison of Snellen and log-based acuity scores for school-aged children. Br Orthopt J. 2000;57:32-8.
137 Pediatric Eye Disease Investigator Group. A randomized trial of atropine vs. patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2002 Mar;120(3):268-78. PMID: 11879129.11879129
138 Wallace DK, Pediatric Eye Disease Investigator Group, Edwards AR, . A randomized trial to evaluate 2 hours of daily patching for strabismic and anisometropic amblyopia in children. Ophthalmology. 2006 Jun;113(6):904-12. doi: 10.1016/j.ophtha.2006.01.069. PMID: 16751033.16751033
139 Repka MX, Beck RW, Holmes JM, . A randomized trial of patching regimens for treatment of moderate amblyopia in children. Arch Ophthalmol. 2003;121(5):603-11. doi: 10.1001/archopht.121.5.603. PMID: CN-00437330.12742836
140 Repka MX, Cotter SA, Beck RW, . A randomized trial of atropine regimens for treatment of moderate amblyopia in children. Ophthalmology; 2004. p. 2076-85.15522375
141 Pediatric Eye Disease Investigator Group. Pharmacological plus optical penalization treatment for amblyopia: results of a randomized trial. Arch Ophthalmol. 2009 Jan;127(1):22-30. doi: 10.1001/archophthalmol.2008.520. PMID: 19139333.19139333
142 Repka MX, Wallace DK, Beck RW, . Two-year follow-up of a 6-month randomized trial of atropine vs patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2005;123(2):149-57. doi: 10.1001/archopht.123.2.149. PMID: CN-00504898.15710809
143 Stewart CE, Stephens DA, Fielder AR, . Objectively monitored patching regimens for treatment of amblyopia: randomised trial. BMJ (Clinical research ed.). 2007;335(7622):707. doi: 10.1136/bmj.39301.460150.55. PMID: CN-00612053.
144 Koklanis K, Abel LA, Aroni R. Psychosocial impact of amblyopia and its treatment: a multidisciplinary study. Clin Experiment Ophthalmol. 2006 Nov;34(8):743-50. doi: 10.1111/j.1442-9071.2006.01317.x. PMID: 17073896.17073896
145 Donahue SP, Arthur B, Neely DE, . Guidelines for automated preschool vision screening: a 10-year, evidence-based update. J AAPOS. 2013 Feb;17(1):4-8. doi: 10.1016/j.jaapos.2012.09.012. PMID: 23360915.23360915
146 Leat SJ, Pierre JS, Hassan-Abadi S, . The moving Dynamic Random Dot Stereosize test: development, age norms, and comparison with the Frisby, Randot, and Stereo Smile tests. J Pediatr Ophthalmol Strabismus. 2001 Sep-Oct;38(5):284-94. PMID: 11587177.11587177
147 American Academy of Family Physicians. Clinical preventive service recommendation: visual difficulties and impairment. http://www.aafp.org/patient-care/clinical-recommendations/all/visual.html. Accessed 27 May, 2015.
148 Donahue SP, Baker CN, Committee On P, . Procedures for the Evaluation of the Visual System by Pediatricians. Pediatrics. 2016 Jan;137(1):1-9. doi: 10.1542/peds.2015-3597. PMID: 26644488.26644488
149 American Optometric Association Consensus Panel on Pediatric Eye and Vision Examination. Optometric Clinical Practice Guidelines: Pediatric Eye and Vision Examination. St. Louis, MO: American Optometric Association; 2002. http://www.aoa.org/documents/optometrists/CPG-2.pdf. Accessed 12 May, 2016.
150 Periodic health examination, 1989 update: 3. Preschool examination for developmental, visual and hearing problems. Canadian Task Force on the Periodic Health Examination. CMAJ. 1989 Dec 1;141(11):1136-40. PMID: 2479458.2479458
151 Adler P, Scally AJ, Barrett BT. Test--retest variability of Randot stereoacuity measures gathered in an unselected sample of UK primary school children. Br J Ophthalmol. 2012 May;96(5):656-61. doi: 10.1136/bjophthalmol-2011-300729. PMID: 22317911.22317911
152 Cooper CD, Gole GA, Hall JE, . Evaluating photoscreeners II: MTI and fortune videorefractor. Aust N Z J Ophthalmol. 1999 Dec;27(6):387-98. PMID: 10641896.10641896
153 Ehrt O, Weber A, Boergen KP. Screening for refractive errors in preschool children with the vision screener. Strabismus. 2007 Jan-Mar;15(1):13-9. doi: 10.1080/09273970601174969. PMID: 17523041.17523041
154 Molteno AC, Hoare-Nairne J, Sanderson GF, . Reliability of the Otago photoscreener. A study of a thousand cases. Aust N Z J Ophthalmol. 1993 Nov;21(4):257-65. PMID: 8148143.8148143
155 Singman E, Matta N, Tian J, . A comparison of the PlusoptiX S04 and A09 photoscreeners. Strabismus. 2013 Jun;21(2):85-7. doi: 10.3109/09273972.2013.786735. PMID: 23713927.23713927