# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; peer reviewers Michael P. Clarke, MB, Sean P. Donahue, MD, PhD, and Steven Goldstein, MD; Evelyn Whitlock, MD, MPH, former Director of the Kaiser Permanente Research Affiliates EPC; and the following RTI International–University of North Carolina EPC staff: Meera Viswanathan, PhD, Director, Carol Woodell, BSPH, Project Manager, Christiane Voisin, MSLS, and Laurie T. Leadbetter, MSLS, research librarians, Sharon M. Barrell, MA, editor, and Loraine G. Monroe, publications specialist.