# Chapter 4 Discussion

## Summary of Evidence

Table 6 provides a summary of findings in this evidence review. This table is organized by KQ and provides a summary of outcomes along with a description of consistency, precision, quality, body of evidence limitations, strength of evidence grade, and applicability.

Table 6 Summary of Evidence for Vision Screening in Children

KQ | No. of Studies (k), No. of Participants or Observations (n) Study Designs | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Quality | Body of Evidence Limitations | Strength of Evidence | Applicability
1 | k=2, n=7,995 analyzed 1 RCT (1,914) 1 prospective cohort (6,081) | School performance, functioning, or quality of life: Neither study reported these outcomes Prevalence of amblyopia at age 7.5 years RCT: Approximately 1% lower for intensive screening (at ages 8, 12, 18, 25, 31, and 37 months) than for screening at age 37 months; difference was statistically significant for 1 of 2 definitions of amblyopia^a^ Cohort: No statistically significant difference between screened (at age 37 months) and nonscreened groups for any definition of amblyopia^b^ | Consistency unknown/imprecise | Not detected | 2 fair | Studies had high overall attrition (approximately 50%) and compared different screening strategies; RCT did not use a valid randomization method | Low | Healthy preschool-age children who received vision screening at ages 4 to 5 years by a school nurse as part of usual care. Trained orthoptists conducted screening exams in both studies.
2 | k=34, n=45,588 observations^c^ k=6 for VA tests k=4 for stereoacuity tests k=1 for cover-uncover test k=4 for a combination of clinical tests k=16 for autorefractors k=11 for photoscreeners k=1 for retinal birefringence scanning Studies of test accuracy | Estimates for all tests suggest utility for identification of children at higher risk for amblyopia risk factors or other visual conditions, with PLRs most commonly in the moderate range (5 to 10). Evidence suggests that combinations of clinical tests have higher PLRs (>10). The VIP study, the largest study to directly compare multiple tests, generally found similar likelihood ratios across tests. Accuracy did not clearly differ for children stratified according to age. | Mostly consistent/Imprecise | Not detected | 34 fair | Many studies recruited from specialty clinics or enrolled populations with high prevalence; heterogeneity of populations, settings, and target conditions evaluated; common shortcomings included high (or NR) rates of uninterpretable results or noncompliance with tests, not reporting whether uninterpretable results or noncompliance were included in analyses, lacking a representative spectrum, and lacking a random or consecutive sample | Low | Most studies of clinical tests didn't include children younger than age 3 years; however, most studies of photoscreeners and 5 of 16 studies of autorefractors included them. Applicable to a variety of settings and screening personnel, although only one study was conducted completely in a primary care setting and another was described as being conducted partly in primary care.
3 | k=17 n=14,196 1 prospective cohort (4,473) 16 observational studies of test accuracy (9,723) | Likelihood of being bullied: Lower for patched children offered screening at age 37 months than for those not screened (25.7% vs. 47.1%; p=0.033; adjusted OR, 0.39 [95% CI, 0.16 to 0.92])^d^ False-positive rates (1−PPV): Studies with a lower prevalence (<10%) of vision abnormalities had higher rates (usually >75%) than studies with higher prevalence (usually <35%) | Bullying: NA (consistency unknown) for single study/imprecise False-positive rates: Reasonably consistent (across studies of similar prevalence)/reasonably precise | Not detected | 17 fair | Risk of selection bias and confounding in the cohort study that reported bullying Did not assess psychological effects or other harms of false- positive results | Low for bullying Moderate for false- positive rates Insufficient for other harms | Children being screened for amblyopia or its risk factors
4a | k=2 n=240 RCTs | Patching vs. no patching: Visual acuity of amblyopic eye: On average, small (<1 line on Snellen chart) improvement after 5 to 12 weeks; more children experienced improvement of ≥2 lines (45% vs. 21%; p=0.003) in the one study reporting it | Consistent/precise | Not detected | 1 good 1 fair | Compliance with treatment was low in the fair-quality study; the fair-quality study focused on compliance and was underpowered to find a small difference between groups in visual acuity | Moderate for improved visual acuity | Children age 3 years or older with amblyopic risk factors pretreated with glasses
4a | k=1 n=177 RCT | Patching + glasses vs. glasses alone vs. no treatment: Visual acuity: On average, improvement of about 1 line on Snellen chart at end of trial (1 year) for patching + glasses vs. no treatment (0.11 logMAR [95% CI, 0.05 to 0.17]) and <1 line for glasses alone; magnitude of improvement was greater for children with worse baseline acuity | NA (single study)/precise | Not detected | Good | Children younger than age 3 years not eligible; mean age, 4 years (range, 3 to 5 years) | Moderate for improved visual acuity^e^ | Children age 3 years or older with amblyopic risk factors (unilateral vision impairment)
4a | k=0 | Atropine vs. control for any eligible outcome | NA | NA | NA | NA | Insufficient | NA
4b | k=0 | Long-term amblyopia and improved school performance, functioning, and/or quality of life | NA | NA | NA | NA | Insufficient | NA
5 | k=3 n=417 RCTs | Worsening visual acuity in the nonamblyopic eye: Risk not increased with patching vs. no patching at 5 weeks (2.4% vs. 6.8%; p=0.28) Loss of visual acuity in the amblyopic eye: No significant difference between patching + glasses, glasses alone, and no treatment at 1 year^f^ Child happiness or behavioral problems: No difference between patching + glasses, glasses alone, and no treatment Child/parental upset/worry about treatment: Greater with patching than with glasses alone | NA (single study reported each outcome)/imprecise | Not detected | 2 good 1 fair | Overall sparse evidence on harms of treatment; no included studies examined atropine; assessment did not compare glasses and patching with the no-treatment group for the psychological harms identified (child difficulty coping, upset, parental worry) | Low | Children receiving treatment for amblyopia or its risk factors with eyeglasses or patching

a Amblyopia A: 1.5% vs. 2.7% (RR, 0.55 [95% CI, 0.29 to 1.04]); amblyopia B: 0.6% vs. 1.8% (RR, 0.35 [95% CI, 0.15 to 0.86]).

b Amblyopia A: adjusted OR, 0.63 (95% CI, 0.32 to 1.23); amblyopia B: adjusted OR, 0.72 (95% CI, 0.32 to 1.60); amblyopia C: adjusted OR, 0.65 (95% CI, 0.38 to 1.10). All ORs adjusted for sex, highest level of maternal education, birth weight, family history of strabismus/amblyopia, and duration of breastfeeding.

c Some study participants contributed multiple observations (e.g., if they were evaluated with multiple tests).

d The effects were seen in children who were patched but not those prescribed only glasses.

e In our assessment of the strength of evidence, we considered that these findings are generally consistent with those from the patching vs. no-patching studies and that the magnitude of improvement was greater for children with worse baseline acuity.

f 9.7% vs. 6.5% vs. 13.3% (p=0.28) for children with mild baseline acuity loss; 15.0% vs. 11.1% vs. 23.8% (p=0.13) for children with moderate baseline acuity loss, respectively, for patching plus eyeglasses, eyeglasses alone, and no treatment.

Abbreviations: CI=confidence interval; k=number of studies; KQ=key question; logMAR=logarithm of the minimum angle of resolution; n=sample size; NA=not applicable; OR=odds ratio; PACT=prism and alternate cover test; PD=prism diopter; PLR=positive likelihood ratio; PPV=positive predictive value; RCT=randomized, controlled trial; RR=relative risk; VA=visual acuity; VIP=Vision in Preschoolers.

### Benefits and Harms of Screening

For our overarching question (KQ 1), we did not identify any eligible RCTs that directly compared screening with no screening. We graded the strength of evidence as low because of unknown consistency (with a single study making each comparison), imprecision, and quality. The two included studies, one prospective cohort and one RCT, evaluated different comparisons. Both focused on the outcome of amblyopia prevalence at age 7.5 years; neither reported school performance, functioning, or quality of life. The prospective cohort study compared screening (at age 37 months) with no screening and found no statistically significant difference between screened and nonscreened groups for any definition of amblyopia.^76^ The RCT compared more intensive screening (at ages 8, 12, 18, 25, 31, and 37 months) with screening at age 37 months and found an approximately 1 percent lower prevalence of amblyopia at age 7.5 years and large relative reductions (RR, 0.55 and 0.35) for intensive screening (at ages 8, 12, 18, 25, 31, and 37 months) than for screening at age 37 months, although the difference was only statistically significant for one of two definitions of amblyopia.^74, 75^ The main limitation of both studies was high overall attrition (approximately 50%). The findings are applicable to healthy preschool-age children who receive vision screening at ages 4 to 5 years as part of usual care. Trained orthoptists conducted screening examinations in both studies.

For harms of screening (KQ 3), we found limited evidence. Evidence included one prospective cohort study that showed a reduction in harm (i.e., less school-age bullying by age 8 years) among patched children screened in preschool compared with patched children not screened in preschool.^114^ We found no studies reporting other measures of psychosocial distress, labeling, or anxiety. We graded the strength of evidence as low for the bullying outcome (downgraded because of unknown consistency, imprecision, and quality). In theory, although both glasses and patching have been reported to increase the risk of being bullied,^38^ preschool screening may allow for treatment before school starts, thus avoiding potential bullying and psychosocial distress. Repeatedly being subjected to bullying is associated with physical and emotional problems and may lead to long-term adverse effects.^119, 120^

Harms of preschool vision screening might include unnecessary referrals due to false-positive results, overdiagnosis, or unnecessary treatment. We calculated false-positive rates using studies of test accuracy and found, similar to the previous review on this topic,^67, 121^ that screening tests are associated with high false-positive rates among populations with a low prevalence of vision abnormalities. We graded the strength of evidence for false-positive rates as moderate (downgraded because of fair, as opposed to good, quality of the individual studies and the related methodological limitations). Calculated rates were reasonably consistent across studies of similar prevalence and were reasonably precise. We found no eligible studies directly examining whether false-positive screening results lead to unnecessary treatments or subsequent long-term vision or functional impairments. A large (N=102,508) retrospective uncontrolled study from a statewide photoscreening program in Tennessee that did not meet eligibility criteria (because it lacked a control group) found that 19.5 percent (174/890) of children with false-positive screening results were prescribed glasses.^122^

### Accuracy and Reliability of Screening Tests

Estimates for all tests suggest utility for identifying children at higher risk for amblyopia risk factors or other visual conditions. PLRs were in the moderate range (5 to 10) for most studies, although some studies found lower or higher PLRs, and most studies that evaluated combinations of clinical tests found high (>10) PLRs. The VIP study, the largest study to directly compare multiple tests, generally found similar accuracy across tests. We graded the strength of evidence for studies of test accuracy as low, because of imprecision and considering our quality assessments of the individual studies. Common methodological limitations of studies included high (or not reported) rates of uninterpretable results or noncompliance with tests, not reporting whether uninterpretable results or noncompliance were included in analyses, lack of a representative spectrum, and lack of a random or consecutive sample.

Findings are applicable to a variety of settings and screening personnel. Studies were conducted in Head Start, school, community, primary care, and ophthalmology settings, although only two studies were conducted completely^89^ or partly^100^ in primary care settings.^100^ Screening was administered by an array of personnel across studies, including pediatricians, eye professionals, nurses, and trained laypersons, indicating that many types of personnel can conduct screening.

We found that accuracy did not clearly differ for preschool-age children in different age groups. However, unlike studies of photoscreeners, most studies of clinical test accuracy did not enroll children younger than age 3 years. Data were relatively limited and estimates were somewhat imprecise, but studies did not find any clear differences in accuracy of tests when results were stratified according to age.

Testability may limit the utility of some screening tests, especially clinical tests, in children younger than age 3 years. Although relatively few of the included studies assessed changes in testability by age, those that did generally found better testability in the older preschool age (3 years or older), and some reported very low testability rates with visual acuity and stereoacuity tests for those younger than age 3 years. In contrast, some data suggest that photoscreeners have high testability rates for children as young as age 1 year (e.g., a statewide photoscreening program administered by a volunteer lay network in Tennessee found that 1-year-olds had testability rates of 94%).^123^

### Benefits and Harms of Treatment of Amblyopia, Its Risk Factors, and Refractive Error

Our review found some evidence of moderate strength supporting the effectiveness of some treatments for improving visual acuity outcomes, although improvements were small, on average. We found no studies that evaluated potential effectiveness of treatments for reducing long-term amblyopia or for improving school performance, functioning, or quality of life, and no eligible studies that evaluated atropine or vision therapy. The three included trials all enrolled children age 3 years or older, and applicability to those younger than age 3 years is unclear. The trials varied somewhat in the populations (children with amblyopic risk factors pretreated with glasses or not pretreated with glasses) and interventions/comparisons (two evaluated patching vs. no patching; one compared patching plus glasses vs. glasses alone vs. no treatment). The trial that compared patching plus eyeglasses, eyeglasses alone, and no treatment enrolled screen-detected children, demonstrating the applicability of findings to the main population of interest for this review.^115^

Taken together, the trials provide evidence of moderate strength that: 1) patching improves visual acuity of the amblyopic eye by an average of less than 1 line on the Snellen chart after 5 to 12 weeks compared with no patching among children with amblyopic risk factors pretreated with glasses, 2) patching plus glasses improves visual acuity by about 1 line after 1 year compared with no treatment among children with amblyopic risk factors not pretreated with glasses, and 3) glasses alone improve visual acuity by less than 1 line after 1 year compared with no treatment among children with amblyopic risk factors. Of note, the magnitude of improvement for patching plus glasses or glasses alone was greater among children with worse baseline visual acuity. Few trials reported binary outcomes that may facilitate determination of how many participants achieved a clinically meaningful change, although one trial reported that more children treated with patching than with no patching experienced improvement of at least 2 lines (45% vs. 21%; p=0.003).^116^

For adverse effects of treatment, we found limited evidence, with a single trial reporting each outcome for which we found data. We graded the strength of evidence as low, downgrading because of unknown consistency (with a single study for each outcome) and imprecision. The trials suggest that patching does not worsen visual acuity in the nonamblyopic eye but that it may be associated with some psychological harms, because child or parental upset/worry about treatment was greater with patching than with glasses alone. However, the study reporting the association did not compare this outcome with an untreated group, and it is uncertain whether upset/worry from treatment is greater than what might result from an untreated vision problem.

### Minimal Clinically Meaningful Changes in Visual Acuity

Definitions for a clinically important change in visual acuity in young children vary across studies. Recent studies consider a change of 0.2 logMAR (about 2 lines on the Snellen chart) as the minimal clinically important change.^124-128^ Others consider smaller changes clinically meaningful, generally between 0.10 logMAR (about 1 line on the Snellen chart) and 0.15 logMAR (between 1 and 2 lines).^115, 129, 130^ When assessing whether improvement in visual acuity represents a clinically meaningful change, practitioners may also consider that visual impairment associated with amblyopia can become permanent and may limit functioning for the lifetime of a child.^23, 131^

Some of the variation in defining a clinically important change is likely associated with the lack of consensus about the minimum perceptible change in acuity. That, largely, is due to varying ranges of test-retest reliability, both within and between the available screening tests.^132, 133^ Visual acuity test results may be influenced by factors^134^ such as ambient lighting in the testing room, lighting of the test target, design of the test chart, the child's pupil size, and the person administering the test. Test-retest reliability for the most common vision screening tests shows that visual acuity can vary by roughly 0.10 logMAR (1 line) between administrations, independent of any real change in acuity.^127, 129, 130, 135, 136^ As a result, large treatment studies have calculated sample size requirements based on the ability to detect a change of at least 0.1 logMAR between treatment groups.^137-140^

## Limitations

Our review has some limitations. For studies of test accuracy conducted in ophthalmology settings, details about the study participants were sometimes limited, making it difficult to determine whether participants had known impaired visual acuity or obvious symptoms of impaired visual acuity. Thus, we may have included some studies that would not meet eligibility criteria if additional description of the study populations was available. Next, studies of test accuracy were most commonly conducted in Head Start programs, schools, the community, or ophthalmology clinics; primary care clinics were rarely involved, and applicability of findings to primary care settings is therefore less certain.

We did not include comparative effectiveness (i.e., head-to-head) studies, such as those comparing atropine with patching. The previous review for the USPSTF identified head-to-head trials that compared different patching regimens (e.g., 2- vs. 6-hour per day patching), different atropine regimens (daily vs. weekend atropine), and patching versus atropine.^137, 139-143^ The review concluded that the trials found no differences in visual acuity improvement in the amblyopic eye between the treatments.

For studies evaluating adverse effects of treatment, eligible studies were required to have a concurrent control group, and we did not include head-to-head comparative effectiveness studies (e.g., comparing patching with atropine). Because they lack an inactive treatment control group, head-to-head studies do not provide evidence on whether treatment increases the risk of adverse effects compared with no treatment. A previous systematic review for the USPSTF summarized adverse effects from head-to-head trials and found that patching (vs. atropine) and atropine plus a plano lens (vs. atropine alone) were associated with an increased risk of temporary worsening of visual acuity (≥2 lines or ≥1 line) in the nonamblyogenic eye in two trials, but visual acuity subsequently returned to baseline in nearly all children.^67^ The review noted that two other trials found no difference in risk for visual acuity loss in the nonamblyopic eye when comparing different patching or atropine regimens.^67^ Previous head-to-head studies examining atropine have noted that commonly reported adverse effects include light sensitivity, lid/conjunctival irritation, eye pain/headache, and facial flushing.^137, 141^ Skin irritation was also reported as an adverse effect of patching in one study.^137^ One head-to-head study of patching and atropine found that both treatments were well tolerated but that patching had worse subscale scores for adverse effects, difficulty with compliance, and social stigma.^137^ Another qualitative study of children with amblyopia found that children undergoing treatment often felt self-conscious, embarrassed, and ashamed, and these concerns were predominantly related to glasses or patching.^144^ Overall, most of the adverse effects identified in various head-to-head studies were mild and resolved after treatment completion.

Finally, we excluded studies published in languages other than English and those conducted in countries not categorized as “very high” on the Human Development Index, as defined by the United Nations Development Programme.

## Future Research Needs

We identified multiple evidence gaps that could be addressed with future research. We found no RCTs evaluating the effectiveness of screening (compared with no screening) and no good-quality RCTs evaluating when to begin screening (e.g., comparing initiation prior to age 3 years with initiation after age 3 years) or assessing various screening intervals. In addition, none of the included trials of screening or treatment assessed effectiveness for improving important health outcomes such as school performance, functioning, or quality of life; all trials focused on visual acuity outcomes. Next, although evidence generally supports the accuracy of screening tests, it does not establish which approach to screening or which combination of screening tests is the best. Finally, we found very little evidence from primary care settings on the accuracy of screening tests.^100^

## Conclusion

Studies that directly evaluated the effectiveness of screening were limited (because of study designs, attrition, imprecision, and quality) and do not establish whether vision screening in preschool-age children is better than no screening. All included studies that evaluated the effectiveness of screening or treatment reported visual acuity outcomes; none evaluated school performance, functioning, or quality of life. Indirect evidence supports 1) the accuracy of multiple screening tests for identifying preschool-age children at higher risk for amblyopia risk factors or other visual conditions (most studies found that abnormal results moderately increased the likelihood of target conditions), and 2) the effectiveness of some treatments for improving visual acuity outcomes, although improvements were small, on average. Evidence on potential adverse effects of screening was limited but indicated a reduction in bullying and high false-positive rates in low-prevalence populations.