# Chapter 3 Results

## Literature Search

We identified 2,182 unique records and further assessed 366 full-text articles for eligibility (Figure 2). We excluded 320 articles for various reasons detailed in Appendix C and included 40 published studies (described in 46 articles) of good or fair quality. Of all the included studies, two addressed the effectiveness of screening (KQ 1), 34 evaluated diagnostic test accuracy (KQ 2), 17 provided information on the harms of screening (KQ 3), three reported benefits of treatment (KQ 4), and three reported harms of treatment (KQ 5). The sum of studies (when adding the numbers included for each KQ) exceeds 40 because some studies were included for more than one KQ. Details of quality assessments of included studies and studies excluded because of poor quality are provided in Appendix D.

Figure 2 Summary of Evidence Search and Selection Diagram

Note: The sum of the numbers of studies/articles per KQ exceeds the total number of studies/articles because some studies/articles were included in multiple KQs.

This figure is a flow chart that summarizes the search and selection of articles. There were 2,069 references identified by searching PubMed (N=1,851), CINAHL (N=2), the Cochrane Library (N=41), and the ClinicalTrials.gov and WHO ICTRP databases (N=175). In addition, there were 113 references identified from hand searching and reference list review (N=33), from peer reviewer suggestions (N=20), and from the 2011 USPSTF review of this literature (N=60). The titles and abstracts of 2,182 references were screened for potential inclusion. Of these, 366 were deemed appropriate for full-text review to determine eligibility. After full-text review, 320 were excluded: 29 for ineligible language/non-English; 20 for ineligible publication type/not original research; 106 for ineligible population; 14 for ineligible screening or intervention; 70 for ineligible comparator; 37 for ineligible outcome; 29 for ineligible study design; 9 for ineligible country; and 6 for poor quality. Forty-six articles representing 40 studies were included in this report's qualitative synthesis. Two studies were included for key question 1; 34 studies were included for key question 2; 17 studies were included for key question 3; 3 studies were included for key question 4; and 3 studies were included for key question 5.

## Results by KQ

### KQ 1 Direct Evidence That Screening Improves Health Outcomes

We identified no eligible RCTs comparing vision screening with no screening. We included two fair-quality studies, one RCT^74, 75^ and one prospective cohort study,^76^ enrolling children from the population-based Avon Longitudinal Study of Parents and Children (ALSPAC) project. ALSPAC is a geographically defined birth cohort study enrolling 14,000 children (85% of those eligible) born in Southwest England between April 1991 and December 1992.^74^ The RCT compared earlier, intensive screening (before age 3 years) with later, one-time screening. The cohort study compared screening at age 3 years (specifically, at age 37 months) with no preschool screening. The included studies reported prevalence of amblyopia at age 7.5 years. Neither study evaluated school performance, functioning, or quality of life outcomes. The major methodological shortcoming in both studies was high attrition; in the RCT, 55 percent of children randomized did not attend the final examination at age 7.5 years and were excluded from analyses.^76^ Similarly, about half of children in the cohort did not have examination results available at age 7.5 years and were excluded from analyses.^76^ In addition, the method of randomization in the RCT was not adequate; children were randomized to the intervention or control group according to the last digit of the mother's day of birth.^74, 75^

The RCT (N=3,490) was nested within the ALSPAC cohort and compared intensive orthoptist visual screening before age 3 years (at 8, 12, 18, 25, 31, and 37 months) with one-time orthoptist screening at age 37 months (Table 3).^74, 75^ Eligible participants were those born in the last 6 months of the ALSPAC cohort whose parents agreed to attend regular clinic examinations; about half were female and 5 percent were nonwhite.^74^ Baseline data for amblyopia or amblyopia risk factors were not reported. The intervention screening examination by the orthoptist consisted of a clinical examination, age-specific visual acuity testing, and the cover-uncover test. Children with positive results on the visual acuity or cover-uncover test in either group were referred to the hospital eye service for further evaluation and treatment. In addition, children in both groups were offered what was considered usual care in terms of surveillance for visual problems: 1) examination at age 8 months and 18 months by a health visitor (taking history, observing visual behavior, and using a cover-uncover test), with referrals if a problem was suspected,^74^ and 2) visual screening at school entry (ages 4 to 5 years) by a school nurse.^75^

Table 3 Characteristics and Results of Studies Included for KQ 1

Author, Year Study | Overall N and N Participants in Each Group | Subject Age, Sex | Country and Setting | Screening Intervention vs. Control | Main Results
Williams et al, 2001^74^ and 2002^75^ RCT | N randomized: 3,490 (2,029 intensive screening,1,490 one-time screening) N analyzed at age 7.5 years: 1,914 | Age: Initially tested at age 8–37 months and followed to age 7.5 years Sex: 48% female (of those analyzed) | United Kingdom Orthoptic clinic in community | Screening at ages 8, 12, 18, 25, 31, and 37 months^a^ vs. screening at age 37 months^b^ | Amblyopia A^c^ at age 7.5 years: 1.5% (16/1,088) vs. 2.7% (22/826); RR, 0.55 (95% CI, 0.29 to 1.04) Amblyopia B^d^ at age 7.5 years: 0.6% (69/1,088) vs. 1.8% (15/876); RR, 0.35 (95% CI, 0.15 to 0.86) Residual amblyopia A in children treated with occlusion: 25% (10/40) vs. 8% (3/40); OR, 1.56 (95% CI, 0.62 to 3.92) Residual amblyopia B in children treated with occlusion: OR, 4.11 (95% CI, 1.04 to 16.29) Mean visual acuity in worse eye after patching treatment (adjusted for confounding variables): 0.15 (95% CI, 0.083 to 0.22) vs. 0.26 (95% CI, 0.17 to 0.35); p<0.001
Williams et al, 2003^76^ Prospective cohort | N eligible: NR N analyzed at age 7.5 years: 6,081 (1,516 were screened at age 37 months, 4,565 were not) | Age: Cohort tested at age 7.5 years; screening offered at age 37 months Sex: 47% female (of those analyzed) | United Kingdom Orthoptic clinic in community | Screening^e^ at age 37 months vs. no screening | Amblyopia A^c^ at age 7.5 years: 1.1% (11/1,019) vs. 2.0% (100/5,062); adjusted OR^f^, 0.63 (95% CI, 0.32 to 1.23) Amblyopia B^d^ at age 7.5 years: 0.7% (7/1,019) vs. 1.3% (65/5,062); adjusted OR^f^, 0.72 (95% CI, 0.32 to 1.60) Amblyopia C^g^ at age 7.5 years: 1.9% (19/1,019) vs. 3.4% (171/5,062); adjusted OR^f^, 0.65 (95% CI, 0.38 to 1.10) Mean visual acuity in worse eye after patching treatment (adjusted for confounding variables): 0.14 (95% CI, 0.11 to 0.18) (n=25) vs. 0.22 (95% CI, 0.20 to 0.23) (n=166); p<0.0001

a Cover-uncover test; Cardiff cards at ages 8 and 12 months; Cardiff and Kays pictures test at ages 18, 25, and 31 months; Kays picture test and HOTV Crowded Symbols Distance Visual Acuity Test at age 37 months; noncycloplegic autorefraction (performed at all visits but only used for referral at age 37 months).

b Cover-uncover test; Kays picture test and HOTV test; noncycloplegic autorefraction.

c Amblyopia A=interocular difference in acuity ≥0.2 logMAR (2 lines on chart).

d Amblyopia B=interocular difference in acuity ≥0.3 logMAR.

e Kays pictures or Sheridan Gardiner singles visual acuity test, cover-uncover test, and 20 diopter prism or stereopsis test (or both).

f Adjusted for sex, highest level of maternal education, birth weight, family history of strabismus/amblyopia, and duration of breastfeeding.

g Amblyopia C=visual acuity in amblyopic eye 0.18 logMAR or worse (6/9 or worse).

Abbreviations: CI=confidence interval; KQ=key question; logMAR=logarithm of the minimum angle of resolution; N=number; NR=not reported; OR=odds ratio; RCT=randomized, controlled trial; RR=relative risk.

The trial reported that the prevalence of amblyopia at 7.5 years was approximately 1 percent lower in the intensive screening group than in the control group, but the difference was only statistically significant for one of their two definitions of amblyopia (Table 3) (amblyopia A: 1.5% vs. 2.7%; relative risk [RR], 0.55 [95% confidence interval (CI), 0.29 to 1.04]; amblyopia B: 0.6% vs. 1.8%; RR, 0.35 [95% CI, 0.15 to 0.86]).^75^ Among children who received patching treatment (n=40 in each group), presence of residual amblyopia at age 7.5 years was more likely in the one-time screening group than in the intensive-screening group, but the difference was only statistically significant for one of the two definitions of amblyopia, and estimates were imprecise (amblyopia A: OR, 1.56 [95% CI, 0.62 to 3.92]; amblyopia B: OR, 4.11 [95% CI, 1.04 to 16.29]).^75^ Also, among children who received patching treatment, visual acuity at age 7.5 years in the worse eye was better in the intensive-screening group than in the one-time screening group (0.15 logMAR [95% CI, 0.08 to 0.22] vs. 0.26 logMAR [95% CI, 0.17 to 0.35]; p<0.001).^75^

The prospective cohort study (N=6,081 completers) compared orthoptist screening at age 3 years in one health district with no preschool screening in two other health districts (Table 3).^76^ Eligible participants were those who attended the examination at age 7.5 years and were not enrolled in the ALSPAC RCT; about half were female, and race/ethnicity was not described.^76^ One of the three health districts in the ALSPAC study area offered preschool orthoptic vision screening and the other two did not. Screening examination by the orthoptist consisted of a monocular vision test, a cover-uncover test, and an assessment of binocularity; positive findings on any part of the examination resulted in referral to the hospital eye service for further evaluation. All children in the study area were offered vision screening at school entry (ages 4 to 5 years).^76^

Among participants who attended the examination at age 7.5 years and were not part of the ALSPAC RCT, there were no statistically significant differences between groups (those who did vs. did not receive preschool vision screening) in amblyopia at age 7.5 years, based on any of the studies' three definitions of amblyopia (Table 3) (amblyopia A: adjusted OR, 0.63 [95% CI, 0.32 to 1.23]; amblyopia B: adjusted OR, 0.72 [95% CI, 0.32 to 1.60]; amblyopia C: adjusted OR, 0.65 [95% CI, 0.38 to 1.10]).^76^ Trends toward better amblyopia outcomes in the screened group were more attenuated when the analysis was based on a comparison of whether children were offered screening rather than whether they received screening (about two-thirds of the children invited to screening participated).^76^

### KQ 2 Accuracy and Reliability of Screening Tests

We included 34 fair-quality studies (described in 38 articles) that evaluated the accuracy of one or more vision screening tests (Appendix Tables E1–11).^65, 77-113^ The studies evaluated a variety of test types, including visual acuity tests (LEA Symbols or HOTV, 6 studies), stereoacuity tests (Stereo Smile II or Random Dot E, 4 studies), ocular alignment tests (cover-uncover test, 1 study), a combination of clinical tests (4 studies), autorefractors (16 studies), photoscreeners (11 studies), and retinal birefringence scanning (1 study) (Table 4). Screening was administered by a variety of personnel across studies, including orthoptists, orthoptists and pediatricians, orthoptists and ophthalmologists, licensed eye professionals, nurses, trained laypersons, Head Start staff, research staff, and technicians, and was sometimes not reported. Sample sizes ranged from 63^99^ to 4,040.^94, 111^ Nineteen studies were conducted in the United States, five in Canada, seven in Europe, and three in either Australia or New Zealand (Appendix Table E2).

Table 4 Summary of Main Results From Studies of Diagnostic Accuracy of Preschool Vision Screening Tests (KQ 2)

Author, Year | Target Condition | Sensitivity (95% CI) | Specificity (95% CI) | Positive Likelihood Ratio (95% CI) | Negative Likelihood Ratio (95% CI)
Visual Acuity Tests
Crowded LEA Symbols Visual Acuity Test (6 studies)
Bertuzzi et al, 2006^81^ | Amblyopia risk factors | 0.96 (0.78 to 1.0) | 0.83 (0.75 to 0.90) | 5.7 (3.8 to 8.6) | 0.05 (0.01 to 0.36)
Miller et al, 1999^97^ | Significant refractive error | 0.91 (0.82 to 0.96) | 0.44 (0.37 to 0.52) | 1.6 (1.4 to 1.9) | 0.21 (0.10 to 0.43)
Miller et al, 2001^98^ | Astigmatism | 0.93 (0.87 to 0.97) | 0.51 (0.44 to 0.57) | 1.9 (1.6 to 2.2) | 0.14 (0.08 to 0.27)
Schmidt (VIP) et al, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.61 (0.56 to 0.66)^a^ | 0.90 (0.88 to 0.92)^a^ | 6.1 (4.8 to 7.6)^a^ | 0.43 (0.38 to 0.50)^a^
VIP Study Group, 2005^108^ Phase II; nurse screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.49 (0.44 to 0.54) | 0.90 (0.88 to 0.92) | 4.9 (4.0 to 6.0) | 0.57 (0.52 to 0.62)
VIP Study Group, 2005^108^ Phase II; lay screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.37 (0.32 to 0.42) | 0.90 (0.88 to 0.92) | 3.7 (3.0 to 4.7) | 0.70 (0.65 to 0.76)
VIP Study Group, 2010^107^ Phase I, year 1 | Amblyopia risk factors or significant nonamblyogenic refractive error | Ranged from 0.57 (0.46 to 0.67) to 0.65 (0.54 to 0.75)^c^ | Ranged from 0.90 (0.84 to 0.94) to 0.92 (0.87 to 0.95)^c^ | Ranged from 5.95 (3.58 to 9.88) to 7.39 (4.57 to 11.93)^c^ | Ranged from 0.39 (0.29 to 0.52) to 0.47 (0.37 to 0.60)^c^
Crowded HOTV Visual Acuity Test (2 studies)
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.54 (0.49 to 0.59)^a^ | 0.89 (0.87 to 0.91)^a^ | 4.9 (3.9 to 6.1)^a^ | 0.52 (0.46 to 0.58)^a^
VIP Study Group, 2010^107^ | Amblyopia risk factors or significant nonamblyogenic refractive error | Ranged from 0.46 (0.33 to 0.59) to 0.57 (0.46 to 0.67)^c^ | Ranged from 0.87 (0.82 to 0.91) to 0.92 (0.87 to 0.95)^c^ | Ranged from 3.76 (2.27 to 6.22) to 6.83 (4.21 to 11.10)^c^ | Ranged from 0.47 (0.37 to 0.60) to 0.62 (0.49 to 0.79)^c^
Stereoacuity Tests
Random Dot E Stereogram (2 studies)
Hope et al, 1990^87^ | Refractive error or strabismus | 0.89 (0.52 to 1.0) | 0.76 (0.68 to 0.82) | 3.6 (2.5 to 5.2) | 0.15 (0.02 to 0.94)
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.42 (0.37 to 0.47)^a^ | 0.90 (0.88 to 0.92)^a^ | 4.2 (3.3 to 5.3)^a^ | 0.65 (0.59 to 0.71)^a^
Randot Preschool Stereoacuity Test (1 study)
Afsari et al, 2013^77^ | Amblyopia | Ranged from 0.24 (0.03 to 0.44) to 0.53 (0.25 to 0.77)^d^ | Ranged from 0.93 (0.91 to 0.94) to 0.98 (0.97 to 0.99)^d^ | Ranged from 7.57 to 12.00^d^ | Ranged from 0.51 to 0.78)^d^
Afsari et al, 2013^77^ | Anisometropia | Ranged from 0.09 (-0.03 to 0.20) to 0.35 (0.15 to 0.54)^d^ | Ranged from 0.93 (0.91 to 0.94) to 0.98 (0.97 to 0.99)^d^ | Ranged from 5.0 to 7.5^d^ | Ranged from 0.70 to 0.93^d^
Afsari et al, 2013^77^ | Strabismus | Ranged from 0.27 (0.12 to 0.42) to 0.48 (0.31 to 0.66)^d^ | Ranged from 0.93 (0.92 to 0.95) to 0.99 (0.98 to 0.99)^d^ | Ranged from 6.86 to 27.0^d^ | Ranged from 0.56 to 0.74^d^
Stereo Smile II Test (3 studies)
Afsari et al, 2013^77^ | Amblyopia | 0.50 (0.01 to 0.99) | Ranged from 0.59 (0.55 to 0.64) to 0.95 (0.93 to 0.97)^e^ | Ranged from 1.22 to 10^e^ | Ranged from 0.84 to 0.58^e^
Afsari et al, 2013^77^ | Anisometropia | Ranged from 0.17 (-4 to 38) to 0.33 (0.07 to 0.60)^e^ | Ranged from 0.59 (0.54 to 0.64) to 0.95 (0.93 to 0.97)^e^ | Ranged from 0.81 to 3.4^e^ | Ranged from 0.87 to 1.14^e^
Afsari et al, 2013^77^ | Strabismus | Ranged from 0.50 (0.22 to 0.78) to 0.83 (0.62 to 1.04)^e^ | Ranged from 0.60 (0.56 to 0.65) to 0.96 (0.94 to 0.98)^e^ | Ranged from 2.08 to 12.5^e^ | Ranged from 0.28 to 0.57^e^
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.44 (0.39 to 0.49)^a^ | 0.91 (0.89 to 0.93)^a^ | 4.9 (3.9 to 6.1)^a^ | 0.62 (0.56 to 0.67)^a^
VIP Study Group, 2005^108^ Phase II; nurse screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.45 (0.40 to 0.50) | 0.90 (0.88 to 0.92) | 4.5 (3.6 to 5.6) | 0.61 (0.56 to 0.67)
VIP Study Group, 2005^108^ Phase II; lay screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.40 (0.36 to 0.45) | 0.90 (0.88 to 0.92) | 4.0 (3.2 to 5.0) | 0.67 (0.62 to 0.72)
Ocular Alignment Tests
Cover-Uncover Test (1 study)
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.16 (0.12 to 0.29) | 0.98 (0.97 to 0.99) | 7.9 (4.6 to 14.0) | 0.73 (0.15 to 0.85)
Combined Clinical Tests (4 Studies)
Barry et al, 2003^80^ | Amblyopia or amblyopia risk factors | 0.91 (0.71 to 0.99) | 0.94 (0.92 to 0.95) | 15 (11 to 19) | 0.10 (0.03 to 0.36)
Chui et al, 2004^82^ | Amblyopia risk factors | 0.67 (0.41 to 0.87) | 0.86 (0.79 to 0.92) | 4.8 (2.8 to 8.4) | 0.39 (0.20 to 0.75)
Kennedy et al, 1995^92^ | Amblyopia risk factors | 0.09 (0.04 to 0.20) | 1.0 (0.99 to 1.0) | 17 (5.5 to 54) | 0.91 (0.84 to 0.99)
Shallo-Hoffman et al, 2004^103^ | Amblyopia risk factors | 0.73 (0.13 to 0.98) | 0.94 (0.90 to 0.96) | 12 (4.7 to 28) | 0.28 (0.03 to 2.4)
Autorefractors
Retinomax (8 studies)
Barry et al, 2001^79^ | Amblyopia | | | 1.9 (1.4 to 2.6) | 0.35 (0.10 to 1.2)
Kulp, 2014^94^ VIP (Phases 1 and 2) | Any significant refractive error: hyperopia >+3.25 D, myopia >2.00 D, astigmatism >1.50 D, and anisometropia >1.00 D IOD in hyperopia, >3.00 D IOD in myopia, or >1.50 D IOD in astigmatism | 0.73 (NR)^f^ | 0.90 (NR) | NR | NR
Miller et al, 1999^97^ | Significant refractive error | 0.91 (0.82 to 0.96) | 0.86 (0.80 to 0.91) | 6.7 (4.5 to 9.8) | 0.11 (0.05 to 0.22)
Miller et al, 2001^98^ | Astigmatism | 0.93 (0.88 to 0.96) | 0.95 (0.91 to 0.98) | 18 (10 to 34) | 0.08 (0.04 to 0.13)
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.64 (0.60 to 0.67)^a^ | 0.90 (0.88 to 0.91)^a^ | 6.1 (5.2 to 7.0)^a^ | 0.41 (0.37 to 0.45)^a^
VIP Study Group, 2011^106^ | Overall | 0.78 (0.67 to 0.88)^g^ | 0.90 (0.83 to 0.95) | 7.58 (4.37 to 13.15) | 0.24 (0.15 to 0.38)
VIP Study Group, 2011^106^ | Amblyopia | 0.88 (0.68 to 0.97) | 0.90 (0.83 to 0.95) | 8.59 (5.27 to 13.99) | 0.14 (0.05 to 0.40)
VIP Study Group, 2011^106^ | Strabismus | 0.70 (0.35 to 0.93) | 0.90 (0.83 to 0.95) | 7.04 (3.84 to 12.92) | 0.33 (0.13 to 0.86)
VIP Study Group, 2011^106^ | Refractive error | 0.84 (0.71 to 0.92) | 0.90 (0.83 to 0.95) | 8.11 (4.78 to 13.74) | 0.18 (0.10 to 0.33)
VIP Study Group, 2011^106^ | Reduced visual acuity | 0.70 (0.35 to 0.93) | 0.90 (0.83 to 0.95) | 7.04 (3.84 to 12.92) | 0.33 (0.13 to 0.86)
VIP Study Group, 2005^108^ Phase II; nurse screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.68 (0.64 to 0.72) | 0.90 (0.88 to 0.92) | 6.8 (5.6 to 8.3) | 0.36 (0.31 to 0.41)
VIP Study Group, 2005^108^ Phase II; lay screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.62 (0.57 to 0.66) | 0.90 (0.88 to 0.92) | 6.2 (5.1 to 7.6) | 0.42 (0.38 to 0.48)
Ying, 2011^111^ VIP (Phases 1 and 2) | Group 1 conditions: presumed unilateral amblyopia, suspected bilateral amblyopia, strabismus, severe anisometropia, hyperopia ≥5.0 D, astigmatism ≥2.5 D, or myopia ≥6.0 D | 0.87 (NR)^h^ | 0.90 (NR) | NR | NR
Suresight (7 studies)
Jost et al, 2015^89^ | Amblyopia or strabismus | 1.00 (0.02 to 1.0) | 0.87 (0.79 to 0.93) | 7.9 (4.7 to 13.4) | 0.0
Kemper et al, 2005^90^ | Amblyopia risk factors | 0.85 (0.69 to 0.95) | 0.52 (0.40 to 0.63) | 1.8^j^ | 0.29^j^
Kulp, 2014^94^ | Any significant refractive error: hyperopia >+3.25 D, myopia >2.00 D, astigmatism >1.50 D, and anisometropia >1.00 D IOD in hyperopia, >3.00 D IOD in myopia, or >1.50 D IOD in astigmatism. | 0.68 (NR)^f^ | 0.90 (NR) | NR | NR
Rogers et al, 2008^102^ | Amblyopia risk factors | 0.97 (0.88 to 1.0)^i^ 0.79 (0.67 to 0.89)^k^ | 0.38 (0.24 to 0.54)^i^ 0.64 (0.48 to 0.78)^k^ | 1.6 (1.2 to 2.0)^i^ 2.2 (1.4 to 3.4)^k^ | 0.09 (0.02 to 0.37)^i^ 0.32 (0.18 to 0.52)^k^
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.85 (0.81 to 0.88)^i^ 0.63 (0.59 to 0.65)^a^ | 0.62 (0.59 to 0.65)^i^ 0.90 (0.88 to 0.92)^a^ | 2.2 (2.0 to 2.4)^i^ 6.3 (5.2 to 7.4)^a^ | 0.24 (0.19 to 0.30)^i^ 0.41 (0.36 to 0.47)^a^
VIP Study Group, 2005^108^ Phase II; nurse screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.64 (0.60 to 0.68) | 0.90 (0.88 to 0.92) | 6.4 (5.3 to 7.8) | 0.40 (0.35 to 0.45)
VIP Study Group, 2005^108^ Phase II; lay screener | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.61 (0.56 to 0.66) | 0.90 (0.88 to 0.92) | 6.1 (5.0 to 7.5) | 0.43 (0.39 to 0.49)
Ying, 2011^111^ VIP (Phases 1 and 2) | Group 1 conditions: presumed unilateral amblyopia, suspected bilateral amblyopia, strabismus, severe anisometropia, hyperopia ≥5.0 D, astigmatism ≥2.5 D, or myopia ≥6.0 D | 0.82 (NR)^h^ | 0.90 (NR) | NR | NR
Topcon PR 2000 (1 study)
Williams et al, 2000^110^ | Spherical error >3.75 D Anisometropia Astigmatism | 0.50 (0.33 to 0.67) 0.74 (0.52 to 0.90) 0.47 (0.28 to 0.66) | 0.95 (0.90 to 0.98) 0.95 (0.91 to 0.98) 0.96 (0.92 to 0.99) | 9.6 (4.5 to 20) 15 (7.5 to 32) 12 (5.2 to 30) | 0.53 (0.38 to 0.73) 0.27 (0.14 to 0.55) 0.55 (0.40 to 0.78)
Plusoptix/Power Refractor (5 studies)
Arthur et al, 2009^78^ | Amblyopia risk factors | 0.83 (0.67 to 0.93) | 0.95 (0.92 to 0.98) | 18 (10 to 33) | 0.17 (0.08 to 0.36)
Dahlmann-Noor et al, 2009^85^ | Decreased visual acuity, strabismus, and ptosis | 0.45 (0.29 to 0.62) | 1.0 (0.98 to 1.0) | 230 (14 to 3680) | 0.56 (0.42 to 0.74)
Dahlmann-Noor et al, 2009^84^ | Myopia | 0.88 (0.30 to 1.0) | 0.96 (0.89 to 0.99) | 21 (7.8 to 55) | 0.13 (0.01 to 1.7)
Dahlmann-Noor et al, 2009^84^ | Hyperopia | 0.20 (0.10 to 0.35) | 0.99 (0.92 to 1.0) | 26 (1.6 to 450) | 0.81 (0.70 to 0.94)
Dahlmann-Noor et al, 2009^84^ | Astigmatism | 0.75 (0.36 to 0.96) | 0.93 (0.86 to 0.97) | 11 (4.7 to 24) | 0.27 (0.08 to 0.89)
Dahlmann-Noor et al, 2009^84^ | Anistometropia | 0.50 (0.31 to 0.69) | 0.87 (0.77 to 0.93) | 3.7 (1.9 to 7.1) | 0.58 (0.40 to 0.84)
Matta et al, 2008^96^ | Amblyopia risk factors | 0.98 (0.85 to 1.0) 0.98 (0.85 to 1.0) | 0.68 (0.51 to 0.81) 0.88 (0.74 to 0.96) | 3.0 (1.9 to 4.7)^i^ 8.4 (3.7 to 19)^a^ | 0.04 (0.01 to 0.26)^i^ 0.03 (0.00 to 0.20)^a^
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.54 (0.49 to 0.59)^a^ | 0.90 (0.88 to 0.92)^a^ | 5.4 (4.4 to 6.6)^a^ | 0.51 (0.46 to 0.57)^a^
Palm-Automatic Refractometer (1 study)
VIP Study Group, 2011^106^ Phase II (Pilot) | Overall | 0.74 (0.61 to 0.84)^l^ | 0.90 (0.83 to 0.95) | 7.14 (4.10 to 12.43) | 0.29 (0.19 to 0.44)
VIP Study Group, 2011^106^ Phase II (Pilot) | Amblyopia | 0.75 (0.53 to 0.90) | 0.90 (0.83 to 0.95) | 7.36 (4.38 to 12.36) | 0.28 (0.14 to 0.56)
VIP Study Group, 2011^106^ Phase II (Pilot) | Strabismus | 0.70 (0.35 to 0.93) | 0.90 (0.83 to 0.95) | 7.04 (3.84 to 12.92) | 0.33 (0.13 to 0.86)
VIP Study Group, 2011^106^ Phase II (Pilot) | Refractive error | 0.84 (0.71 to 0.92) | 0.90 (0.83 to 0.95) | 8.11 (4.78 to 13.74) | 0.18 (0.10 to 0.33)
VIP Study Group, 2011^106^ Phase II (Pilot) | Reduced visual acuity | 0.30 (0.06 to 0.65) | 0.90 (0.83 to 0.95) | 3.02 (1.06 to 8.61) | 0.78 (0.52 to 1.17)
Photoscreeners
MTI Photoscreener (6 studies)
Miller et al, 2001^110^ | Astigmatism | 0.66 (0.59 to 0.73) | 0.71 (0.64 to 0.78) | 2.3 (1.8 to 2.9) | 0.48 (0.38 to 0.60)
Ottar et al, 1995^100^ and Donahue et al, 2002^101^ | Amblyopia risk factors | 0.82 (0.76 to 0.87) | 0.91 (0.88 to 0.93) | 8.7 (6.9 to 11) | 0.20 (0.15 to 0.27)
Ottar et al, 1995^100^ and Donahue et al, 2002^101^ | Higher magnitude amblyopia risk factors | 0.50 (0.39 to 0.61) | 0.98 (0.97 to 0.99) | 33 (18 to 58) | 0.51 (0.41 to 0.63)
Rogers et al, 2008^102^ | Amblyopia risk factors | 0.95 (0.86 to 0.99) | 0.88 (0.74 to 0.96) | 8.0 (3.5 to 18) | 0.06 (0.02 to 0.18)
Tong et al, 2000^105^ | Amblyopia risk factors | 0.56 (0.50 to 0.62) | 0.91 (0.84 to 0.96) | 6.4 (3.4 to 12) | 0.48 (0.42 to 0.56)
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.37 (0.32 to 0.42) | 0.94 (0.92 to 0.95) | 6.2 (4.7 to 8.1) | 0.67 (0.62 to 0.72)
Weinand et al, 1998^109^ | Amblyopia risk factors | 0.83 (range, 0.72 to 0.94)^m^ | 0.66 (range, 0.42 to 0.74)^m^ | 2.4 (range, 1.6 to 3.0)^m^ | 0.26 (range, 0.14 to 0.38)^m^
iScreen Photoscreener (2 studies)
Kennedy et al, 2000^93^ | Amblyopia risk factors | 0.92 (0.88 to 0.95) | 0.89 (0.83 to 0.94) | 8.6 (5.4 to 14) | 0.09 (0.06 to 0.13)
VIP Study Group, 2004^65^ | Amblyopia risk factors or significant nonamblyogenic refractive error | 0.37 (0.32 to 0.42) | 0.94 (0.92 to 0.95) | 6.2 (4.7 to 8.1) | 0.67 (0.62 to 0.72)
VisiScreen 100 Photoscreener (2 studies)
Cogen et al, 1992^83^ | Amblyopia risk factors | 0.85 (0.55 to 0.98) | 0.94 (0.87 to 0.98) | 14 (6.3 to 32) | 0.16 (0.05 to 0.59)
Morgan et al, 1987^99^ | Amblyopia risk factors | 0.91 (0.76 to 0.98) | 0.74 (0.52 to 0.90) | 3.5 (1.7 to 7.0) | 0.12 (0.04 to 0.36)
Otago (Noncommercial) Photoscreener (2 studies)
Kennedy et al, 1995^92^ | Amblyopia risk factors | 0.46 (0.22 to 0.72) | 1.0 (0.99 to 1.0) | 110 (38 to 310) | 0.54 (0.33 to 0.89)
Kennedy et al, 1989^91^ | Amblyopia risk factors | 0.94 (0.87 to 0.98) | 0.94 (0.89 to 0.98) | 16 (8.2 to 32) | 0.06 (0.03 to 0.14)
Off-Axis-Type Photoscreener (1 study)
Kennedy et al, 1989^91^ | Amblyopia risk factors | 0.85 (0.76 to 0.91) | 0.87 (0.80 to 0.92) | 6.5 (4.2 to 10) | 0.18 (0.11 to 0.28)
Retinal Birefringence Scanning
Pediatric Vision Scanner (1 study)
Jost et al, 2016^89^ | Amblyopia or strabismus | 1.00 (0.02 to 1.0) | 0.90 (0.83 to 0.96) | 10.4 (5.61 to 19.4) | 0.0

a Based on 90% specificity.

b Based on 0.80 acuity score cutoff.

c Results stratified by age: 3, 4 years to young, 4 years to old, and 5 years (see Appendix E Table 7).

d Results stratified by levels of disparity: 120, 240, and 480 arcsec (see Appendix E Table 1).

e Results stratified by levels of disparity: 200, 400, and 800 arcsec (see Appendix E Table 1).

f Data presented are for 90% specificity; data for 94% specificity are in Appendix E Table 4.

g For all of the “sensitivity” cells for Ciner et al, 2011^106^ in this section: data presented are for 90% specificity; data for 94% specificity are in Appendix E Table 4.

h Data presented are for 90% specificity; data for additional levels of specificity and for additional groups of conditions are in Appendix E Table 4.

i Based on manufacturer's referral criteria.

j Confidence intervals not calculable.

k Based on VIP 90% specificity criteria.

l For all of the sensitivity data cells: data presented are for 90% specificity; data for additional levels of specificity are in Appendix E Table 4.

m Based on median results from multiple readers.

Abbreviations: CI=confidence interval; D=diopter; IOD=interocular difference; KQ=key question; NR=not reported; VIP=Vision in Preschoolers.

The age of participants in most studies was 3 years or older (e.g., 3 to 4, 3 to 5, 4 to 5, or 3 to 7 years). About a third of the studies included participants younger than age 3 years,^77, 83, 89, 90, 95, 96, 99, 100, 102, 103, 105, 109-111^ and some reported including children as young as age 6 months.^83, 90, 96, 100, 109^ The included studies reported accuracy of tests for a variety of target conditions, ranging from very specific (e.g., astigmatism, myopia, anisometropia) to broad (e.g., amblyopia risk factors) (Table 4).

Less than half of the included studies (14 studies) recruited participants from ophthalmology clinics.^81, 83, 84, 87, 90, 91, 93, 96, 99, 102, 103, 105, 109, 110^ Most (17 studies) recruited from community, Head Start, or school settings;^65, 77-80, 85, 86, 88, 92, 94, 95, 97, 98, 104, 106-108, 111^ one study was conducted in a private pediatric primary care clinic,^89^ one was conducted partly in a primary care setting (in public health and pediatric clinics),^100^ and one did not report the setting.^82^ The prevalence of target conditions was generally much higher in samples from ophthalmology clinics than in those from primary care, community, Head Start, or school settings (>70% of studies from ophthalmology clinics reported prevalence ≥36% [range, 36% to 81%], whereas all of the studies from primary care, community, Head Start, or school settings reported prevalence ≤36% [range, 1% to 36%]).

The largest studies used data from phases 1 and/or 2 of the Vision In Preschoolers (VIP) study group (≤4,040 participants) and reported prevalence of any target conditions from 21 to 36 percent. The VIP study enrolled children from Head Start and oversampled children with amblyopia, amblyopia risk factors, reduced visual acuity, or strabismus identified on a screening evaluation.^65, 88, 94, 104, 106-108, 111^ Phase 1 of the VIP study enrolled 3- to 5-year-old children in Head Start who were selected to overrepresent children with vision problems and compared the accuracy of 11 screening tests.^65^ Tests were conducted in specially equipped vans that provided a standard environment with minimal distractions. Phase 2 compared the performance of nurse versus lay screeners and focused on four of the 11 screeners (based on findings of phase 1); specifically, Retinomax autorefractor, SureSight Vision Screener, crowded linear LEA Symbols visual acuity test at 10 feet, and the Stereo Smile II test.^108^ Unlike many of the other included studies that focused on just amblyopia and/or amblyopia risk factors, the VIP study evaluated accuracy for a broader range of conditions, including significant nonamblyogenic refractive error.

The included studies were all rated fair quality (Appendix Table D3). The most common methodological shortcomings were a high rate (or not reporting the rate) of uninterpretable results or noncompliance with screening test or reference standard (14 studies [41%]), not reporting whether children with uninterpretable results or noncompliance were included in analyses (16 studies [47%]), lack of a representative spectrum of patients (19 studies [56%]), and lack of description of enrolling a random or consecutive sample (22 studies [65%]).

Publications from phases 1 and 2 of the VIP study were assessed as fair quality. Key methodological limitations included not enrolling a representative spectrum of patients and not predefining screening cutoffs (rather than predefining cutoffs, sensitivity for each test was calculated based on the cutoff needed to yield specificity of 0.90 or 0.94). Although this approach allows for clear comparison of sensitivity across tests (because the specificity is essentially fixed), it may introduce bias and may overestimate accuracy, because cutoffs were defined post hoc. The applicability of the VIP study may be limited because it did not enroll a representative spectrum, study subjects may have experienced fatigue from the volume of tests (children underwent 6 to 8 procedures, many more than are typically used in routine clinical screening), and testing was conducted by highly skilled personnel in a controlled environment (in phase 1).

#### Visual Acuity Tests

Six fair-quality studies evaluated visual acuity tests (LEA Symbols or HOTV, 6 studies) (Table 4; Appendix E).^65, 81, 97, 98, 107, 108^ All six assessed LEA Symbols and two^65, 107^ also assessed HOTV.

Three publications from the VIP study group (6,019 total participants) evaluated the accuracy of LEA Symbols for detecting amblyopia risk factors or significant nonamblyogenic refractive error.^65, 107, 108^ When screening test cutoffs were set to achieve specificity of 90 percent, phase 1 of the VIP study found that an abnormal result moderately increased the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error both overall (PLR, 6.1 [95% CI, 4.8 to 7.6])^65^ and for those in the 3-, 4-, and 5-year-old age groups (PLR range, 5.95 to 7.39).^107^ It found that a normal result indicated a small decrease in the likelihood both overall (NLR, 0.43 95% CI, 0.38 to 0.50) and for those in the 3-, 4-, and 5-year-old age groups (NLR range, 0.39 to 0.47]).^65, 107^ In phase 2, when using nurse and lay screeners, the VIP study found that an abnormal result indicated a small increase in the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error (PLRs, 4.9 [95% CI, 4.0 to 6.0] and 3.7 [95% CI, 3.0 to 4.7], respectively), and that a normal result indicated a minimal decrease in the likelihood (NLRs, 0.57 [95% CI, 0.52 to 0.62] and 0.70 [95% CI, 0.65 to 0.76], respectively).

The other three studies (773 total participants) that evaluated LEA Symbols each reported test characteristics for detecting different target conditions; one each for amblyopia risk factors, significant refractive error, and astigmatism. Briefly, one study (N=149) from a pediatric ophthalmology setting found that an abnormal result moderately increased the likelihood of amblyopia risk factors (PLR, 5.7 [95% CI, 3.8 to 8.6]) and a normal result indicated a large decrease in the likelihood (NLR, 0.05 [95% CI, 0.01 to 0.36]).^81^ The other two evaluated Native American children in Head Start and found that an abnormal result minimally increased the likelihood of either significant refractive error (among those with astigmatism)^97^ or astigmatism^98^ and a normal result indicated a small^97^ or moderate^98^ decrease in the likelihood, respectively (Table 4).

Two publications from the VIP study group (3,121 total participants) evaluated the accuracy of HOTV visual acuity tests for detecting amblyopia risk factors or significant nonamblyogenic refractive error.^65, 107^ Both evaluated participants from phase 1 and found that an abnormal result indicated a small to moderate increase in the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error when screening test cutoffs were set to achieve specificity of 90 percent (overall PLR, 4.9 [95% CI, 3.9 to 6.1];^65^ PLR range, 3.76 to 6.83 for the 3-, 4-, and 5-year-old age groups^107^). They found that normal results indicated a minimal to small decrease in the likelihood (Table 4).

#### Stereoacuity Tests

Four fair-quality studies (7,801 total participants) evaluated stereoacuity tests, either the Stereo Smile II, the Randot Preschool Stereoacuity, or Random Dot E (Table 4).^65, 77, 87, 108^ These included evaluations of phase 1 and 2 of the VIP study and the Sydney Paediatric Eye Disease Study. Most of the studies found that abnormal results indicated a small increase in the likelihood of target conditions (PLR range, 3.6 to 4.9 in most studies) (Table 4) and normal results indicated either a minimal^65, 108^ decrease in the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error, or a moderate^87^ decrease in the likelihood of refractive error or strabismus.

#### Ocular Alignment Tests

Phase 1 of the VIP study (N=3,121) was the only study that evaluated an ocular alignment test, the cover-uncover test (Table 4).^65^ It found that abnormal results indicated a moderate increase in the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error (PLR, 7.9 [95% CI, 4.6 to 14.0]) and normal results indicated a minimal decrease in the likelihood.

#### Combinations of Clinical Tests

Four fair-quality studies (1,854 total participants) evaluated a combination of clinical tests, including visual acuity tests, stereoacuity tests, and ocular alignment tests (Table 4; Appendix Table E1).^80, 82, 92, 103^ The specific tests evaluated varied somewhat across studies (Appendix Table E1). Three of the four studies found that abnormal results indicated a large increase in the likelihood of amblyopia or its risk factors (PLR range, 12 to 17).^80, 92, 103^ The largest of these three studies (N=1,180) was set in kindergartens in Germany and evaluated 3-year-olds, with screening conducted by an orthoptist.^80^ The one study that found a smaller PLR (4.8 [95% CI, 2.8 to 8.4]) was the smallest (N=141) of the four studies; screening was conducted by nurses and the study setting was not reported.^82^ The four studies found more variability for NLRs, with results ranging from minimal^92^ to small^82, 103^ to moderate^80^ NLRs (range, 0.10 to 0.91) (Table 4).

#### Autorefractors

Sixteen fair-quality studies (16,712 observations) evaluated autorefractors (Table 4; Appendix E).^65, 78, 79, 84, 85, 89, 90, 94, 96-98, 102, 106, 108, 110, 111^ Eight evaluated Retinomax,^65, 79, 94, 97, 98, 106, 108, 111^ seven evaluated SureSight,^65, 89, 90, 94, 102, 108, 111^ five evaluated Plusoptix/Power Refractor,^65, 78, 84, 85, 96^ one evaluated the Topcon PR 2000,^110^ and one evaluated the Palm to Automatic Refractometer.^106^ Overall, most studies found moderate PLRs and small NLRs, although some found large PLRs and NLRs.

Autorefractor screening was administered by a variety of personnel across studies, including orthoptists, ophthalmologists, licensed eye professionals, nurses, trained laypersons, research staff, and Head Start staff, and was sometimes not reported. Sample sizes ranged from 80^96^ to 4,040.^94, 111^ Eleven studies were conducted in the United States, one in Canada, and four in Europe (Appendix Table E2). The age of participants in most studies was 3 years or older (e.g., 3 to 5, 4 to 5 years). Five studies included participants younger than age 3 years,^89, 90, 96, 102, 110^ and two of those included children as young as age 6 months.^90, 96^ The included studies reported accuracy of tests for a variety of target conditions, ranging from very specific (e.g., astigmatism, myopia, anisometropia) to broad (e.g., amblyopia risk factors) (Table 4). Most (10 studies) recruited from Head Start or school settings.^65, 78, 79, 85, 94, 97, 98, 106, 108, 111^ Five of the studies recruited participants from ophthalmology clinics,^84, 90, 96, 102, 110^ and one took place in a pediatric primary care clinic.^89^

##### Retinomax

Of the eight studies that evaluated Retinomax,^65, 79, 94, 97, 98, 106, 108, 111^ most found that abnormal results indicated a moderate increase in the likelihood of target conditions (i.e., moderate PLRs) and a normal result indicated a small decrease in the likelihood (i.e., small PLRs) (Table 4). For example, when screening test cutoffs were set to achieve specificity of 90 percent, phase 1 of the VIP study found that an abnormal result moderately increased the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error (PLR, 6.1 [95% CI, 5.2 to 7.0]) and a normal result indicated a small decrease in the likelihood (NLR, 0.41 [95% CI, 0.37 to 0.45]).^65^

Some studies found slightly higher or lower likelihood ratios. One study that evaluated 3- to 5-year-old Native American children in Head Start (N=379) found a large PLR for astigmatism,^98^ and one study of 3-year-olds in kindergartens in Germany (N=404) found a minimal PLR for amblyopia.^79^ Two studies that evaluated 3- to 5-year-old Native American children in Head Start found that a normal result indicated a moderate to large decrease in the likelihood of either significant refractive error (among those with astigmatism)^97^ or astigmatism among a high-prevalence (48%) population.^98^

##### SureSight

Of the seven studies that evaluated the SureSight autorefractor,^65, 89, 90, 94, 102, 108, 111^ four were from the VIP study group and evaluated the accuracy for detecting amblyopia risk factors or significant nonamblyogenic refractive error.^65, 94, 108, 111^ When screening test cutoffs were set to achieve specificity of 90 percent, phase 1 of the VIP study found that an abnormal result moderately increased the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error (PLR, 6.3 [95% CI, 5.2 to 7.4]) and a normal result indicated a small decrease in the likelihood (NLR, 0.41 [95% CI, 0.36 to 0.47]).^65^ In phase 2, when using nurse and lay screeners, the VIP study found similar results.^108^ In contrast, when screening test cutoffs were set based on the manufacturer's referral criteria, the VIP study found a small PLR (2.2 [95% CI, 2.0 to 2.4]). Similarly, two other U.S.-based studies that recruited from ophthalmology settings (270 total participants) reported small PLRs for the likelihood of amblyopia risk factors when using the manufacturer's referral criteria.^90, 102^

One study with 102 participants ages 2 to 6 years conducted in a private pediatric primary care practice in the United States reported that an abnormal result moderately increased the likelihood of amblyopia or strabismus (PLR, 7.9 [95% CI, 4.7 to 13.4]) and a normal result indicated a large decrease in the likelihood (NLR, 0.0).^89^ Screening with SureSight detected the only participant with amblyopia or strabismus (sensitivity, 100%); the study found a specificity of 87 percent (95% CI, 79% to 93%).

##### Plusoptix

All five of the studies that evaluated the Plusoptix autorefractor (previously known as the Power Refractor) reported moderate to large PLRs for some of the target conditions they assessed (Table 4).^65, 78, 84, 85, 96^ When screening test cutoffs were set to achieve specificity of 90 percent, phase 1 of the VIP study found that an abnormal result moderately increased the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error (PLR, 5.4 [95% CI, 4.4 to 6.6]) and a normal result indicated a minimal decrease in the likelihood (NLR, 0.51 [95% CI, 0.46 to 0.57]).^65^ Another study reported similarly that an abnormal result moderately increased the likelihood of ambylogenic risk factors (PLR, 8.4 [95% CI, 3.7 to 19]) when referral criteria were modified to enhance specificity.^96^ Three of the five studies reported large PLRs for amblyopia risk factors; myopia, hyperopia, and astigmatism; or decreased visual acuity, strabismus, and ptosis.^78, 84, 85^

##### Topcon PR 2000

The only included study (N=222) that evaluated the Topcon PR 2000 recruited children from ophthalmology clinics in the United Kingdom and reported moderate to large PLRs and small to minimal NLRs for spherical error, anisometropia, and astigmatism (Table 4).^110^

##### Palm to Automatic Refractometer

The only included study (N=190) that evaluated the Palm to Automatic Refractometer was the pilot portion of phase 2 of the VIP study.^106^ It reported a moderate PLR for a combination of four target conditions (amblyopia, strabismus, refractive error, and reduced visual acuity) and a small NLR when screening was conducted by one trained and certified non–eye-care professional screener (Table 4).

#### Photoscreeners

Eleven fair-quality studies (12 publications, 6,187 observations) evaluated photoscreeners (Table 4; Appendix E).^65, 83, 91-93, 98-102, 105, 109^ Six studies (7 publications) evaluated the MTI photoscreener,^65, 98, 100-102, 105, 109^ two evaluated the iScreen photoscreener,^65, 93^ two evaluated the VisiScreen 100 photoscreener,^83, 99^ and two evaluated an Otago photoscreener.^91, 92^ Overall, most studies found moderate PLRs and small NLRs, although some found larger or smaller likelihood ratios.

Photoscreening was administered by a variety of personnel across studies, including orthoptists and pediatricians,^100, 101^ licensed eye professionals,^65^ trained laypersons,^102^ and technicians,^83, 91-93^ and was sometimes not reported.^105, 109^ Sample sizes ranged from 63^99^ to 3,121.^65^ Seven studies were conducted in the United States and three in Canada, and one country was not reported (Appendix Table E2). Most studies allowed for inclusion of children younger than age 3 years. The included studies reported accuracy of tests for a variety of target conditions, ranging from very specific (e.g., astigmatism, strabismus) to broad (e.g., amblyopia risk factors) (Table 4). Most (7 studies) recruited from ophthalmology clinics, with fewer recruiting from primary care, community, Head Start, or school settings.^65, 92, 98, 100^

##### MTI Photoscreener

Of the six studies (7 publications) that evaluated the MTI photoscreener,^65, 98, 100-102, 105, 109^ most (including phase 1 of the VIP study) found that abnormal results indicated a moderate increase in the likelihood (i.e., moderate PLRs) of amblyopia risk factors or a composite of amblyopia risk factors or significant nonamblyogenic refractive error (Table 4).^65, 100-102, 105^ One study also reported a large PLR for detecting higher-magnitude amblyopia risk factors (PLR, 33 [95% CI, 18 to 58]).^100, 101^ Two other studies found small PLRs for 3- to 5-year-old Native American children in Head Start (N=379) for astigmatism^98^ or 6- to 48-month-old children (N=112) in an ophthalmology clinic for amblyopia risk factors.^109^ Most of the included studies found small to minimal NLRs (Table 4),^65, 98, 100, 101, 105, 109^ although one study of 100 children ages 1 to 6 years screened by a trained layperson in ophthalmology clinics found a large NLR for amblyopia risk factors (0.06 [95% CI, 0.02 to 0.18]).^102^

##### iScreen Photoscreener

Both of the included studies that evaluated the iScreen photoscreener found moderate PLRs (Table 4).^65, 93^ However, NLRs differed. Phase 1 of the VIP study found that normal results indicated a minimal decrease in the likelihood of amblyopia risk factors or significant nonamblyogenic refractive error (NLR, 0.67 [95% CI, 0.62 to 0.72]),^65^ whereas a Canadian study of more than 400 children (prevalence of amblyopia risk factors, 64%) screened by a technician in ophthalmology clinics found a large NLR for amblyopia risk factors (0.09 [95% CI, 0.06 to 0.13]).^93^

##### VisiScreen 100 Photoscreener

The two included studies of the VisiScreen 100 photoscreener found very different PLRs but similar NLRs (Table 4).^83, 99^ Both were conducted in the United States in ophthalmology settings and targeted amblyopia risk factors. One found a large PLR (14 [95% CI, 6.3 to 32]) and moderate NLR (0.16 [95% CI, 0.05 to 0.59]) among 127 children ages 6 months to 6 years who were screened by a technician.^83^ The other found a small PLR (3.5 [95% CI, 1.7 to 7.0]) and moderate NLR (0.12 [95% CI, 0.04 to 0.36]) among 63 children ages 3 months to 8 years.^99^

##### Otago Photoscreener

The two included studies of Otago-type photoscreeners (noncommercial; developed by the study investigators) both found large PLRs for amblyopia risk factors but very different NLRs (Table 4).^91, 92^ Both were conducted in Canada with screening by a technician, but one (N=236) was conducted in an ophthalmology clinic^91^ and one (N=264) in a school setting (kindergarten).^92^ The former found a large NLR (0.06 [95% CI, 0.03 to 0.14]),^91^ whereas the latter found a minimal NLR (0.54 [95% CI, 0.33 to 0.89]).^92^

#### Retinal Birefringence Scanning

One study with 102 participants ages 2 to 6 years conducted in a private pediatric primary care practice in the United States evaluated the Pediatric Vision Scanner. It reported that an abnormal result indicated a large increase in the likelihood of amblyopia or strabismus (PLR, 10.4 [95% CI, 5.6 to 19.4]) and a normal result indicated a large decrease in the likelihood (NLR, 0.0).^89^ Screening with the Pediatric Vision Scanner detected the only participant with amblyopia or strabismus (sensitivity, 100%); the study found a specificity of 90 percent (95% CI, 83% to 96%).

#### Direct Comparisons of Different Screening Tests

Few of the included studies directly compared different tests. The best evidence directly comparing various tests comes from the VIP study investigators. As described above, phase 1 of the VIP study compared 11 screening tests among 3- to 5-year-old children in Head Start.^65^ Tests were conducted in specially equipped vans that provided a standard environment with minimal distractions. Phase 2 compared the performance of nurse versus lay screeners and focused on the best four screening tests (based on findings of phase 1): Retinomax autorefractor, SureSight Vision Screener, LEA Symbols, and the Stereo Smile II test.^108^ When screening test cutoffs were set to achieve specificity of 90 percent, phase 1 of the VIP study reported higher sensitivities for LEA Symbols or HOTV visual acuity tests, Retinomax autorefractor, SureSight autorefractor, and Power Refractor for detecting any visual condition than for the Random Dot E stereoacuity test, Stereo Smile II test, iScreen photoscreener, and MTI photoscreener (Appendix Table E8). Nevertheless, likelihood ratios were similar, and PLRs generally fell within the moderate range, with NLRs in the small to minimal range. Confidence intervals generally overlapped.

### KQ 2a Does Accuracy Vary by Age?

We included five studies that evaluated whether accuracy varies by age (results are summarized in Appendix Table E7).^82, 90, 93, 105, 107^ All five evaluated different screening tests, including visual acuity tests (LEA Symbols and HOTV),^107^ a combination of clinical tests (LEA Symbols visual acuity test, Frisby stereoacuity test, and external visual inspection),^82^ the SureSight autorefractor,^90^ the iScreen photoscreener,^93^ or the MTI photoscreener.^105^ All five assessed different age stratifications/comparisons. As described above (under “Visual Acuity Tests”), the VIP study group reported similar PLRs and NLRs among children in the 3-, 4-, and 5-year-old age groups for LEA Symbols and HOTV visual acuity tests for detecting amblyopia risk factors or significant nonamblyogenic refractive error.^107^ The study that evaluated a combination of clinical tests (N=141 evaluated) compared children age 41 months or older with those younger than age 41 months.^82^ The study of the SureSight autorefractor compared children ages 3 to 5 years with those younger than age 3 years.^90^ The study of the iScreen photoscreener compared children ages 4 to 6 years with those age 3 years or younger.^93^ The study of the MTI photoscreener compared children by quartiles of age.^105^ Overall, data were relatively limited and estimates were somewhat imprecise, but studies did not find any clear differences in accuracy of tests when results were stratified according to age.

#### Testability

The ability of children to complete various screening tests (i.e., testability) provides additional information about how the utility of tests may vary by age. Testability information was reported by many of the included studies, although few of those reported data stratified by age or for children younger than age 3 years. Appendix Table E8 summarizes the proportion of children who were reported to be unexaminable in each study. Overall, testability exceeded 90 percent in the majority of studies, and few studies reported testability rates less than 80 percent for any tests, but all studies that reported rates less than 80 percent included children younger than age 3 years.^77, 90, 95, 102^ Further, some studies demonstrated that testability rates improved somewhat as children age from 2 to 5 or 6 years^95, 103^ or from 3 to 5 years,^65, 81, 113^ and others found that testability was better for children ages 4 to 6 years than for the overall sample of participants ages 1 to 6 years^102^ or for those age 3 years or older than for those younger than age 3 years.^90^

Several studies addressed variation in testability of visual acuity and stereoacuity by age. The Sydney Paediatric Eye Disease Study (N=1,170) found that testability rates were 10 percent for visual testing with HOTV at ages 24 to less than 30 months, and steadily improved to 80 percent by ages 36 to less than 42 months and to 95 percent by ages 48 to less than 54 months among Australian children.^95^ The VIP study found testability rates greater than 95 percent for LEA Symbols and HOTV at ages 3, 4, and 5 years, but found higher rates of testability for 5-year-olds than for 3-year-olds for Random Dot E (95% vs. 86%).^65, 112, 113^ A smaller study (N=149) from ophthalmology clinics in Italy found that testability with LEA Symbols improved from 93 percent in children ages 38 to 42 months up to 100 percent in those ages 49 to 54 months.^81^ A study from U.S. ophthalmology clinics (N=269) reported an increase in Random Dot E testability from 65 to 100 percent from ages 2 to 6 years.^103^

For autorefractors and photoscreeners, the VIP study found testability rates near 100 percent.^65^ Applicability to younger children is uncertain because the VIP study did not include children younger than age 3 years. Further, the vast majority (93%) of the 3-year-olds in the study were at least age 42 months. Two smaller studies from U.S. ophthalmology clinics reported better testability for older preschool-age children than for younger ones. The first study (N=100) found that testability with both the SureSight autorefractor and the MTI photoscreener was perhaps slightly better for children ages 4 to 6 years than for the overall sample of participants ages 1 to 6 years (80% vs. 76% and 100% vs. 96%, respectively).^102^ The other study (N=170) reported that testability with the SureSight autorefractor was worse for children younger than age 3 years than for those age 3 years or older (49% vs. 84%; p<0.001).^90^

The study with 102 participants ages 2 to 6 years conducted in a private pediatric primary care practice in the United States reported testability rates of 93 percent (95/102) and 94 percent (96/102) with the Pediatric Vision Scanner and the SureSight autorefractor, respectively.^89^ All but one of the children unable to perform a test were age 2 or 3 years. Among 2-year-olds, 17 percent (5/29) were unable to be tested with the Pediatric Vision Scanner, and 14 percent (4/29) were unable to be tested with the SureSight autorefractor.

### KQ 3 Harms of Screening

We included one controlled study that evaluated potential psychosocial effects^114^ and used 16 studies of test accuracy described in KQ 2 to calculate false-positive rates (1 minus positive predictive value).

The one controlled study used the ALSPAC population-based cohort (N=4,473) to assess bullying.^114^ It prospectively compared children who had been offered state-provided preschool screening for amblyopia (at age 37 months) with those who had not. The study aimed to test the theory that preschool screening might reduce bullying. In theory, although patching treatment and wearing glasses may increase the risk of being bullied, preschool screening may result in greater likelihood that any needed patching treatment is concluded before school starts, thus avoiding potential psychosocial effects. The outcome measure was bullying victimization by age 8 years assessed with a structured standard interview; children were asked whether they had repeatedly (≥4 times per month) been the victims of bullying.

The study showed a reduction in school-age bullying among patched children screened in preschool. Children offered screening had a lower likelihood of being bullied compared with those not screened earlier (25.7% vs. 47.1%; p=0.033; adjusted OR, 0.39 [95% CI, 0.16 to 0.92], adjusted for sex, paternal socioeconomic class, highest level of maternal education, and type of housing). These effects were seen in children who were patched and not in those who were only prescribed glasses. The authors suggest that the findings indicate that earlier screening can potentially reduce psychosocial harms.

The most frequently assessed potential harms of screening were false-positive results (that would lead to unnecessary referrals). In general, studies with a lower prevalence (<10%) of vision abnormalities showed much higher false-positive rates (usually >75%), while studies with a high prevalence had lower false-positive rates (usually <35%) (Figure 3).

Figure 3 Relationship Between Prevalence of Vision Problems and False-Positive Rates in 16 Studies

Abbreviation: PPV=positive predictive value.

This figure depicts the relationship between the prevalence of vision problems and the false-positive rate (as calculated by 1 minus the positive predictive value) in 16 studies included for key question 3. Six of the 7 studies with a prevalence of vision disorders below 10% found false-positive rates above 60%. Conversely, 7 of the 9 studies with prevalence of vision disorders at or above 20% found false-positive rates below 35%.

In seven studies with vision disorder prevalence more similar to the general population (1% to 8%), false-positive rates were generally high. Six of the seven studies found false-positive rates between 62 and 99 percent;^77, 79, 80, 87, 89, 103^ rates ranged from 23 to 99 percent when considering all seven studies.^77, 79, 80, 87, 89, 92, 103^ The one study (N=270) that reported a lower false-positive rate was unlike the other studies in that it sampled a subset (rather than all) of children with normal screening results; participants were children who screened positive (n=29) plus a random sample of those who did not (n=241).^92^ It found false-positive rates of 46 and 23 percent for a manual approach to screening (Snellen E or Stycar-graded balls visual acuity tests and Titmus stereotest) and for an Otago-type photoscreener, respectively. The seven studies with low prevalence of vision disorders evaluated the performance of the Retinomax autorefractor,^79^ Random Dot E,^77, 87^ Stereo Smile II test,^77^ Otago-type photoscreener,^91^ Pediatric Vision Scanner,^89^ SureSight autorefractor,^89^ or a combination of manual screening tools.^80, 92, 103^

In contrast, in nine studies with a higher prevalence (20% to 81%), false-positive rates were generally lower. Seven of these nine studies had false-positive rates less than 32 percent,^93, 99, 100, 102, 105, 107, 109^ and rates ranged from 3 to 65 percent.^65, 93, 99, 100, 102, 105-107, 109^ These studies evaluated the iScreen photoscreener,^65, 93^ VisiScreen 100 photoscreener,^99^ MTI photoscreener,^65, 100, 102, 105, 109^ SureSight autorefractor,^65, 102^ LEA Symbols,^65, 107^ HOTV,^65, 107^ Random Dot E,^65^ cover-uncover test,^65^ noncycloplegic retinoscopy,^65^ Retinomax autorefractor,^65, 106^ Stereo Smile II test,^65^ Power Refractor II,^65^ Palm-Automatic Refractometer,^106^ and SureSight Vision Screener.^65, 102^

### KQ 4 Benefits of Treatment of Amblyopia, Its Risk Factors, and Refractive Error

We included one fair- and two good-quality trials that evaluated benefits of treatment (Table 5).^115-117^ All three trials were included in the previous review.^67^ All trials evaluated patching for amblyopia or amblyopic risk factors. Two of the included trials compared patching with no patching (children were pretreated with eyeglasses if indicated in both groups),^116, 117^ and one compared patching plus eyeglasses versus eyeglasses alone versus no treatment.^115^ One trial included a run-in phase, during which all participants wore updated eyeglass prescriptions until visual acuity in the amblyopic eye stopped improving;^116^ another trial treated children with refractive error with 6 weeks of corrective lenses prior to allocation.^117^ None of the included studies evaluated atropine or vision therapy. Sample sizes ranged from 60^117^ to 180.^116^ The trials enrolled preschoolers with a mean age ranging from 4 to 5.2 years. All three studies included children based on visual acuity criteria. Only one of the three trials (the one that compared patching plus eyeglasses vs. eyeglasses alone vs. no treatment) enrolled screen-detected children.^115^ Duration of treatment (and followup) was different in each trial: 5 weeks (1 year),^116^ 12 weeks (12 weeks),^117^ and 1 year (1.5 years).^115^ All included trials were conducted in the United States^116^ or the United Kingdom.^115, 117^ Most of the trials reported different outcome measures. Of the three studies, two measured best corrected visual acuity^115, 116^ and one measured improvement in visual acuity as a secondary outcome.^117^ We did not pool results primarily because of differences in populations (e.g., eligibility criteria, baseline visual acuity), outcome measures, comparisons, and duration of followup. Overall, the trials indicate that treatment of amblyopia or its risk factors results in small improvements in visual acuity, on average.

Table 5 Characteristics and Results of Randomized Trials That Evaluate Treatment of Amblyopia, Its Risk Factors, and Refractive Error (KQs 4 and 5)

Author, Year Study Name Quality | Sample Size Duration | Age Diagnosis | Country Setting | Intervention(s) vs. Control | Main Results
Awan, Proudlock, and Gottlob, 2005^117^ Fair | 60 12 weeks | Mean age, 4.6 years (range, up to 8) 45% strabismus 42% mixed amblyopia | U.K. Ophthalmology and orthoptic clinics | Patching 3 hours/day Patching 6 hours/day No treatment for 12 weeks Eyeglasses were prescribed for all who needed them (all groups) | Mean change (SD) in visual acuity 3-hour patching: 0.29 (0.14) 6-hour patching: 0.34 (0.19) No treatment: 0.24 (0.17) Snellen equivalent (lines of improvement) 3-hour patching: 1.9 (1.0) 6-hour patching: 2.3 (1.2) No treatment: 1.6 (0.12)
Clarke et al, 2003^115^ Good | 177 1 year of treatment (78 weeks followup) | Mean age, 4 years (range, 3 to 5) 72% anisometropia | U.K. 8 eye clinics | Patching + eyeglasses vs. eyeglasses only vs. no treatment | Mean (SD) best-corrected visual acuity at 1 year Patching + eyeglasses: 0.19 (0.12) Eyeglasses only: 0.22 (0.17) No treatment: 0.30 (0.20) Mean difference (95% CI) from no treatment: Patching + eyeglasses: 0.11 (0.05 to 0.17) Eyeglasses only: 0.08 (0.02 to 0.15) In the subgroup with moderate acuity loss at baseline (n=63): Mean difference (95% CI) from no treatment: Patching + eyeglasses: 0.27 (0.14 to 0.39) Eyeglasses only: 0.11 (-0.03 to 0.24)
Wallace et al, 2006^116^ PEDIG Good | 180 5 weeks of treatment (≤52 weeks followup) | Mean age, 5.2 years (range, 3 to 7) 23% strabismus, 47% anisometropia, 30% strabismus and anisometropia | U.S. 46 clinical sites | Patching 2 hours/day (with ≥1 hour of near activities) vs. no patching Continued use of eyeglasses if needed, regardless of randomization group | Mean change (SD) in lines from baseline in amblyopic eye at 5 weeks Patching vs. control: 1.1 (1.6) vs. 0.5 (1.7) Mean (SD) logMAR acuity Patching vs. control: 0.44 (0.22) vs. 0.51 (0.28) Mean difference (95% CI) in logMAR acuity, adjusted for baseline acuity: 0.07 (0.02 to 0.12) Mean (SD) improvement in lines in amblyopic eye, best- measured acuity (from 5 to 52 weeks) Patching vs. control: 2.2 (1.8) vs. 1.3 (1.4) Difference (95% CI) in mean best logMAR acuity, adjusted for baseline acuity: 0.10 (0.05 to 0.14) Proportion of patients with ≥2 lines of improvement in visual acuity: Patching vs. control: 38/85 (45%) vs. 18/88 (21%)

Abbreviations: CI=confidence interval; IXT=intermittent exotropia; KQ=key question; logMAR=logarithm of the minimum angle of resolution; PACT=prism and alternate cover test; PD=prism diopters; PEDIG=Pediatric Eye Disease Investigator Group; RCT=randomized, controlled trial; SD=standard deviation; SPCT=simultaneous prism and cover test; U.K.=United Kingdom; U.S.=United States

#### Patching Versus No Patching

Two of the three trials compared patching with no patching (Table 5).^116, 117^ First, one good-quality trial from the Pediatric Eye Disease Investigator Group^116^ randomized 180 children whose baseline mean logMAR acuity was 0.56 (approximate Snellen equivalent of 20/75). After adjusting for baseline acuity, children treated with 2 hours per day of patching had better visual acuity in the amblyopic eye (mean logMAR visual acuity, 0.44 [equivalent Snellen, 20/50]) than those in the no-patching group (mean logMAR acuity, 0.51 [Snellen equivalent, 20/63]) at the end of the 5-week trial (adjusted mean difference in logMAR, 0.07 [95% CI, 0.02 to 0.12]). Visual acuity in the amblyopic eye had improved by an average of 1.1 lines in the patching group and 0.5 lines in the no-patching group (a difference of <1 line on a standard visual acuity chart). The investigators also found a difference of 0.10 (95% CI, 0.05 to 0.14) between treatment groups in mean best logMAR acuity (achieved at any visit) adjusted for baseline acuity at followup (including visits from week 5 through at least week 17). The proportion of children who experienced an improvement of at least 2 lines on the visual acuity chart was greater in the patching group than in the no-patching group (45% vs. 21%; p=0.003).

The second trial randomized 60 children with strabismic or mixed amblyopia to 3 hours of patching per day, 6 hours of patching per day, or no patching.^117^ The mean baseline logMAR acuity in the amblyopic eye was 0.63, 0.69, and 0.59 (approximate Snellen equivalents of 20/85, 20/100, and 20/80) in the three treatment groups, respectively. The trial focused primarily on assessing compliance but also reported visual acuity among secondary outcomes. It reported no statistically significant differences between groups in mean visual acuity improvement after 12 weeks (0.29 vs. 0.34 vs. 0.24, respectively; p=0.11; approximate Snellen equivalents of 1.9, 2.3, and 1.6 lines, respectively). However, the effect estimates trended in favor of the patching groups, compliance was suboptimal (participants wore patching for 58% of the prescribed time in the 3-hour group [mean, 103 minutes] and for 41% in the 6-hour group [mean, 153 minutes]), and the study was underpowered to find a small difference between groups.

#### Patching Plus Eyeglasses Versus Eyeglasses Alone Versus No Treatment

One good-quality trial compared patching plus glasses, glasses alone, and no treatment among preschoolers (N=177) with unilateral refractive error.^115^ The mean baseline logMAR acuity in the amblyopic eye for these 177 children was 0.36 (approximate Snellen equivalent, 20/45). The hours per day of patching were not reported. The trial found that both treatment conditions resulted in better visual acuity at 1 year compared with no treatment (mean difference in best corrected visual acuity between patching plus eyeglasses and no treatment, 0.11 logMAR [95% CI, 0.05 to 0.17]; mean difference between glasses alone and no treatment, 0.08 [95% CI, 0.02 to 0.15]). The differences between groups in acuity were not significant at 6 months posttrial, after all groups had received treatment (after the 1-year followup visit, children in the no-treatment and glasses-only groups received treatment following the same protocol as those in the combined treatment group).

#### Atropine

We found no eligible studies that examined atropine.

#### Vision Therapy

We found no eligible studies that examined vision therapy.

#### Treatment Differences for Subgroups

Two of the included trials^115, 116^ examined treatment outcomes for subgroups defined by baseline visual acuity. First, the good-quality trial from the Pediatric Eye Disease Investigator Group (N=180) assessed subgroups with either moderate (20/40 to 20/100) or severe (20/125 to 20/400) amblyopia at baseline.^116^ Findings for these subgroups were similar to the overall trial results for the primary outcome, visual acuity in the amblyopic eye. Second, the good-quality trial that compared patching plus eyeglasses, eyeglasses alone, and no treatment among preschoolers (N=177) assessed subgroups defined by baseline visual acuity abnormality.^115^ The authors assessed children with mild (0.18 to 0.30 logMAR) and moderate or worse (≥0.48 logMAR) refractive error at baseline and examined differences between treatment groups. For children with moderate refractive error at baseline, patching plus eyeglasses resulted in much greater improvement than no treatment at 1 year (0.27 logMAR [95% CI, 0.14 to 0.39]) compared with improvement for all participants (0.11 logMAR [95% CI, 0.05 to 0.17]); the difference between eyeglasses alone and no treatment did not reach statistical significance, but the estimate of effect was also larger in this subgroup (0.11 logMAR [95% CI, -0.03 to 0.24]) than for all participants (0.08 logMAR [95% CI, 0.02 to 0.15]). For children with mild refractive error at baseline, neither patching plus eyeglasses nor glasses alone was significantly different than no treatment at the end of the trial (between-group differences were negligible [0.04 to 0.05 logMAR]; improvements were small in all three groups [from 0.19 to 0.24 logMAR]).

### KQ 4b Long-Term Amblyopia, School Performance, Functioning, and Quality of Life

We found no eligible studies that examined these outcomes.

### KQ 5 Harms of Treatment of Amblyopia, Its Risk Factors, and Refractive Error

We included one fair- and two good-quality trials (described in four articles) that evaluated harms of treatment (Table 5).^115-118^ Two of the included trials compared patching with no patching (children were pretreated with eyeglasses if indicated),^116, 117^ and one compared patching plus eyeglasses versus eyeglasses alone versus no treatment.^115^ None of the included studies evaluated atropine. Sample sizes ranged from 60^117^ to 180.^116^ All three enrolled preschoolers with a mean age ranging from 4 to 5.3 years. Duration of treatment (and followup) varied from 5 weeks (1 year)^116^ to 12 weeks (12 weeks)^117^ to 1 year (1.5 years).^115^ A single trial reported each outcome for which we found evidence; none of the included trials reported on similar outcomes. Overall, the trials provide limited evidence but suggest that patching may have some psychological harms.

#### Harms to the Nonamblyopic Eye

One trial comparing patching (n=87) with no patching (n=93) found that worsening visual acuity (decrease >1 line from baseline) in the nonamblyopic eye was not significantly different between groups at 5 weeks (2.4% vs. 6.8%, respectively; p=0.28).^116^ There was also no difference between treatment groups on the Randot Preschool Stereoacuity Test (p=0.6). Among children with no ocular deviation at baseline (n=118), five patients in the patching group and three patients in the no-treatment group had a new small-angle strabismus (1 to 8 PD), and one patient in the no-treatment group had a new strabismus of more than 8 PD.

#### Loss of Visual Acuity in the Amblyopic Eye

The trial comparing patching plus eyeglasses (n=59), eyeglasses alone (n=59), and no treatment (n=59) found no statistically significant difference between treatment groups at the 1-year followup in proportion of children with worsening of uncorrected visual acuity in the amblyopic eye (change >0.1 logMAR) among those with baseline mild acuity loss (9.7% vs. 6.5% vs. 13.3%; p=0.28) or baseline moderate acuity loss (15.0% vs. 11.1% vs. 23.8%; p=0.13); trends favored fewer children with loss of visual acuity in the treatment groups than in the no-treatment group.^115^

#### Psychological Harms

A substudy^118^ of the trial^115^ that compared patching plus eyeglasses, eyeglasses alone, and no treatment examined the emotional status of children undergoing treatment (144/177 participants completed questionnaires) and found there was no difference between treatment groups with regard to the child being happy, cooperative, or good tempered most or all of the time; teasing by siblings or friends; problems at preschool; or mean Rutter behavior score (a validated scale assessing emotional and behavioral problems in children). Parents completed a questionnaire assessing these items on a 4- or 5-point rating scale at baseline (all participants), 3 months after beginning treatment (participants in active treatment only), and 2 years after recruitment (all participants). However, the study reported that children were more upset by patching plus eyeglasses than by eyeglasses alone; less than a third of children wearing glasses were upset by treatment compared with more than half of children wearing patching and glasses (29% vs. 85% at age 4 years; p=0.03; 26% vs. 62% at age 5 years; p=0.005). Although the study reported some negative effects of glasses or patching for the child (difficulty wearing patch or glasses, upset, coping with treatment) and parent (worry about treatment, upset by treatment, arguments about treatment), it did not compare with psychosocial outcomes for the no-treatment group. Therefore, we are unable to determine how the reported psychosocial harms compared with no treatment.

#### Other Harms

One trial (N=60) comparing no treatment, patching for 3 hours per day, or patching for 6 hours per day reported that no patients experienced an adverse event, such as inverse amblyopia or patch allergy.^117^