# Chapter 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and Key Questions (KQs). Figure 1 shows the analytic framework and KQs that guided the review. The KQs for this review were:

1 Does screening for amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years reduce long-term amblyopia or improve visual acuity, school performance, functioning, and/or quality of life?
  a. Does the effectiveness of screening in children ages 6 months to 5 years vary among different age groups?
2 What is the accuracy and reliability of screening tests for amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years?
  a. Does the accuracy or reliability of screening tests for amblyopia, its risk factors, and refractive error vary among different age groups?
3 What are the harms of screening for amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years?
4a Does treatment of amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years improve visual acuity?
4b Does treatment of amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years reduce long-term amblyopia or improve school performance, functioning, and/or quality of life?
5 What are the harms of treatment of amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years?

Figure 1 Analytic Framework

Abbreviation: KQ=Key Question.

a Amblyopia risk factors include anisometropia, strabismus, hyperopia, any media opacity, astigmatism, and abnormal visual acuity (which includes substantial isoametropic refractive error).

b Determination of refractive error will be based on age-appropriate standards.

KQs to Be Systematically Reviewed

1 Does screening for amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years reduce long-term amblyopia or improve visual acuity, school performance, functioning, and/or quality of life?
  a. Does the effectiveness of screening in children ages 6 months to 5 years vary among different age groups?
2 What are the accuracy and reliability of screening tests for amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years?
  a. Do the accuracy and reliability of screening tests for amblyopia, its risk factors, and refractive error vary among different age groups?
3 What are the harms of screening for amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years?
4a Does treatment of amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years improve visual acuity?
4b Does treatment of amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years reduce long-term amblyopia or improve school performance, functioning, and/or quality of life?
5 What are the harms of treating amblyopia, its risk factors, and refractive error in children ages 6 months to 5 years?

This figure is the analytic framework depicting the five key questions and the research approach that guided the evidence review. In general, the figure illustrates the overarching question (key question 1): whether screening children ages 6 months to 5 years for visual impairment leads to improved health outcomes. The framework starts on the left with the patient population of interest: children ages 6 months to 5 years. Moving from left to right, the figure depicts the availability of tools to screen children for visual impairment and the accuracy and reliability of such tools (key question 2). There are potential harms of screening (key question 3). For children with visual impairment, treatment may improve health outcomes, such as visual acuity, reduced long-term amblyopia, school performance, functioning, and quality of life (key question 4). Treatment may also result in harms (key question 5).

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cumulative Index to Nursing and Allied Health Literature, and the Cochrane Library for English-language articles published from January 2009 through June 2016, with surveillance of the literature through June 7, 2017. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. We relied primarily on the 2011 systematic review for the USPSTF^67-69^ to identify potentially relevant studies published before 2009 (we reassessed all articles included in that systematic review using our eligibility criteria). We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform. Complete search terms and limits are listed in Appendix B. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies that met our inclusion criteria and added all previously unidentified relevant articles. We reviewed all literature suggested by peer reviewers or public comment respondents and incorporated eligible studies into the final review.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs with input from the USPSTF (Appendix B). We included English-language studies of children ages 6 months to 5 years conducted in countries categorized as “very high” on the United Nations Human Development Index. We excluded studies of children with eye injury/trauma, severe congenital conditions or developmental delays, retinopathy of prematurity, glaucoma, congenital cataract, neurodevelopmental disorders, systemic conditions associated with ocular abnormalities, or pathologic myopia. We excluded studies that were not available as full-text articles (e.g., conference abstracts, posters).

For KQs 1 through 3 (benefits, accuracy, and harms of screening), we required studies to enroll children without known impaired visual acuity or obvious symptoms of impaired visual acuity. For KQs 4 and 5 (benefits and harms of treatment), we included children with amblyopia, amblyopia risk factors, and/or refractive error. Studies performed in primary care, community-based, and school settings were eligible for all KQs. For KQs 2 through 5, studies performed in specialty settings (e.g., ophthalmology or optometry practices) were also eligible.

For KQs 1 through 3 (benefits, accuracy, and harms of screening), we included studies of screening tests used or available in primary care, including visual acuity tests (e.g., autorefraction; picture identification tests, such as Allen test cards or LEA symbols; HOTV chart; Snellen chart; tumbling E chart), stereoacuity tests (e.g., contour stereotests, such as the Frisby, Random Dot E, Stereo Smile, and Titmus Fly tests; Moving Dynamic Random Dot Stereosize test), and ocular alignment tests (e.g., photoscreening, corneal light reflex test, cover-uncover test, red reflex test). We excluded studies of screening tests not used or available in primary care settings (e.g., contrast sensitivity test, funduscopic examination, visual acuity test with cycloplegia) or not intended to detect amblyopia, amblyopia risk factors, or refractive error (e.g., white reflex test). For KQs 1 and 3 (benefits and harms of screening), we required studies to compare screened with nonscreened groups or earlier (at a younger age) versus later screening (at an older age). For KQ 2 (accuracy of screening), we required studies to compare the screening test with an evaluation that included cycloplegic refraction and/or a comprehensive eye examination. We excluded studies with no comparison group or nonconcordant historical controls.

For KQs 4 and 5 (benefits and harms of treatment), studies that evaluated correction of refractive error (eyeglasses), penalization of the nonamblyopic eye (eye patch, atropine), and vision therapy (eye exercises) were eligible. We required studies to compare the treatment with no treatment, sham, or inactive control. We excluded studies with no comparison group, nonconcordant historical controls, or comparative studies of various interventions (i.e., head-to-head studies without an additional comparison group).

We required studies for KQs 1 and 4 (benefits of screening and treatment) to report at least one of the following outcomes: long-term amblyopia, visual acuity, school performance, functioning, or quality of life. Eligible outcomes for KQ 2 were sensitivity; specificity; positive and negative predictive values; likelihood ratios; diagnostic odds ratios (ORs); and measures of reliability, including reproducibility, interrater reliability, and testability (ability of children to cooperate with the test). For KQs 3 and 5 (harms of screening and treatment), studies must have reported a harm, such as psychological distress, labeling, anxiety, other psychological effects, false-positive results, or adverse effects on vision in the nonimpaired eye.

For KQ 1, we included randomized, controlled trials (RCTs) and prospective cohort studies with an eligible comparator. For KQ 2 (screening accuracy), we included cross-sectional studies, cohort studies, or trials focused on assessment of diagnostic accuracy. We excluded studies that did not attempt to perform the reference standard in all participants or in a random sample of participants. For KQs 3 and 5 (harms), we included RCTs, controlled cohort studies, and case-control studies. For KQ 4 (benefits of treatment), only RCTs were eligible.

## Quality Assessment and Data Abstraction

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy. To provide a consistent metric for visual acuity outcome measures, results were converted to logMAR measurements using established conversion charts.^70^

We assessed the quality of studies as good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B).^71^ Two independent reviewers assigned quality ratings for each study. Disagreements were resolved by discussion with an experienced team member. We included only studies rated as good or fair quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular and narrative format. We did not attempt to quantitatively pool results of studies of test accuracy because of the considerable clinical and methodological heterogeneity, specifically as a result of the variety of screening cutoff definitions, target condition definitions, enrolled populations, and results. We did not attempt quantitative synthesis of treatment studies because there were too few trials making similar comparisons.

For KQ 2 (accuracy), we calculated sensitivity, specificity, likelihood ratios, and predictive values when sufficient data were reported by articles. When qualitatively evaluating likelihood ratios, we considered positive likelihood ratios (PLRs) to indicate a minimal (1–2), small (2–5), moderate (5–10), or large (>10) increase in the risk of the condition of interest (e.g., amblyopia or its risk factors). We considered negative likelihood ratios (NLRs) to indicate a minimal (0.5–1), small (0.2–0.5), moderate (0.1–0.2), or large (<0.1) decrease in the risk of the condition of interest. Likelihood ratios below 0.1 or above 10 are typically thought to provide strong evidence for ruling out (NLR <0.1) or ruling in (PLR >10) diagnoses.^72, 73^

We assessed the overall strength of the body of evidence for each KQ as high, moderate, low, or insufficient using methods developed for the USPSTF (based on methods of the Evidence-based Practice Center program^68, 69^), based on the overall quality of studies, consistency of results between studies, precision of findings, and risk of reporting bias. We also assessed the applicability of the findings to U.S. primary care populations and settings.

## Expert Review and Public Comment

This draft report was reviewed by content experts, USPSTF members, and AHRQ Medical Officers and was revised based on comments. It was also posted for public comment and revised based on public comments.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.